# EXCLUDED STUDIES

All studies listed were reviewed in their full-text version and excluded for the reason indicated.

Reference | Design not SR | Intervention not eligible CAM treatment | Population not primary depression or anxiety | Poor quality SR
Bohlmeijer_2010_EN2000 | | | X
Coelho_2008_EN1926 | | | X
Even_2008_EN1920 | | | | X
Freeman_2010_EN2003 | | X
Halbreich_2008_EN1936 | X
Hou_2010_EN1992 | | | X
Lee_2008_EN1937 | | | X
Li_2010_EN2066 | | X
Meeks_2007_EN1921 | | | X
Shih_2009_EN1990 | | | X
Teixeira_2010_EN1998 | X
Thachil_2007_EN1894 | | X
Tsang_2008_EN1930 | | X
Uebelacker_2010_EN1986 | X
van_der_Watt_2008_EN1932 | X