# SUMMARY AND DISCUSSION

This evidence synthesis was requested by VA Research and Development to review and summarize the empirical evidence for applications of common CAM therapies to the treatment of PTSD. Four KQs were identified to examine the efficacy of mind-body therapies (KQ 1), manipulative and body-based therapies (KQ 2), movement-based therapies (KQ 3), and relevant evidence derived from nonrandomized trials of CAM interventions for PTSD (KQ 4).

Our systematic literature search yielded six RCTs relevant to KQ 1, one relevant to KQ 2, and none to KQ 3. For KQ 4, which enabled us to expand our search beyond RCTs to include nonrandomized trials, two additional studies were identified. Most studies reviewed appeared to be preliminary investigations and were underpowered, limited by significant design flaws, and often provided inadequate descriptions of the intervention to permit replication. For each KQ, the evidence reviewed was limited. Indeed, perhaps our most striking finding overall was the relative dearth of available evidence on CAM applications for PTSD, despite clear consumer interest and widespread use of these treatments.

## SUMMARY OF EVIDENCE BY KEY QUESTION

For each KQ, we summarize the strength of evidence (SOE) and magnitude of treatment effects in Table 9. Interventions are compared to control or usual care and to active treatments separately. When the strength of evidence was rated insufficient, we did not calculate a treatment effect.

Table 9 Summary of the strength of evidence for KQs 1–3

Number of studies (subjects) | Domains pertaining to strength of evidence | | | | Magnitude of effect^a^ and SOE
| Risk of bias: design/quality | Consistency | Directness | Precision | PTSD symptoms: Effect estimate (95% CI)
KQ 1: Meditation vs. usual care | | | | | Low SOE
1 (29) | RCT/Fair | Not applicable | Direct | Imprecise | SMD: −0.32 (−1.46 to 0.05), self-report PCL; −0.70 (−1.06 to 0.41), interviewer-based CAPS
KQ 1: Meditation vs. active treatment | | | | | Insufficient SOE
1 (25) | RCT/Poor | Not applicable | Direct | Imprecise | Not estimated
KQ 1: Acupuncture vs. control | | | | | Moderate SOE
1 (84) | RCT/Good | Not applicable | Direct | Imprecise | SMD: −0.92 (−1.51 to −0.32), self-report PSS-SR
KQ 1: Acupuncture vs. group CBT | | | | | Low SOE
1 (84) | RCT/Good | Not applicable | Direct | Imprecise | SMD: −0.35 (−0.91 to 0.22), self-report PSS-SR
KQ 1: Relaxation vs. control | | | | | Insufficient SOE
1 (90) | RCT/Poor | Not applicable | Direct | Imprecise | Not estimated
KQ 1: Relaxation vs. other active treatment | | | | | Insufficient SOE
2 (56) | RCT/Fair to Poor | Consistent | Direct | Imprecise | Low^b^ SMD: 0.41 (−0.42 to 1.24), interviewer based SI-PTSD SMD: 0.79 (−0.13 to 1.71), interviewer based SS-PTSD
KQ 2: Massage vs. control | | | | | Insufficient SOE
1 (8) | RCT/Fair | Not applicable | Direct | Imprecise | Not estimated
KQ 3: Movement-based and energy therapies vs. control | | | | | Insufficient SOE
None | NA | NA | NA | NA | NA

a A negative SMD indicates a greater effect for the CAM therapy.

b SMDs were are reported separately for the two studies because a summary estimate was not indicated.

Abbreviations: CI = confidence interval, OR = odds ratio, NA = not applicable, RCT = randomized controlled trial, SMD = standardized mean difference, SOE = strength of evidence

Considered in sum, the highest quality evidence exists for acupuncture. However, strong conclusions cannot reliably be drawn on the basis of a single RCT; replication of findings is required. In addition, the active comparator in this study was group CBT, which is generally considered to be less potent than individual CBT therapies.55 The greatest breadth of evidence exists for relaxation interventions—we identified three RCTs that examined forms of breathing and muscle relaxation. In each case, the trials were preliminary and design flaws limited interpretation of study findings, which were positive overall. Further conclusions cannot be made in the absence of well-designed investigations of these modalities.

The evidence base for meditation therapies is similarly limited by a paucity of well-designed trials, although early evidence is promising. In addition to a lack of scientific rigor and the need to replicate preliminary findings, the current literature is limited to concentrative meditative techniques. No RCTs of other common mind-body interventions, including mindfulness meditation and yoga, were identified in our review of the published, peer-reviewed literature. However, we identified 16 ongoing and/or unpublished studies registered with ClinicalTrials.gov, suggesting that this is a growing area of research. Approximately half of these trials are ongoing, and the majority are recruiting active military and/or Veteran samples. Thus, a significantly larger and broader evidence base may be anticipated within the next several years.

For manipulative and body-based CAM therapies, the evidence base is extremely limited, and for movement-based and energy therapies, we identified no RCTs, published or in progress. Thus, the current and developing evidence bases for these therapies are likely to remain insufficient for clinical or policy recommendations in the near future.

More broadly, the limitations of the current evidence preclude conclusions about specific interventions, populations, formats, settings, appropriate treatment length or “dosing,” or other refinements to the development of these approaches. We found little evidence addressing adverse effects, and retention rates, when reported, were comparable to current evidence-based treatments.

## LIMITATIONS

Several limitations of the current review merit mention. First, we limited our literature search to clinical trials published in peer-reviewed, English-language journals. We also searched ClinicalTrials.gov for ongoing and unpublished trials, which served as a proxy “snapshot” of additional evidence that may be anticipated in the near future. However, our search did not extend to the “gray literature,” and thus excluded technical reports, white papers, and other evidence streams and formats that would not have been identified through standard database searches. In addition, we limited our literature search to CAM trials conducted in PTSD samples. Thus, the current review did not consider evidence of CAM applications in other anxiety disorders, major depression, or sleep disorders, for which there is symptom overlap and frequent comorbidity with PTSD. For example, in their review of CAM and self-help treatments for all anxiety disorders (generalized anxiety disorder was most frequently described), Jorm and colleagues56 found evidence from at least one well-designed RCT in support of acupuncture, aromatherapy, massage, dance and movement, meditation, relaxation training, and yoga. Other recent evidence reviews and meta-analyses have examined applications of massage in depression;57 energy therapies for health and mental health conditions;58 mindfulness-based stress reduction for anxiety, depression, pain, and chronic medical conditions;59–61 meditation therapy in anxiety disorders;62 and vipassana (mindfulness) meditation in a broad range of presentations.63 Evidence of effectiveness in closely related mental illnesses could provide indirect evidence of effectiveness for PTSD.

The current review also did not include applications of CAM treatments in nonclinical populations or noninterventional designs. Because relaxation training has been employed as a placebo control condition in PTSD treatment trials, our inclusion criteria specified that relaxation interventions be presented as active treatment and that the key components be described in sufficient detail. These criteria led to the exclusion of five RCTs of relaxation interventions for PTSD, which otherwise would have met criteria for inclusion in the current review. Of these, two were excluded because relaxation was a control rather than an active comparator,37,38 and three were excluded due to lack of detail about the relaxation condition, such that we could not confidently categorize the interventions as CAM.39–41 It merits mention that in these studies, relaxation showed modest effects and performed less favorability than active comparators. Thus, a wider set of inclusion criteria for the current review may have yielded a larger evidence base, and tempered enthusiasm for applications of relaxation-based monotherapies for PTSD. Likewise, we did not examine, or attempt to examine, issues of symptom overlap or comorbidity of PTSD and traumatic brain injury or other unique presentations that may be anticipated among OEF/OIF Veterans. In addition, the scope of our literature search excluded natural products (e.g., nutritional supplements), as was our charge. Finally, our review did not examine third-wave psychotherapies (e.g., mindfulness-based cognitive therapy, dialectical behavior therapy, and acceptance and commitment therapy) and related approaches. Despite some conceptual overlap with CAM and incorporation of CAM techniques such as meditation, these approaches are theoretically grounded in cognitive behavioral theory. They are understood to be extensions of mainstream approaches—and thus are distinct from CAM. Although outside of the scope of the current review, consideration of these strategies may inform broader understanding of the utility of CAM approaches for PTSD. It also merits mention that numerous forms and practices of mindfulness practice exist, such as seated meditation, movement-based practices, and even the occasional mindful enjoyment of a single raisin. The field may be best served at this stage of treatment development by considering a range of different approaches to cultivating mindfulness skills.

In addition to the above limitations, there are important strengths of our methodological approach as well. First, limiting our review to evidence gleaned from published, peer-reviewed trials allowed us to focus on quality over quantity when examining this relatively undeveloped body of research. Although many CAM approaches have been in practice for thousands of years, the application of rigorous methods to standardize and evaluate the efficacy of these treatments is a relatively new development in the field of interventional PTSD research. In addition, our evidence synthesis was guided by a carefully designed standardized protocol, including a systematic search of research databases and relevant bibliographies, double data abstraction, and use of AHRQ criteria to assess the quality of identified studies. Our multidisciplinary team included expertise in internal medicine, clinical psychology, epidemiology, acupuncture research, and integrative medicine. In sum, this was a highly structured and systematic review of the extant evidence.

## RECOMMENDATIONS FOR FUTURE RESEARCH

The limitations of the current evidence preclude our ability to draw strong conclusions to inform clinical practice or public policy regarding optimal use of CAM therapies for PTSD, yet the limitations in the available evidence point to numerous opportunities for future research. Questions remain about the efficacy, effectiveness, safety, cost-effectiveness, comparative effectiveness, mechanisms of actions, dosing, indications and contraindications, and differential response among subgroup populations. There are also unanswered questions about patient and provider preferences and expectations, optimal outcome, adherence and fidelity measures, and resource utilization patterns.

One of the most pertinent questions regarding CAM therapies for PTSD is, What effects might one expect of a given intervention relative to no intervention? This clinically relevant question is best addressed by a randomized clinical trial with a no-treatment (waitlist) comparator. This trial design controls for many threats to internal validity and is particularly appropriate when there are no or few controlled trials. However, study designs that withhold or delay treatment to those with PTSD may not be institutionally feasible or ethically defensible.64 In their thoughtful discussion of the methodological challenges inherent in this area of research, Devilly and McFarlane (2009)65 question the value and appropriateness of waitlist and placebo-controlled PTSD intervention trials given potential risks (e.g., greater chronicity, comorbidities, suicidality, functional impairments, and financial burden) that may be incurred when available evidence-based treatments are withheld or delayed. As an alternative to the standard RCT design, the authors demonstrate a means of deriving statistical estimates of waitlist control and placebo treatment effect sizes from existing data and applying these estimates to interpret the effects of future treatment innovations. Although this statistical approach has not been used widely, such strategies merit consideration as an alternative to the use of nonactive controls.

Another pertinent question is, To what extent might placebo, or nonspecific effects account for observed clinical outcomes? This question can be hard to answer for CAM therapies, for which it may be difficult to design a sham procedure that is both truly inert and that appears sufficiently similar to the active intervention to isolate the specific effect of the intervention. The fields of surgical and psychotherapy research have long grappled with similar issues. Strong recommendations and methodological guidelines now exist to guide these efforts. 66,67 Of the many CAM therapies with potential to serve as a therapeutic option in the treatment of PTSD, acupuncture is arguably the one with the most plausible placebo control. For example, it is possible, in the context of a clinical trial, to administer sham acupuncture such that research subjects are unable to determine with certainty whether they are receiving the true or sham treatment. The current standard in acupuncture research is to compare an active acupuncture intervention to both a sham acupuncture intervention and a no-acupuncture control. This three-arm RCT design makes it possible to simultaneously assess the efficacy or effectiveness and safety of a course of acupuncture while also partially addressing the extent to which nonspecific effects may contribute to observed outcomes.

Although more costly and challenging to conduct, comparative effectiveness designs also may be indicated to give patients and clinicians the most direct evidence about competing treatment options. These trials may be most appropriate and informative after additional preliminary work has fostered a stronger evidence base for CAM treatments of interest. Finally, practical clinical trials, which combine aspects of efficacy and effectiveness designs, merit consideration as a potentially more efficient and actionable alternative to traditional explanatory trials.68

Ultimately, the choice of which research strategy to employ should be determined by the key questions and the plausibility and estimates of benefit based on prior research.66,69–71 For example, explanatory trials are best suited to address the question, Can this intervention work? and pragmatic trials to address the question, Does this intervention work?69 For most CAM treatments, the basic question of “Can it work?” for PTSD has not been answered. Observational studies can provide good evidence about the feasibility of interventions and adverse effects that require large studies or long followup durations to detect. Smeeding and colleagues (2010)72 conducted a longitudinal evaluation of the effectiveness of an integrative health clinic and program within the Veterans Affairs Health Care System (VAHCS) for PTSD, chronic pain, stress-related depression, and anxiety. Observational studies of this kind can provide a rich source of information about the feasibility and acceptability of CAM treatments delivered within a VA setting. In addition, high-quality observational studies that show very large treatment effects can provide good evidence of treatment effect. For example, we do not need an RCT to prove the benefits of a good parachute when stepping out of an airplane at altitude. However, our review did not identify observational studies showing very large treatment effects for any of the CAM treatments evaluated. Thus, randomized, placebo (or sham intervention) controlled trials— the gold standard for evaluating intervention effects—will be the most logical design for the majority of studies planned to evaluate CAM interventions. Small exploratory trials would be a logical next step for the CAM interventions that lack any studies of treatment effect.67

Whether evaluated in RCTs or observational studies, evaluating CAM therapies is challenging.73,74 A complete description of the challenges is beyond the scope of this report, but issues of blinding patients and treating clinicians to the intervention assignment, accounting for the learning curve of procedural-based interventions, identifying the appropriate comparator, procedures to minimize attrition, and monitoring fidelity to the planned intervention are all key challenges. In addition, research on PTSD has important challenges, including the variety of traumas (e.g., combat, rape), the time since trauma, and the presence of medical or psychiatric comorbidity, all of which may impact treatment response. In addition to these more general challenges, we observed important variability in the completeness and consistency of PTSD outcome reporting. The evidence base for CAM treatments, and PTSD more generally, would be strengthened by a more uniform approach to outcome assessment. For our review, we prioritized PTSD symptom response, HRQOL, and adverse effects as the most important outcomes. Secondary outcomes included patient satisfaction, treatment adherence, and functional status. This prioritization of outcomes should be confirmed with stakeholders and then assessed more consistently across studies. To this end, the PROMIS initiative, an AHRQ-funded effort to develop a common battery of measures for many different conditions, may be a useful resource. Another important limitation of the current evidence base was the descriptions of treatment interventions, which were usually inadequate to permit replication. Glasziou and colleagues75 have recently proposed standards for intervention reporting to include sufficient detail to guide replication, including descriptions of the interventionists, the content of the intervention, the treatment setting, how and when the intervention was delivered, and the degree of flexibility permissible. Finally, health services research in the VA could be facilitated by developing procedure codes to capture CAM approaches used in the VA.

## CONCLUSIONS

Our systematic review identified seven RCTs and two nonrandomized studies of CAM interventions for PTSD. Our review of relevant studies registered with ClinicalTrials.gov further suggests that this modest empirical foundation is growing. The term CAM encompasses a broad range of treatments—not all of which may hold the same level of promise as applications for PTSD. The current absence of a strong signal pointing to any one CAM approach over others argues for investment in a set of adequately powered trials to evaluate the most promising therapies, rather than a single large trial for any one treatment. Given the current state of evidence, a two-pronged approach may be most appropriate at this stage to move the field forward. That is, a series of adequately powered RCTs may be indicated for select CAM interventions for which there is clear and strong preliminary signal, either based on good-quality, early empirical evidence (e.g., acupuncture), a sound theoretical rationale for efficacy in the absence of strong pilot findings (e.g., meditation), and/or promising data gleaned from the bench sciences (e.g., compelling animal models). For other CAM modalities for which the science and theory are even less well developed, such as energy therapies, more prudence is indicated, suggesting the utility of exploratory pilot studies as the appropriate next step. In addition, the efficiency and ultimate yield of future efforts may be further optimized by consensus agreement about, and concerted efforts to address, limitations identified in the current literature. Broadly, these limitations concern issues of appropriate design, outcome, and replication strategies. There is an opportunity for strategic, well-designed studies to address the substantial gaps in evidence identified in this review.