# RESULTS

## LITERATURE SEARCH

We identified 1776 unique citations from a combined search of MEDLINE^®^ (via PubMed^®^, n = 353), Embase^®^ (n = 451), CINAHL^®^ (n = 429), PsychINFO^®^ (n = 390), Cochrane Database of Systematic Reviews (n = 32), and the PILOTS database (n = 121). By manual examination of the bibliographies of included studies and review articles, we identified four additional citations. Of these, 1738 were excluded at the title-and-abstract level. Of the 1738 studies excluded at the title-and-abstract level, we reevaluated and categorized the reason for exclusion in a subsample of 600 citations. The most common reasons for exclusion were review article (23%); a drug or a non-CAM intervention (22%); a “standard treatment” (e.g., EMDR or CBT) without a CAM comparator (14%); a sample under 19 years of age (13%); a sample that did not have PTSD (10%); and evaluation of therapies that were neither standard for PTSD nor for CAM (10%).

An additional 29 studies were excluded following full-text review. The question of what type of relaxation study was applicable to our report was a complicated one. Our literature search identified six citations that included a relaxation treatment arm but did not meet full eligibility criteria. Of these, one did not evaluate a population with PTSD;35 one was determined not to be CAM because the relaxation was delivered in conjunction with biofeedback;36 two conceptualized the relaxation as a control group rather than an active treatment;37,38 and one study with three citations did not describe the key components of the relaxation intervention such that it could not be categorized as CAM or otherwise.39–41

Nine published studies were retained and abstracted for this evidence synthesis, including 7 RCTs (described in 12 articles) and 2 non-RCTs. Five articles contained previously described demographic or descriptive data for the seven RCTs; these studies are referred to as “companion” studies.

Additionally, our search of www.clinicaltrials.gov identified 438 potentially relevant, unpublished trials. Of these, 16 were RCTs of an eligible CAM therapy for PTSD and are described in the applicable KQ sections that follow. There were also three non-RCTs, described in the KQ 4 section.

Figure 2 illustrates each step of our literature search process. Appendix F provides a complete listing of articles excluded at the full-text stage, with reasons for exclusion.

Figure 2 Literature flow diagram

*Reference list includes additional references cited for background and methods plus Web sites relevant to KQs.

Abbreviations: KQ = key question, CAM = complementary and alternative medicine, PTSD = posttraumatic stress disorder, RCT = randomized controlled trial

## STUDY CHARACTERISTICS

Basic characteristics of these studies are summarized in Table 2. A total of 7 RCTs (296 subjects) and 2 non-RCTs (41 subjects) met eligibility criteria. Of the RCTs, three evaluated relaxation, two evaluated meditation, and one each evaluated acupuncture and massage interventions. There were no RCTs identified that examined movement-based or energy therapies. To be eligible for participation, all studies required patients to meet DSM criteria for PTSD, and four of the seven RCTs included military Veterans. All studies reported PTSD symptom outcomes, but health-related quality of life (HRQOL), patient satisfaction, social functioning, and adverse effects were reported less frequently. Only one RCT was good quality.

Table 2 Summary of study characteristics

Study | Study design (n) | Quality^a^ | Intervention vs. comparator | Outcome measures^b^
RCTs of mind-body interventions: KQ 1
Bormann et al., 2008^42^ | RCT (n = 29) | Fair | Mantram repetition vs. usual care | CAPS, PCL, Q-LES-Q-SF, FACIT-SpEx4, CSQ
Brooks and Scarano, 1985^43^ | RCT (n = 25) | Poor | Transcendental meditation vs. psychotherapy | PVSDS, individual items to assess employment status and family problems
Echeburúa et al., 1996^44^ | RCT (n = 20) | Poor | Progressive muscle relaxation vs. cognitive behavioral therapy | SS-PTSD, SOA
Hollifield et al, 2007^45^ | RCT (n = 84) | Good | Acupuncture vs. group cognitive behavioral therapy vs. waitlist | PSS-SR, SDI
Vaughan et al., 1994^46^ | RCT (n = 36) | Fair | Applied muscle relaxation vs. image habituation training vs. EMDR | SI-PTSD, IES
Watson et al., 1997^47^ | RCT (n = 90) | Poor | Simple relaxation instruction vs. relaxation instruction + deep breathing vs. relaxation instruction + deep breathing and thermal biofeedback | PTSD-I M-PTSD
RCT of manipulative and body-based interventions: KQ 2
Price, 2006^48,49^ | RCT (n = 8) | Poor | Body-oriented therapy (massage) vs. waitlist | CR-PTSD
Non-RCTs of CAM therapies for PTSD: KQ 4
Abramowitz and Lichtenberg, 2010^50^ | Prospective cohort (n = 36) | NA | Hypnotherapeutic olfactory conditioning | IES-R
Hossack and Bentall, 1996^51^ | Case series (n = 5); 17 and 29 weeks | NA | Relaxation and visual kinesthetic dissociation | IES

a Study quality assessed via key quality criteria described in Agency for Healthcare Research and Quality’s (AHRQ’s) Methods Guide for Effectiveness and Comparative Effectiveness Reviews.31

b Outcomes limited to those with direct relevance to KQs 1–4 (i.e., PTSD severity/diagnosis, HRQOL).

Abbreviations: CAPS = Clinician-Administered PTSD Scale, CR-PTSD = Crime-Related Post Traumatic Stress Disorder Scale, EMDR = eye movement desensitization and reprocessing, FACIT-SpEx4 = Functional Assessment of Chronic Illness Therapy–Spirituality-Expanded Version 4, IES = Impact of Events Scale, IES-R = Impact of Events Scale–Revised, M-PTSD = Mississippi Scale for Combat-Related PTSD, NA = not applicable, PCL = Posttraumatic Stress Disorder Checklist (-M is military version), PSS-SR = Posttraumatic Symptom Scale–Self Report, PTSD-I = Posttraumatic Stress Disorder Interview, PVSDS = Post-Vietnam Stress Disorder Scale, Q-LES-Q-SF = Quality of Life Enjoyment and Satisfaction Questionnaire–Short Form, RCT = randomized controlled trial, SI-PTSD = PTSD Structured Interview, SOA = Scale of Adaptation, SS-PTSD = Scale of Severity of Posttraumatic Stress Disorder, SDI = Sheehan Disability Inventory

Common study limitations included (1) a lack of power to draw meaningful conclusions, (2) the absence of explanations for missing data and dropouts, and (3) analyses that were performed on completers rather than intent-to-treat samples. In addition, important aspects of the study design and sample characteristics were frequently unclear in the fair- and poor-quality articles. For example, it was difficult in every case to discern whether the groups being compared were truly comparable at baseline. The nonrandomized studies used prospective cohort and case series designs.

Table 3 summarizes the outcome measures included in this evidence synthesis, listing the abbreviated and full name of each instrument, format, number of items, score range, and interpretation of scoring.

Table 3 Summary of outcome measures

Abbreviation | Name of instrument | Format | # of items | Range | Interpretation
CAPS^a^ | Clinician-Administered PTSD Scale | Semistructured interview | 17 | 0–136 | Higher score = more severe PTSD symptoms
CR-PTSD^b^ | Crime-Related Post Traumatic Stress Disorder Scale | Self-report scale | 28 | 0–112 | Higher score = more severe PTSD symptoms
CSQ | Client Satisfaction Questionnaire | Self-report scale | 8 | 8–36 | Higher score = more satisfaction with treatment
FACIT-SpEx4 | Functional Assessment of Chronic Illness Therapy– Spirituality-Expanded Version 4 | Self-report scale | 23 | 0–184 | Higher score = better quality of life
IES^c^ | Impact of Events Scale | Self-report scale | 15 | 0–75 | Higher score = more severe PTSD symptoms
IES-R | Impact of Events Scale–Revised | Self-report scale | 22 | 0–88 | Higher score = more severe PTSD symptoms
M-PTSD | Mississippi Scale for Combat-Related PTSD | Self-report scale | 35 | 35–175 | Higher score = more severe PTSD symptoms
PCL | PTSD Checklist | Self-report scale | 17 | 17–85 | Higher score = more severe PTSD symptoms
PSS-SR | Posttraumatic Symptom Scale–Self-Report | Self-report scale | 17 | 0–51 | Higher score = more severe PTSD symptoms
PTSD-I | Posttraumatic Stress Disorder Interview | Structured interview | 17 | 17–119 | Higher score = more severe PTSD symptoms
PVSDS | Post-Vietnam Stress Disorder Scale (unpublished) | NR | NR | NR | Higher score = more severe PTSD symptoms
Q-LES-Q-SF | Quality of Life Enjoyment and Satisfaction–Short Form | Self-report scale | 14 | 14–70 | Higher score = better quality of life
SDI | Sheehan Disability Inventory | Self-report scale | 3 | 0–30 | Higher score = greater functional impairment
SI-PTSD | PTSD Structured Interview | Structured interview | 17 | 0–68 | Higher score = more severe PTSD symptoms
SOA | Scale of Adaptation | Self-report scale | 6 | 6–36 | Lower score = better adaption to impact of sexual aggression on daily life
SS-PTSDS | Scale of Severity of Posttraumatic Stress Disorder Symptoms | Structured interview | 51 | 0–51 | Higher score = more severe PTSD symptoms

a Numerous scoring strategies exist. The number of items/range of scores presented here refer only to the interview items that assess DSM-IV diagnostic criteria. Additional CAPS items may administered to assess functioning, response validity, and presence of associated symptoms.

b Score is typically calculated and interpreted as the average item score.

c The IES does not assess Cluster D/hyperarousal PTSD symptoms, whereas the IES-R does include items to assess this symptom cluster.

Abbreviations: NR = not reported, PTSD = posttraumatic stress disorder

## KEY QUESTION 1 In adults with PTSD, are mind-body complementary and alternative medicine therapies (e.g., acupuncture, yoga, meditation) more efficacious than control for PTSD symptoms and health-related quality of life?

### Published literature

We identified six published RCTs that met our criteria for KQ 1. Of these, two examined meditation,42,43 one examined acupuncture,45 and three examined breathing/relaxation training.44,46,47 These studies are summarized in Table 4 and discussed in this section.

Table 4 Characteristics of mind-body interventions (KQ 1)

Study and quality rating | Population | Design details | Intervention | Comparator | Outcomes^a^
Bormann et al., 2008^42^ Fair | N = 29 Trauma: combat Mean age (SD): 56 (6.57) Male: 29 (100%) Military Veterans: 29 (100%) | PTSD diagnosis: DSM-IV by CAPS Key exclusions: Psychotic disorder Severe suicidality Inability to participate in a group Recruitment: PTSD orientation groups, fliers, brochures | 6 weekly, 90-minute group sessions of mantram repetition + home practice Led by psychiatric nurses | Usual care | Remission: NR Response: ES = between group differences NR HRQOL: ES = between group differences NR AE: NR Followup duration: 6 weeks (end of treatment)
Brooks and Scarano, 1985^43^ Poor | N = 25 Trauma: combat Mean age (SD): 33.3 (NR) Male: 25 (100%) Military Veterans: 25 (100%) | PTSD diagnosis: DSM-III (means of assessment not specified) Key exclusions: Substance abuse Major tranquilizers Psychiatric hospitalization Suicidal or homicidal Currently practicing TM Recruitment: from mental health clinic | 4-day workshop on transcendental meditation (TM), then weekly 60-minute sessions for 11 weeks + home practice 20 minutes/day, twice daily) Led by Maharishi-trained leader | Individual psychotherapy | Remission: NR Response: decreased PTSD symptom severity, p < .05; emotional numbness, p < .025 HRQOL: decreased family problems, p < .05 AE: NR Followup duration: 12 weeks (end of treatment)
Echeburúa et al., 1996^44^ Poor | N = 20 Trauma: rape/sex assault Mean age (SD): 22 (6.9) Women: 20 (100%) Veterans: none | PTSD diagnosis: DSM-IIIR by SS-PTSDS Key exclusions: Other serious mental illness Time since trauma > 3 months Recruitment: Consecutive patients seeking treatment | Progressive muscle relaxation (PMR) Five 1-hour sessions Intervention not well described | Cognitive restructuring, coping skills training, and PMR | Remission: 5 of 10 treatments vs. 8 of 10 control had no symptoms Response: no between group differences HRQOL: NR AE: NR Followup duration: 5 weeks (end of treatment) and 2,4,7, 13 months
Hollifield et al., 2007^45^ Good | N = 84 Trauma: childhood sexual/physical abuse Mean age (SD): 42.2 (NR) Male: 27 (32.14%) Veterans: none | PTSD diagnosis: DSM-IV by SCID Key exclusions: substance abuse, psychosis, current other active treatment for PTSD Recruitment: clinical referral, advertisement, flyers, other media, professional contacts, word of mouth | Acupuncture (traditional Chinese medicine) with 11 to 14 solid needles placed for 25–40 minutes with manipulation + 15 minutes/day of home-based therapy (ear seeds) | Cognitive behavioral therapy or waitlist | Remission: NR Response (PSS-SR < 16): Acupuncture = 15 (63%), maintained at 24 weeks CBT = 9 (36%), increased to 13 (52%) at 24 weeks Waitlist = 4 (17%), NR at 24 weeks HRQOL: acupuncture and CBT groups improved compared to WL control AE: 1 in acupuncture group Followup duration: 12 weeks (end of treatment) and 24 weeks
Vaughan et al., 1994^46^ Fair | N = 36 Trauma: childhood abuse, sexual/physical assault, transportation Mean age (SD): 32 (14.7) Male: 13 (36.11%) Veterans: none | PTSD diagnosis: DSM-IIIR by SI-PTSD Key exclusions: severe personality disorder, psychosis Recruitment: from mental health clinic | Applied muscle relaxation (early recognition of anxiety, progressive muscle relaxation, passive muscle (“release-only”) relaxation, cue-controlled relaxation | EMDR or exposure therapy | Remission: no between group differences Response: no between group differences HRQOL: NR AE: NR Followup duration: 2 to 3 weeks (end of treatment) and 24 weeks
Watson et al., 1997^47^ Poor | N = 90 Trauma: combat Mean age (SD): 45.6 (NR) Male: 90 (100%) Military Veterans: 90 (100%) | PTSD diagnosis: DSM-IIIR by PTSD-I Key exclusions: NR Recruitment: NR | 10 weekly, 30-minute sessions of relaxation instruction (RI) or RI + deep breathing instruction | 10, weekly, 30-minute sessions of RI, deep breathing + thermal biofeedback | Remission: NR Response: NR HRQOL: NR AE: NR Followup duration: NR

a If comparator, outcomes given for intervention versus comparator.

Abbreviations: AE = adverse effects, CAPS = Clinician-Administered PTSD Scale, DSM = Diagnostic and Statistical Manual, EMDR = eye movement desensitization and reprocessing, ES = effect size, HRQOL = health-related quality of life, PCL = PTSD Checklist, PSS-SR = Posttraumatic Symptom Scale–Self Report, PTSD-I = Post-traumatic Stress Disorder Interview. Q-LES-Q-SF = Quality of Life Enjoyment and Satisfaction Questionnaire–Short Form, NR = not reported, NS = not significant, RI = relaxation instruction, SCID = Structured Clinical Interview for DSM, SD = standard deviation, SI-PTSD = PTSD Structured Interview

In addition to the published literature, our search of ClinicalTrials.gov identified 16 unpublished or ongoing studies relevant to this question (Table 5).

Table 5 Ongoing RCTs of mind-body interventions (KQ 1)

Study title | VA/DoD population? | Intervention | Comparator | Sponsor and clinicaltrials.gov ID | Funding start and stop date | Status
A Controlled Breathing Course for Social & Emotional Health for Vietnam Veterans with Chronic PTSD-RCT^a^ | Y | Yoga breathing technique; single group assignment | Not clearly specified | The University of Queensland NCT00256477 | Mar 2005–Oct 2005 | Completed^b^
Acupuncture for the Treatment of Posttraumatic Stress Among Military Personnel^a^ | Y | Acupuncture | Waitlist | Henry M. Jackson Foundation NCT00320138 | Mar 2006–Oct 2007 | Completed
Effectiveness of Three Different Psychotherapies for Chronic Post-Traumatic Stress Disorder | N | Interpersonal psychotherapy | 1. Prolonged exposure; 2. Relaxation | NIMH NCT00739765 | Apr 2008–Mar 2013 | Recruiting
Effect of EFT on Psychological States in a Veterans Population^a^ | Y | Emotional Freedom Techniques | Standard care | Soul Medicine Institute NCT0074341 | Dec 2008–May 2010 | Completed
Efficacy of Yoga for Treatment-Resistant Posttraumatic Stress Disorder | N | Yoga | Women’s health education | Justice Resource Institute NCT00839813 | Nov 2008–May 2011 | Recruiting
Evaluation of a MCYI as Adjunct of Psychiatric Treatment for Vietnam Veterans With PTSD-RCT^a^ | Y | Yoga | Usual care | The University of Queensland NCT00256464 | Jun 2007–Jan 2008 | Unknown
Evaluation of Telehealth Interventions for Post-Trauma Stress^a^ | Y | Mindfulness Telehealth Intervention | Self | Samueli Institute for Information Biology NCT00350584 | Feb 2007–Apr 2008 | Completed
Examining the Effect of Acupuncture on Sleep Difficulties Related to Post Traumatic Stress Disorder | Y | Acupuncture | 1. Sham acupuncture; 2. No intervention | Department of Veterans Affairs NCT00868517 | Oct 2009–Sep 2011 | Recruiting
Guided Imagery for Military Sexual Trauma-Related Posttraumatic Stress Disorder (PTSD)^a^ | Y | Guided imagery | Music | Duke University NCT00635635 | Oct 2007–Mar 2010 | Completed
Mechanistic Pathways of Mindfulness Meditation in Post-Traumatic Stress Disorder | Y | 1. Slow breathing; 2. Meditation; 3. Meditation + slow breathing | Sitting quietly | Oregon Health and Science University NCT00778960 | Jan 2009–Sep 2013 | Recruiting
Mind-Body Skills Groups for the Treatment of War Zone Stress in Military and Veteran Populations | Y | Mind-body skills | Standard treatment | The Center for Mind-Body Medicine NCT01093053 | Sep 2010–Aug 2012 | Recruiting
Mindfulness Based Stress Reduction for Posttraumatic Stress Disorder: A Pilot Study^a^ | Y | Mindfulness-based stress reduction | Usual care | Seattle Institute for Biomedical and Clinical Research NCT00880152 | Sep 2008–Dec 2009 | Completed
Neural Correlates of PTSD Prevention With Mindfulness Based Stress Reduction (MBSR) in Iraqi Veterans^a^ | Y | Mindfulness-based stress reduction | Supportive therapy | Department of Veterans Affairs NCT01058031 | Jan 2007–Nov 2010 | Completed
Pilot of Acupuncture to Improve Quality of life in Veterans with Traumatic Brain Injury (TBI) and Post-Traumatic Stress Disorder (PTSD) | Y | Acupuncture | Standard care | Department of Veterans Affairs NCT01060553 | Jul 2010–Jun 2011 | Recruiting
Psychological Symptom Change in Veterans After Six Sessions of EFT (Emotional Freedom Technique) | Y | Emotional Freedom Technique | Waitlist | Soul Medicine Institute NCT01117545 | May 2010–Jun 2013 | Recruiting
Study on the Psychotherapeutic Treatment for the Feeling of Being Contaminated After Childhood Sexual Abuse | N | Imagery modification | Waitlist | Goethe University NCT00976859 | Sep 2009–Dec 2011 | Recruiting

a No publication found.

b Author contacted, no results published in peer-reviewed journal as of May 2011.

Abbreviations: NCCAM = National Center for Complementary and Alternative Medicine, NIMH = National Institute of Mental Health, PTSD = posttraumatic stress disorder, RCT = randomized controlled trial

#### Meditation

Although various typologies of meditation practice exist, meditation may be broadly classified as concentrative or nonconcentrative (e.g., mindfulness meditation), depending on the manner in which mental attention is entrained. Concentrative techniques are those in which the practitioner intensely focuses on a particular object (e.g., a candle flame, the sensation of breathing, a word or sound) and tries to repeatedly bring focus back to the object if attention falters. In contrast, nonconcentrative techniques encourage practitioners to cultivate awareness and acceptance of all mental events. The goal is to observe moment-to-moment shifts in one’s internal experiences without controlling or judging their content.

In this evidence synthesis, we identified two studies42,43 involving a total of 54 patients that compared concentrative meditation to control (1 study) or to an active comparator (1 study). Both studies enrolled samples of male combat Veterans into group-based interventions and encouraged regular home practice. Sample sizes were relatively modest (n = 25 to 29), treatment length was brief (6 to 12 weeks), and outcomes were assessed at posttreatment only. We did not identify any published studies of nonconcentrative meditative techniques for PTSD.

Bormann and colleagues (2008)42 conducted a fair-quality RCT of 29 male combat Veterans who met DSM-IV criteria for PTSD. Participants were recruited from a VA medical center via clinical orientation groups or flyers and brochures. Participants randomized to the mantram intervention received six, 90-minute, weekly group sessions co-led by two psychiatric nurses. Session content included the use of mantram repetition (i.e., the spiritual practice of repeating a sacred word or phrase) to manage PTSD symptoms, slow down thinking to decrease reactivity, and foster mindfulness to train attention. Home practice and self-monitoring were encouraged. Participants randomized to this condition were allowed to maintain usual care, including medications. Patients allocated to the control condition received “usual care” that was not described further. Key inclusion criteria were male VA participants diagnosed with combat-related PTSD. Those with current psychosis or severe suicidality or those deemed unable to participate in a group were excluded.

Outcomes were assessed at posttreatment (6 weeks). PTSD severity was assessed with the Clinician-Administered PTSD Scale (CAPS) and PTSD checklist (PCL). HRQOL was assessed with the Functional Assessment of Chronic Illness Therapy–Spirituality-Expanded Version 4 (FACIT-SpEx4) and Quality of Life Enjoyment and Satisfaction Questionnaire–Short Form (Q-LES-Q-SF). Satisfaction with the mantram intervention was assessed with the Client Satisfaction Questionnaire (CSQ). Adverse effects and treatment adherence (i.e., group session adherence, home practice) were not reported. Steps to ensure treatment fidelity included the use of a treatment manual and expert review of randomly selected session recordings. This trial was conceptualized as a feasibility study, and some of its limitations were consistent with a preliminary effort, including nonblinding of group assignment, failure to report or address missing data, and a lack of followup assessments. In addition, the authors did not report or account for potential baseline between-group differences (e.g., PTSD severity) that may have influenced the findings.

Participants were randomized to the mantram intervention (n = 14) or control (n = 15). Change scores and effect sizes were provided for all outcome measures. However, because no inferential analyses were conducted, the statistical significance of reported differences was unclear. Posttreatment decreases in the severity of PTSD symptoms were larger in the intervention group compared to control. For the CAPS, mean change was −4.79 (SD = 7.45) versus −2.64 (SD = 5.44); effect size: −0.33. For the PCL, mean change was −8.79 (SD = 12.64) versus −1.20 (SD = 7.95); effect size: −0.72. A similar pattern of improvement was observed on both measures of HRQOL. For the Q-LES-Q-SF, mean change was 0.64 (SD = 0.93) versus 0.07 (SD = 0.70); effect size: 0.70. For the FACIT-SpEx4, mean change was 10.14 (SD = 9.49) versus 2.64 (SD = 12.62); effect size: 0.67. Eighty-six percent of participants who completed the mantram intervention, including those initially randomized to the waitlist control, rated their treatment satisfaction as “moderate to high” on the CSQ (mean scores not provided).

Brooks and Scarano (1985)43 conducted a poor-quality RCT that allocated 25 patients to either a 12-week transcendental meditation (TM) group (n = 13) or individual psychotherapy (n = 12). TM is a spiritually-based form of mantram. All potential participants were seeking treatment for combat-related trauma symptoms at the Denver Vet Center. No specific inclusion criteria were listed, and it was not clear if all participants met full diagnostic criteria for PTSD. Exclusion criteria included history of psychiatric hospitalization, current suicidal or homicidal ideation, or currently practicing TM. With the exception of the study treatments, the authors did not specify whether participants were able to begin or continue other behavioral or pharmacological therapies during the study period.

TM was taught in a 4-day workshop that included daily 90-minute sessions led by an individual who was trained by Maharishi Mahesh Yogi (TM developer), followed by 11, 1-hour, weekly followup meetings. Home practice for 20 minutes twice daily was recommended. No additional information about the TM trainer was provided. Therapists providing psychotherapy to participants randomized to the comparison condition held a minimum of a master’s degree in social work or psychology. The primary study outcomes, measured at baseline and posttreatment (12 weeks), were the “degree” of PTSD and emotional numbness assessed with the Post-Vietnam Stress Disorder Scale (PVSDS), an unpublished measure. Additional items assessed aspects of HRQOL, including employment status and family problems. Adverse effects (except for discontinuation) were not reported.

Several significant design flaws limited interpretability of study findings, including the use of unpublished and unvalidated measures; failure to describe subject characteristics (although the authors indicated that there were no between-group differences at baseline); no measure of adherence (group attendance, home practice) or treatment fidelity; and failure to measure or report other treatments received during the study period. Because a single interventionist delivered the TM intervention, treatment and therapist effects were confounded. Finally, although not specifically addressed by the authors, this preliminary study enrolled a relatively modest sample size and certainly was not adequately powered for equivalence hypothesis testing (nor was it intended to be).

Comparable proportions of participants in each study arm completed 12 weeks of treatment: 10 (77%) completed TM and 8 (67%) completed individual therapy. Reasons for discontinuation were not reported. Mean pretreatment and posttreatment scores were provided for the PVSDS. However, no information was provided about possible range and interpretation of scores, which largely limited their interpretability. Controlling for pretreatment values, greater reduction in PTSD severity was observed for the TM group (9.70 ± 2.98 to 5.80 ± 4.26) versus psychotherapy group (11.71 ± 2.63 to 10.86 ± 2.85, p < .05). This was also true for the Emotional Numbness Scale for TM versus psychotherapy (3.70 ± 1.64 to 1.70 ± 1.95 versus 3.75 ±1.03 to 3.50 ± 1.41, p < 0.05, respectively). At posttreatment, those in the TM group were also more likely to report fewer family problems (p < 0.05), whereas no between-group difference in employment status was observed. Within-group, paired t-tests showed significant improvement on all self-reported measures for the TM group and no significant changes at posttreatment for the psychotherapy group.

To summarize, the findings of two short-term RCTs provided limited support for two forms of concentrative meditation for combat-related PTSD. Both studies examined relatively brief group therapy formats in all-male Veteran samples, with demonstrated effects on PTSD severity and HRQOL. However, both were preliminary inquiries, and design limitations compromised interpretability and generalizability of reported findings. Yet, together these studies demonstrate the feasibility of enrolling and retaining male Veterans into meditation group interventions, and both recorded improvement in posttreatment symptoms relative to baseline levels.

#### Acupuncture

Acupuncture, a branch of traditional Chinese medicine, has been used to treat mental illness in other countries for centuries. It comprises a varied group of procedures that can include needle placement in preselected or individually chosen points; in subcutaneous tissue or muscle; with or without manipulation, electrical stimulation or the use of “ear seeds” in addition to needle placement. However, it is unknown whether acupuncture can be used to treat PTSD successfully.

We identified a single, good-quality RCT by Hollifield and colleagues (2007)45 that allocated 84 patients who met DSM-IV criteria for PTSD either to acupuncture (n = 29); cognitive behavioral therapy (CBT) sessions (n = 28); or a waitlist control (n = 27). The intervention period was 12 weeks and comprised 24 acupuncture sessions or weekly group CBT sessions. Participants in the study were recruited by clinician referrals and advertisements in the local media; no VA or DoD settings were included. Key exclusions were comorbid psychotic disorder or substance abuse or current engagement in a PTSD-specific treatment. However, participants could continue stable supportive therapy or prescribed medication for another psychiatric disorder, such as depression.

Biweekly acupuncture treatments were 60 minutes each and included a symptom interview; pulse and tongue evaluation; needle insertion, manipulation, and retention; and Vaccaria seed (or “ear seed”) placement. Participants were instructed to massage the seeds, which were taped to specific points on the ear, for 15 minutes every day between sessions. Treatment was administered by an experienced, licensed acupuncturist trained in traditional Chinese medicine. Weekly, 2-hour group CBT sessions followed a manualized protocol. To equalize amount of attention to the problem the two groups experienced, home practice of CBT methods for 15 minutes/day was also encouraged, but adherence was not measured. The training and experience level of the therapist who led the CBT groups were not specified. Only one interventionist was assigned to each intervention; thus, treatment and therapist effects were confounded.

Assessments were conducted at baseline, 12 weeks (end of treatment), and 6 months (3-month followup). PTSD severity was measured with the Posttraumatic Symptom Scale–Self Report (PSS-SR), and HRQOL was measured with the Sheehan Disability Inventory (SDI). Treatment satisfaction was assessed among those randomized to acupuncture or CBT with a 10-item scale developed by the authors (α = 0.87). Neither treatment adherence nor treatment fidelity was reported. Among the 29 participants randomized to acupuncture, 65.5 percent were retained. Five withdrew before initiation of treatment and thus were not included in the analyzed sample (i.e., no baseline data). An additional five participants withdrew during treatment for the following reasons: incarceration (n = 1); conflicting medical treatments (n = 2); perceived adverse effects of acupuncture (n = 1); and difficulty keeping appointments (n = 1). Of the 28 participants randomized to CBT, 75 percent were retained. Three withdrew before treatment, and 4 withdrew during treatment due to difficulty keeping appointments (n = 2) and unknown reasons (n = 2). Among the 27 participants randomized to waitlist control, 77.8 percent were retained. Three withdrew before treatment, and three withdrew during the study period for unstated reasons. Intent-to-treat analyses included all participants for whom baseline data were available: acupuncture (n = 24); CBT (n = 25); and waitlist control (n = 24). Missing data were estimated using the last-observation-carried-forward method.

Mean PSS-SR scores decreased from baseline to the 12-week assessment in both the acupuncture group (31.3 ± 10.1 to 15.6 ± 13.9) and CBT group (32.5 ± 6.6 to 20.0 ± 10.6; p < .05) but remained essentially unchanged in the waitlist group (30.8 ± 9.5 to 27.9 ± 12.3). At 6 months, the treatment effects on PTSD symptoms persisted (PSS-SR scores =15.4, acupuncture; 16.7, CBT; and 27.9, waitlist control). Pairwise contrasts from 0 to 12 weeks were not statistically different between acupuncture and CBT (p = 0.29). Pairwise contrasts were statistically significant between both waitlist and acupuncture (p < 0.01) and CBT (p < 0.01).

Similar findings were observed for all three study arms on the SDI: scores decreased from baseline to the 12-week assessment in both acupuncture (3.8 ± 0.8 to 3.0 ± 1.3) and CBT (4.1 ± 0.8 to 3.3 ± 1.2; p < .05) but were again essentially unchanged in the waitlist control. SDI scores remained relatively stable across all three groups at 6 months. As with the PSS-SR, pairwise contrasts from baseline to posttreatment for the SDI were not statistically different between acupuncture and CBT (p = .83); However, there were statistically significant differences between waitlist and both acupuncture (p = .01) and CBT(p < .01). Global satisfaction with care was high, and there was no significant difference between groups in both acupuncture and CBT.

In summary, the findings from a single, good-quality RCT suggested that a 12-week course of acupuncture treatments was similar to group CBT (although not powered for equivalence hypothesis testing) and more effective than no acupuncture in reducing PTSD symptoms and improving HRQOL. The clinical improvement associated with acupuncture or CBT persisted for at least 3 months after completion of treatment.

#### Relaxation

Three studies involving 146 patients44,46,47 compared forms of relaxation training to active comparators; one also included a third, attention control arm47 Study quality ranged from poor44,47 to fair.46

The RCT by Echeburúa and colleagues (1996)44 randomly assigned 20 women who had experienced sexual aggression in the past 3 months to a CBT-based intervention that included cognitive restructuring plus coping skills training and progressive muscle relaxation (PMR)—or to PMR alone. In this comparative effectiveness design, both interventions consisted of five, 60-minute, weekly sessions administered by a doctoral-level therapist with 5 years’ experience conducting CBT for sexual assault-related PTSD. The therapist also was responsible for conducting all study assessments. Participants were recruited from three psychological counseling centers for women in Spain. All met DSM-IIIR criteria for acute PTSD (i.e., symptoms had persisted for > 1 month and < 3 months) per the Scale of Severity of Posttraumatic Stress Disorder Symptoms (SS-PTSDS). Severe psychiatric comorbidity (e.g., schizophrenia, mental deficiency) was the primary exclusion criteria.

The cognitive restructuring plus specific coping skills training intervention included:

- psychoeducation about sexual trauma and PTSD
- introduction of CBT techniques for modifying maladaptive thoughts and feelings related to sexual trauma
- coping skills training including PMR, thought stopping, and distraction
- instructions for self-guided exposure to avoided situations and stimuli

The PMR alone intervention provided psychoeducation and training in progressive muscle relaxation. For both conditions, PMR followed methods proposed by Bernstein and Borkovec.52 This study was considered poor quality because of nonblinding of subjects or the assessor/therapist, unclear randomization and allocation concealment, and no intent-to-treat analysis. Power was not calculated a priori and clearly was inadequate for comparative analyses. There was no measure of treatment fidelity, and adherence was unclear. Finally, inclusion of PMR in both intervention arms complicated interpretation of study findings in the absence of a clearer description of how applying this technique may have differed between treatment conditions.

Outcomes were assessed at baseline; posttreatment (5 weeks after baseline); and at approximately 2, 4, 7, and 13 months after baseline (i.e., 1, 3, 6, and 12 months after the end of treatment). It appears that all 20 patients completed treatment and remained in the study through the 13-month assessment. At baseline, mean score on the SS-PTSDS, the primary outcome measure, was 35.5 (SD = 7.96). Within groups, mean scores decreased from baseline to posttreatment, from 36.7 (SD = 8.59) to 12 (SD = 6.94) for the cognitive restructuring plus coping skills group, and from 34.3 (SD = 7.54) to 18.7 (SD = 9.20) for the PMR group. Scores decreased slightly in subsequent assessments in both groups. There were no statistically significant between-group differences. At posttreatment, 8 out of 10 patients (80%) in the cognitive restructuring plus coping skills group and 5 out of 10 (50%) in the PMR group no longer met criteria for PTSD. Additional improvements were observed at the 2-month followup (100% remission in the cognitive restructuring plus coping skills group versus 80% remission in the PMR group), which were retained at the 13-month followup. Results of the Scale of Adaptation (SOA), a measure of functional adaptation to the experience of sexual aggression, reflected significant reductions in both treatment groups, which were retained at the 13-month followup.

In the RCT by Vaughan and colleagues (1994),46 applied muscle relaxation (AMR) was compared to eye movement desensitization (EMD) and image habituation training (IHT), a form of exposure therapy. Thirty-six patients with PTSD referred to an outpatient PTSD clinic were randomly assigned to AMR (n = 11), EMD (n = 12), or IHT (n = 13). Participants’ trauma histories included violent crime, rape, child abuse, and motor vehicle accident. Schizophrenia and severe personality disorders were exclusions. At baseline, 22 percent reported subclinical levels of Category C (avoidance/numbing) symptoms and thus did not meet full DSM-IIIR criteria for PTSD.

Patients were scheduled to attend four sessions over a 2- to 3-week period. The AMR treatment, adapted from Ost (1987),53 taught participants to recognize early signs of anxiety and to apply relaxation techniques to manage and quell anxiety. During the treatment sessions, three increasingly brief, relaxation techniques were sequentially introduced: progressive muscle relaxation, release-only relaxation (i.e., passive muscle relaxation), and cue-controlled relaxation, in which self-instruction to “relax” was paired with the state of relaxation. Participants were expected to practice these techniques between sessions, 40 minutes per day. In the EMD condition (now known as eye movement desensitization and reprocessing [EMDR]), saccadic eye movements (induced by asking the patient to track the therapist’s hand as it moved rapidly across the visual field) were paired with associative elements of the traumatic memory, including imagery, cognition, affect, and physiological sensations. No between-session work was assigned to participants in the EMD group. Patients in the IHT group were required to listen to continuous-loop, audiotaped descriptions of their trauma and to record cognitions and anxiety levels on a homework sheet for 60 minutes per day. The level of education and training of the therapists was not reported, but all were trained in EMD by Francine Shapiro, the originator of the technique. This study was considered fair quality because of ambiguous reporting of methods (including lack of clarity about the adequacy of randomization, nonblinded assessments, inadequate treatment of missing data, lack of intent-to-treat analyses) and inadequate statistical power.

The primary PTSD-related outcome measure was the PTSD Structured Interview (SI-PTSD), assessed by a blinded rater at baseline, posttreatment (2 to 3 weeks), and 3 months. All three treatment groups were associated with significant improvement (p < 0.001) in SI-PTSD scores at the posttreatment and 3-month followup. There were no between-group differences in SI-PTSD scores at the baseline, posttreatment, or 3-month assessments. Adverse effects were not reported.

In a 3-arm, 10-week trial, Watson and colleagues (1997)47 randomized 90 male Vietnam-era Veterans to 1 of 3 relaxation training conditions: simple relaxation instruction (RI), RI plus deep breathing, or RI plus deep breathing plus thermal biofeedback. All were recruited by a technician at the St. Cloud, Minnesota VA Medical Center; additional details about recruitment procedures were not reported. All met DSM-IIIR criteria for PTSD, per the Posttraumatic Stress Disorder Interview (PTSD-I). Additional details about diagnostic procedures or specific inclusion/exclusion procedures were not provided. The technician, who was trained by a doctoral-level psychologist with 7 years’ experience in biofeedback and relaxation therapies, was responsible for recruitment, administration of all study treatments, and all study assessments—and thus was not blinded to treatment group assignment.

All 3 treatment conditions consisted of 10, 30-minute sessions conducted in a quiet, dimly lit laboratory in which participants were seated in a reclining chair and provided 10 minutes to adapt to room temperature before beginning each session. Regardless of treatment group assignment, each participant was attached to a biofeedback apparatus that monitored finger temperature and frontalis muscle tension. Participants randomized to the RI group were instructed to “relax as much as possible” during the sessions. Those in the RI plus deep breathing condition were also given instruction in deep breathing prior to each session and instructed to practice relaxing and deep breathing throughout the 30-minute session. Those in the RI plus deep breathing plus thermal biofeedback condition were additionally told that they would hear a tone, indicating their level of relaxation, and instructed to increase their finger temperature and lower the tone as much as possible by relaxing during the session. Thus, the three treatment arms could be conceptualized as an attention control (RI), relaxation/CAM intervention (RI + deep breathing), and biofeedback/traditional treatment.

Outcomes included PTSD-I total and individual item scores, Mississippi Scale for Combat-Related PTSD (M-PTSD), finger temperature, and frontalis muscle tension. This study was considered poor quality. Key limitations included unclear randomization and allocation concealment; inadequate treatment of incomplete outcome data; nonblinding of subject, provider, and assessor; no intent-to-treat analysis; and no power or sample size calculation/underpowered for comparative analyses. Adverse effects were not reported.

In the completer sample, significant pretreatment versus posttreatment (Week 10) differences were observed for two PTSD symptoms assessed by individual items on the PTSD-I: intrusive memories (p < .01) and exaggerated startle response (p < .05), as well as M-PTSD total scores (p < .05) and middle-finger skin temperature, reported as degrees Fahrenheit p < .05). However, no time-by-treatment group differences were noted. Analysis of outcome data was limited to those who completed at least 9 of the 10 treatment sessions. Those who missed more than one session were replaced by other volunteers; intent-to-treat results were not reported.

To summarize, the findings of three RCTs provided limited support for relaxation interventions for PTSD. However, none of these relatively small studies was adequately powered for comparisons of active treatment groups, and significant design flaws limited interpretability of study findings.

Overall, the findings from six published RCTs that included a mind-body complementary and alternative medicine therapy as an intervention demonstrated the following:

- Meditation techniques were associated with moderate improvements in symptoms and HRQOL compared to usual care only (one fair-quality study) and decreased symptom severity compared to individual psychotherapy (one poor-quality study).
- The clinical effectiveness of a course of acupuncture as a treatment for PTSD was similar to that of group CBT and greater than waitlist control (one good-quality RCT).
- Relaxation training was associated with moderate clinical improvement, but studies were small and favored the active comparator. Because 95 percent confidence intervals were large, an important clinical benefit for active comparators versus relaxation treatment was possible (three poor-quality RCTs).

### Unpublished literature

Our search of ClinicalTrials.gov identified 16 RCTs relevant to KQ 1. These studies are summarized in Table 5, organized alphabetically by trial name. We identified eight ongoing trials that are examining the following CAM interventions: acupuncture, emotional freedom techniques, guided imagery/imagery modification, mind-body skills, mindfulness meditation, relaxation, and yoga. In addition, we identified six completed studies for which we could not identify a publication that reported clinical outcomes; they included these interventions: acupuncture, emotional freedom techniques, guided imagery, mindfulness-based stress reduction, and yoga. There was also one trial on yoga with status listed as “unknown.” Of the completed studies, two had funding stop dates of April 2009 or earlier, raising the possibility of publication bias for these interventions. The authors of these two studies were contacted, and for one study (Acupuncture for Posttraumatic Stress Among Military Personnel), a manuscript is in development.

## KEY QUESTION 2 In adults with PTSD, are manipulative and body-based complementary and alternative medicine therapies (e.g., spinal manipulation, massage) more efficacious than control for PTSD symptoms and health-related quality of life?

### Published literature

We identified one poor-quality RCT by Price (2006)48,49 of body-oriented therapy in eight adult female subjects with histories of childhood sexual trauma (Table 6).

Table 6 Characteristics of manipulative and body-based interventions (KQ 2)

Study | Population | Design details | Intervention | Comparator | Outcomes^a^
Price, 2006^48,49^ | N = 8 Trauma: rape, childhood physical/sexual abuse Mean age (SD): 38 (NR) Women: 8 (100%) Veterans: none | PTSD diagnosis: Severity of PTSD by PCL Key exclusions: Substance abuse, currently involved in a violent relationship, Not currently in active psychotherapy, Not able to pay 50% of the cost for massage Recruitment: clinical referral | 8 weekly 60-minute sessions of body-oriented therapy (massage) + body awareness education and body-mind integration | Waitlist | Remission: Score below clinical cut-off— intervention group, 2 of 4 vs. waitlist group, 1 of 4 Response: symptom improvement, intervention group, p < .01 HRQOL = NR AE = NR Followup duration: 9 weeks (end of treatment)

a If comparator, outcomes given for intervention versus comparator.

Abbreviations: AE = adverse effect, NR = not reported, HRQOL = health-related quality of life, PCL = PTSD Checklist

Although formal PTSD diagnosis was not a study inclusion criterion, six of the eight women screened positive for PTSD at study inception, as indicated by baseline administration of the Crime-Related Post Traumatic Stress Disorder Scale (CR-PTSD)—the primary outcome variable. Participants were recruited through clinician referral, free advertisements on women’s groups’ Web sites, and emails to select graduate students; no VA or DoD settings were included. To be included, women had to be in active psychotherapy; be willing to stop any current bodywork one month prior to entering the study; and agree to pay 50 percent of the cost for the study-related bodywork sessions. Exclusion criteria were current substance abuse, involvement in a violent relationship, or psychiatric hospitalization within the last year. There was no requirement to maintain stable dosages of psychotropic medications. Four subjects were randomly allocated to eight, 1-hour sessions of Swedish-type massage, body awareness education, and “body-mind integration” (i.e., exploration of links between internal experiences and physiological sensations). The other four subjects were allocated to a waitlist control. The primary outcome measure, assessed at 9 weeks, was the CR-PTSD.

Pretreatment and posttreatment (Week 9) changes in scores were presented graphically, but axis labels were unclear, which hampered interpretation. Study limitations included incomplete descriptions of study participants, small sample size, and the potential for differing cointerventions across groups. In addition, the principal investigator collected and analyzed all data, and was not blinded to treatment condition. Although not explicitly stated, it appeared that the principal investigator also was the sole interventionist; her level of experience providing bodywork was not stated. This limitation introduces potential bias and confounds treatment and therapist effects. As is common for a small preliminary study, treatment adherence and fidelity were not assessed.

The sample was relatively homogeneous: 89 percent were white; 71 percent reported incomes equal to or greater than $25,000; and all had at least a bachelor-level education. Sexual orientation was fairly varied—nearly half reported homosexual or bisexual orientations. All subjects had been in psychotherapy at least 1 year (range 1 to 20), and five of eight women were taking psychotropic medications. By Week 9, clinical remission (per recommended screening cutoffs on the CR-PTSD) had occurred in two of four women in the intervention group and one of four women in the waitlist control group. Pretreatment and posttreatment within-group comparisons showed significant improvements for the intervention group but not for the control group on the CR-PTSD; between-group comparisons were not significant.

In summary, the findings from one small, poor-quality RCT in a relatively homogeneous sample provided modest support for the application of body-oriented therapy as an adjunctive treatment for women survivors of childhood sexual assault. We found no RCTs of manipulative or body-based CAM interventions in men, military or Veteran samples, or individuals with PTSD related to more recent traumatic stressors (versus childhood abuse). We were unable to identify published RCTs of other manipulative or body-based CAM interventions, such as chiropractic medicine and naturopathy, or of alternative applications and forms of massage therapy.

### Unpublished literature

Our search of ClinicalTrials.gov did not identify any RCTs relevant to KQ 2.

## KEY QUESTION 3 In adults with PTSD, are complementary and alternative medicine therapies that are movement-based or involve energy therapies more efficacious than control for PTSD and health-related quality of life?

Our literature search identified no published RCTs of movement-based or energy therapies for PTSD.

### Unpublished literature

Our search of ClinicalTrials.gov did not identify any RCTs relevant to KQ 3.

## KEY QUESTION 4 For treatments evaluated in KQs 1–3 that lack RCTs, is there evidence from other study designs that suggests the potential for treatment efficacy?

### Published literature

We identified two nonrandomized, prospective studies (Table 7) that assessed clinical outcomes over time among patients with PTSD who received a CAM intervention as defined in the Methods section.

Table 7 Characteristics of nonrandomized CAM treatment studies (KQ 4)

Study | Population | Design details | Intervention | Comparator | Outcomes
Abramowitz and Lichtenberg, 2010^50^ | Israeli combat Veterans with PTSD by DSM-IV. Mean age: 41.2 (12.2) Women: 0% Veterans: 100% | Prospective cohort (N = 36) Outcomes:; 1. Immediately posttreatment (6 weeks); 2. 6 months; 3. 1 year | Hypnotherapeutic olfactory conditioning Six 1.5-hour sessions over 6 weeks | NA | Remission: NR Response: IES-R; improvement was significant at the 6-week posttreatment assessment and remained improved at 6 and 12 months
Hossack and Bentall, 1996^51^ | Male volunteers who met DSM- III-R criteria for PTSD Mean age: 34.8 (10.26) Women: 0% Veterans: 0% | Multiple baseline design across subjects (N = 5) Outcome: Subjects 1 and 2 received intervention at 3 weeks from baseline; subject 3 received intervention at 6 weeks from baseline; subjects 4 and 5 received intervention at 9 weeks from baseline | 4 therapy sessions including Relaxation: Jacobson’s method and guided imagery Two sessions Visual kinesthetic dissociation Two sessions | Baseline | Response: 3 patients reported decrease in intrusive imagery, 1 reported “less clear cut improvement,” and 1 showed “no improvement”

Abbreviations: DSM = Diagnostic and Statistical Manual of Mental Disorders, IES-R = Impact of Events Scale-Revised, NA = not applicable, NR = not reported, PTSD = posttraumatic stress disorder

A prospective cohort study by Abramowitz and Lichtenberg (2010)50 involved 36 Israeli veterans with combat-related PTSD and treatment-resistant, olfactory-induced flashbacks. DSM-IV diagnostic criteria were determined by semistructured, clinical interview. Participants underwent a form of brief hypnotherapy that entailed six, 90-minute, weekly hypnotherapeutic olfactory conditioning sessions in addition to standard CBT and stress management strategies (including imaginal exposure to the traumatic event). The core components of the intervention included:

- Session 1: repeated pairing of pleasant memories with a pleasant-smelling essential oil (i.e., classical conditioning)
- Session 2: hypnotic induction, imaginal reexperiencing of functioning well under stress, paired with hypnotic suggestion that the participant can manage PTSD-related intrusive memories and flashbacks
- Session 3: use of guided imagery, hypnosis, and suggestion around themes of mastery, control, and safety, paired with the pleasant scent identified in the initial session
- Sessions 4 and 5: repeated imaginal exposure to traumatic memories under hypnosis, paired with the pleasant scent
- Session 6: review of treatment gains, new skills, and plans to maintain and use new skills, particularly when triggered by olfactory stimuli

Compared to baseline, the Impact of Events Scale-Revised (IES-R) scores were significantly improved at 6 weeks, 6 months, and 12 months. The investigators also reported significant decreases at 12 months, relative to baseline, in dosage and use of SSRIs, benzodiazepine, and neuroleptic medications.

The multiple baseline case series by Hossack and Bentall (1996)51 examined a visual-kinesthetic dissociation intervention in five male U.K. residents who reported severe intrusive imagery and met DSM-IIIR criteria for PTSD. Study diagnoses were determined by forensic psychiatrists and confirmed by brief clinical interview by the lead author. Participants’ trauma histories included surviving an industrial helicopter crash (n = 1) and witnessing a crowd surge at a football stadium that resulted in 95 deaths (n = 4). In addition to the five participants who completed treatment, a sixth participant enrolled but dropped out during the baseline phase and was not included in study analyses. The Impact of Events Scale (IES), which assesses Cluster B (“reexperiencing”) and Cluster C (“avoidance and numbing”) symptoms, was the primary measure of PTSD severity. Participants also completed daily diaries of duration, clarity, and related distress. The four-session intervention was administered in two phases:

- Relaxation: In the first two individual sessions, participants were taught to apply progressive muscle relaxation and guided imagery techniques to promote relaxation. Instruction in guided imagery emphasized incorporation of multiple sensory modalities (visual, kinesthetic, auditory, olfactory, and gustatory) in preparation for the next treatment phase.
- Visual-kinesthetic dissociation: In the final two sessions, participants were taught to apply relaxation skills and multisensory imagery techniques to imagine themselves at the cinema and to switch vantage points between being within a film of their trauma (first person), watching the film (second person), and watching themselves watch the film (third person). Using a manualized protocol, participants were then taught to manipulate the color and speed of the film and to run it backward and forward while repeatedly rotating their experience of the image from the first-, second-, and third-person perspectives.

In addition to daily diaries of intrusive events, assessments were conducted at regular intervals across the 17 weeks in which this multiple baseline design study was conducted, as well as 3-month followup (29-week assessment). No descriptive or inferential statistical analyses were conducted. However, visual plots of each participant’s symptom change over time were presented and discussed. The authors report “substantial” reductions in IES scores for four of the five participants (although two showed evidence of some posttreatment increase in avoidance). Daily diary results indicated that four participants reported sizable decreases in the experience of intrusive imagery (maintained at 3-month followup), whereas one experienced a modest increase. The authors noted that daily diary results suggested important (albeit preliminary) differences in how participants responded to the different treatment components: for one participant, relaxation seemed the most potent; for another, visual-kinesthetic dissociation had the greatest impact; and two others seemed to respond to both interventions.

In summary, the two published, nonrandomized studies identified by our systematic search provided little evidence of broad potential efficacy in PTSD for any of the CAM interventions of interest. One study50 presented initial pilot findings of a multimodal intervention that included both CAM (hypnotherapy, guided imagery) and imaginal exposure techniques. Although initial findings are promising, the study appears most applicable to the subgroup of combat Veterans who are particularly sensitive to olfactory triggers. Because the study sample was limited to men, it provided no additional information about the potential efficacy of CAM modalities in women. Likewise, a second study in five males provided limited initial information about the feasibility and potential utility of brief CAM intervention that included instruction in relaxation skills and imagery techniques including imaginal exposure.

In addition to these studies, one additional nonrandomized study,54 which was published after we conducted our literature search, was identified during the peer review process. In a study by Rosenthal and colleagues (2011), five OEF/OIF Veterans who met DSM-IV diagnostic criteria for combat-related PTSD were instructed in transcendental meditation (TM) by a certified instructor and asked to practice the technique for 20 minutes, twice daily, during the 12-week study period. Clinician support was provided through the study duration via biweekly, face-to-face meetings, as well as telephone, email, and text message contacts. At 8-week followup, patients showed improvements in the clinician-rated PTSD symptom severity (CAPS: M change score = 31.4, p = 0.02), self-reported PTSD symptom severity (PCL: M change score = 24.00, p < .02), and self-reported quality of life (Q-LES-Q-SF: M change score = −13.00, p < 0.01). The results of this small, uncontrolled study provide additional preliminary support for applications of meditation in Veterans with PTSD.54

### Unpublished literature

Our search of ClinicalTrials.gov identified two non-RCTs relevant to KQ 4. These studies are summarized in Table 8, organized alphabetically by trial name. Both trials examined yoga. One is still recruiting, but the other is completed with a funding stop date of April 2009 or earlier, raising the possibility of publication bias for this intervention.

Table 8 Nonrandomized studies (KQ 4)

Study Title | VA/DOD population? | Intervention | Comparator | Sponsor and clinicaltrials.gov ID | Funding start and stop date | Status
Evaluation of a Yoga Intervention for Post-Traumatic Stress Disorder | Y | Yoga | None | Brigham and Women’s Hospital NCT00962403 | Aug 2009–Dec 2010 | Recruiting
Yoga as a Therapy for Traumatic Experience^a^ | Y | Yoga | None | Samueli Institute for Information Biology NCT00269490 | Dec 2005–Aug 2007 | Completed

a No publication found