# REFERENCES

1 Kessler RC, Berglund P, Demler O, et al. Lifetime prevalence and age-of-onset distributions of DSM-IV disorders in the National Comorbidity Survey Replication. Arch Gen Psychiatry. 2005;62(6):593-602. [pmid: 15939837].
2 Amaya-Jackson L, Davidson JR, Hughes DC, et al. Functional impairment and utilization of services associated with posttraumatic stress in the community. J Trauma Stress. 1999;12(4):709-24. [pmid: 10646189].
3 Calhoun PS, Bosworth HB, Grambow SC, et al. Medical service utilization by veterans seeking help for posttraumatic stress disorder. Am J Psychiatry. 2002;159(12):2081-6. [pmid: 12450960].
4 Helzer JE, Robins LN, McEvoy L. Post-traumatic stress disorder in the general population. Findings of the epidemiologic catchment area survey. N Engl J Med. 1987;317(26):1630-4. [pmid: 3683502].
5 Hoge CW, Terhakopian A, Castro CA, et al. Association of posttraumatic stress disorder with somatic symptoms, health care visits, and absenteeism among Iraq war veterans. Am J Psychiatry. 2007;164(1):150-3. [pmid: 17202557].
6 Jakupcak M, Cook J, Imel Z, et al. Posttraumatic stress disorder as a risk factor for suicidal ideation in Iraq and Afghanistan War veterans. J Trauma Stress. 2009;22(4):303-6. [pmid: 19626682].
7 Prigerson HG, Maciejewski PK, Rosenheck RA. Population attributable fractions of psychiatric disorders and behavioral outcomes associated with combat exposure among US men. Am J Public Health. 2002;92(1):59-63. [pmid: 11772762].
8 Thomas JL, Wilk JE, Riviere LA, et al. Prevalence of mental health problems and functional impairment among active component and National Guard soldiers 3 and 12 months following combat in Iraq. Arch Gen Psychiatry. 2010;67(6):614-23. [pmid: 20530011].
9 Weisberg RB, Bruce SE, Machan JT, et al. Nonpsychiatric illness among primary care patients with trauma histories and posttraumatic stress disorder. Psychiatr Serv. 2002;53(7):848-54. [pmid: 12096168].
10 Hosek JR. United States. Dept. of Defense. Office of the Secretary of Defense., National Defense Research Institute (U.S.). How is deployment to Iraq and Afghanistan affecting U.S. service members and their families? An overview of early RAND research on the topic. Santa Monica, CA. RAND Corporation. 2011.
11 Seal KH, Metzler TJ, Gima KS, et al. Trends and risk factors for mental health diagnoses among Iraq and Afghanistan veterans using Department of Veterans Affairs health care, 2002–2008. Am J Public Health. 2009;99(9):1651-8. [pmid: 19608954].
12 Rosenheck RA, Fontana AF. Recent Trends In VA Treatment Of Post-Traumatic Stress Disorder And Other Mental. Health Aff (Millwood). 2007:1720-1727. [pmid: 17978391].
13 Kessler RC, Davis RB, Foster DF, et al. Long-term trends in the use of complementary and alternative medical therapies in the United States. Ann Intern Med. 2001;135(4):262-8. [pmid: 11511141].
14 Barnes PM, Bloom B, Nahin RL. Complementary and alternative medicine use among adults and children: United States, 2007, National health statistics reports; no 12. Hyattsville, MD. National Center for Health Statistics. 2008. Available at: http://nccam.nih.gov/news/2008/nhsr12.pdf. Accessed May 31, 2011.
15 Unutzer J, Klap R, Sturm R, et al. Mental disorders and the use of alternative medicine: results from a national survey. Am J Psychiatry. 2000;157(11):1851-7. [pmid: 11058485].
16 The Management of Post-Traumatic Stress Working Group. VA/DoD Clinical Practice Guideline for Management of Post-Traumatic Stress. 2010.
17 Bisson J, Andrew M. Psychological treatment of post-traumatic stress disorder (PTSD). Cochrane Database Syst Rev. 2007;(3):CD003388. [pmid: 17636720].
18 Foa EB. International Society for Traumatic Stress Studies. Effective treatments for PTSD: practice guidelines from the International Society for Traumatic Stress Studies. 2nd ed. New York. Guilford Press. 2009.
19 Institute of Medicine (IOM). Treatment of posttraumatic stress disorder: An assessment of the evidence. Washington, DC. The National Academies Press. 2008.
20 Bradley R, Greene J, Russ E, et al. A multidimensional meta-analysis of psychotherapy for PTSD. Am J Psychiatry. 2005;162(2):214-27. [pmid: 15677582].
21 Stein DJ, Ipser JC, Seedat S. Pharmacotherapy for post traumatic stress disorder (PTSD). Cochrane Database Syst Rev. 2006;(1):CD002795. [pmid: 16437445].
22 Zohar J, Amital D, Miodownik C, et al. Double-blind placebo-controlled pilot study of sertraline in military veterans with posttraumatic stress disorder. J Clin Psychopharmacol. 2002;22(2):190-5. [pmid: 11910265].
23 Davidson J, Baldwin D, Stein DJ, et al. Treatment of posttraumatic stress disorder with venlafaxine extended release: A 6-month randomized controlled trial. Arch Gen Psychiatry. 2006;63(10):1158-1165. [pmid: 17015818].
24 Hoge CW, Castro CA, Messer SC, et al. Combat duty in Iraq and Afghanistan, mental health problems, and barriers to care. N Engl J Med. 2004;351(1):13-22. [pmid: 15229303].
25 Feeny NC, Zoellner LA, Mavissakalian MR, et al. What would you choose? Sertraline or prolonged exposure in community and PTSD treatment seeking women. Depress Anxiety. 2009;26(8):724-31. [pmid: 19544313].
26 Anderson IM. Selective serotonin reuptake inhibitors versus tricyclic antidepressants: a meta-analysis of efficacy and tolerability. J Affect Disord. 2000;58(1):19-36. [pmid: 10760555].
27 Hageman I, Andersen HS, Jorgensen MB. Post-traumatic stress disorder: a review of psychobiology and pharmacotherapy. Acta Psychiatr Scand. 2001;104(6):411-22. [pmid: 11782234].
28 Kessler RC, Soukup J, Davis RB, et al. The use of complementary and alternative therapies to treat anxiety and depression in the United States. Am J Psychiatry. 2001;158(2):289-94. [pmid: 11156813].
29 Smith TC, Ryan MA, Smith B, et al. Complementary and alternative medicine use among US Navy and Marine Corps personnel. BMC Complement Altern Med. 2007;7:16. [pmid: 17506899].
30 Gordon JS. The White House Commission on Complementary and Alternative Medicine Policy: final report and next steps. Altern Ther Health Med. 2002;8(3):28-31. [pmid: 12017497].
31 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. Available at: http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. Accessed May 31, 2011.
32 Guyatt GH, Oxman AD, Vist GE, et al. GRADE: an emerging consensus on rating quality of evidence and strength of recommendations. BMJ. 2008;336(7650):924-6. [pmid: 18436948].
33 Cohen J. Statistical power analysis for the behavioral sciences. 2nd ed. Hillsdale, NJ. L. Erlbaum Associates. 1988.
34 Kraemer HC, Kupfer DJ. Size of treatment effects and their importance to clinical research and practice. Biol Psychiatry. 2006;59(11):990-6. [pmid: 16368078].
35 Short A. Theme and variations on quietness: Relaxation-focused music and imagery in aged care. Australian Journal of Music Therapy. 2007;18:39-61.
36 Carlson JG, Chemtob CM, Rusnak K, et al. Eye movement desensitization and reprocessing (EDMR) treatment for combat-related posttraumatic stress disorder. J Trauma Stress. 1998;11(1):3-24. [pmid: 9479673].
37 Marks I, Lovell K, Noshirvani H, et al. Treatment of posttraumatic stress disorder by exposure and/or cognitive restructuring: a controlled study. Arch Gen Psychiatry. 1998;55(4):317-25. [pmid: 9554427].
38 Echeburua E, de Corral P, Zubizarreta I, et al. Psychological treatment of chronic post-traumatic stress disorder in victims of sexual aggression. Behav Modif. 1997;21(4):433-56. [pmid: 9337600].
39 Taylor S. Outcome Predictors for Three PTSD Treatments: Exposure Therapy, EMDR, and Relaxation Training. J Cogn Psychother. 2003;17(2):149-161.
40 Taylor S, Thordarson DS, Maxfield L, et al. Comparative efficacy, speed, and adverse effects of three ptsd treatments: exposure therapy, emdr, and relaxation training. J Consult Clin Psychol. 2003;(2):330-8. [pmid: 12699027].
41 Stapleton JA, Taylor S, Asmundson GJ. Effects of three PTSD treatments on anger and guilt: exposure therapy, eye movement desensitization and reprocessing, and relaxation training. J Trauma Stress. 2006;(1):19-28. [pmid: 16568469].
42 Bormann JE, Thorp S, Wetherell JL, et al. A spiritually based group intervention for combat veterans with posttraumatic stress disorder: feasibility study. J Holist Nurs. 2008;26(2):109-16. [pmid: 18356284].
43 Brooks J, Scarano T. Transcendental Meditation in the Treatment of Post-Vietnam Adjustment. Journal of Counseling and Development. 1985;64:212-215.
44 Echeburúa E, de Corral P, Sarasua B, et al. Treatment of acute posttraumatic stress disorder in rape victims: An experimental study. J Anxiety Disord. 1996;10(3):185-199.
45 Hollifield M, Sinclair-Lian N, Warner TD, et al. Acupuncture for posttraumatic stress disorder: a randomized controlled pilot trial. J Nerv Ment Dis. 2007;195(6):504-13. [pmid: 17568299].
46 Vaughan K, Armstrong MS, Gold R, et al. A trial of eye movement desensitization compared to image habituation training and applied muscle relaxation in post-traumatic stress disorder. J Behav Ther Exp Psychiatry. 1994;25(4):283-91. [pmid: 7706505].
47 Watson CG, Tuorila JR, Vickers KS, et al. The efficacies of three relaxation regimens in the treatment of PTSD in Vietnam war veterans. J Clin Psychol. 1997:917-23. [pmid: 9403395].
48 Price C. Body-oriented therapy in sexual abuse recovery: A pilot-test comparison. J Bodyw Mov Ther. 2006;10(1):58-64.
49 Price C. Characteristics of women seeking body-oriented therapy as an adjunct to psychotherapy during recovery from childhood sexual abuse. J Bodyw Mov Ther. 2004;8(1):35-42.
50 Abramowitz EG, Lichtenberg P. A new hypnotic technique for treating combat-related posttraumatic stress disorder: a prospective open study. Int J Clin Exp Hypn. 2010;58(3):316-28. [pmid: 20509071].
51 Hossack A, Bentall RP. Elimination of posttraumatic symptomatology by relaxation and visual-kinesthetic dissociation. J Trauma Stress. 1996;9(1):99-110. [pmid: 8750454].
52 Bernstein DA, Borkovec TD. Progressive relaxation training : a manual for the helping professions. Champaign, Ill. Research Press. 1973.
53 Ost LG. Applied relaxation: description of a coping technique and review of controlled studies. Behav Res Ther. 1987;25(5):397-409. [pmid: 3318800].
54 Rosenthal JZ, Grosswald S, Ross R, et al. Effects of transcendental meditation in veterans of Operation Enduring Freedom and Operation Iraqi Freedom with posttraumatic stress disorder: a pilot study. Mil Med. 2011;176(6):626-30. [pmid: 21702378].
55 Schnurr PP, Friedman MJ, Foy DW, et al. Randomized trial of trauma-focused group therapy for posttraumatic stress disorder: results from a department of veterans affairs cooperative study. Arch Gen Psychiatry. 2003;60(5):481-9. [pmid: 12742869].
56 Jorm AF, Christensen H, Griffiths KM, et al. Effectiveness of complementary and self-help treatments for anxiety disorders. Med J Aust. 2004;181(7 Suppl):S29-46. [pmid: 15462640].
57 Hou WH, Chiang PT, Hsu TY, et al. Treatment effects of massage therapy in depressed people: a meta-analysis. J Clin Psychiatry. 2010;71(7):894-901. [pmid: 20361919].
58 Adams E. Brief Overview: Complementary and Alternative Therapies for Post Traumatic Stress Disorder. Veterans Health Administration Office of Patient Care Services Technology Assessment Program. 2009.
59 Bohlmeijer E, Prenger R, Taal E, et al. The effects of mindfulness-based stress reduction therapy on mental health of adults with a chronic medical disease: a meta-analysis. J Psychosom Res. 2010;68(6):539-44. [pmid: 20488270].
60 Grossman P, Niemann L, Schmidt S, et al. Mindfulness-based stress reduction and health benefits. A meta-analysis. J Psychosom Res. 2004;57(1):35-43. [pmid: 15256293].
61 Hofmann SG, Sawyer AT, Witt AA, et al. The effect of mindfulness-based therapy on anxiety and depression: A meta-analytic review. J Consult Clin Psychol. 2010;78(2):169-83. [pmid: 20350028].
62 Krisanaprakornkit T, Krisanaprakornkit W, Piyavhatkul N, et al. Meditation therapy for anxiety disorders. Cochrane Database Syst Rev. 2006;(1):CD004998. [pmid: 16437509].
63 Chiesa A. Vipassana meditation: systematic review of current evidence. J Altern Complement Med. 2010;16(1):37-46. [pmid: 20055558].
64 World Medical Association. Declaration of Helsinki - Ethical Principles for Medical Research Involving Human Subjects. Available at: http://www.wma.net/en/30publications/10policies/b3/. Accessed May 31, 2011.
65 Devilly GJ, McFarlane AC. When Wait Lists Are not Feasible, Nothing Is a Thing That Does not Need to Be Done. J Consult Clin Psychol. 2009;77(6):1159-1168. [pmid: 19968391].
66 Schnurr PP. The rocks and hard places in psychotherapy outcome research. J Trauma Stress. 2007;20(5):779-92. [pmid: 17955539].
67 Cook JA. The challenges faced in the design, conduct and analysis of surgical randomised controlled trials. Trials. 2009;10:9. [pmid: 19200379].
68 Schnurr PP, Friedman MJ, Engel CC, et al. Cognitive behavioral therapy for posttraumatic stress disorder in women: a randomized controlled trial. JAMA: Journal of the American Medical Association. 2007;297(8):820-830. [pmid: 17327524].
69 Karanicolas PJ, Montori VM, Devereaux PJ, et al. A new ‘mechanistic-practical” framework for designing and interpreting randomized trials. J Clin Epidemiol. 2009;62(5):479-84. [pmid: 18468856].
70 March J, Kraemer HC, Trivedi M, et al. What have we learned about trial design from NIMH-funded pragmatic trials?. Neuropsychopharmacology. 2010;35(13):2491-501. [pmid: 20736990].
71 Parmar MK, Ungerleider RS, Simon R. Assessing whether to perform a confirmatory randomized clinical trial. J Natl Cancer Inst. 1996;88(22):1645-51. [pmid: 8931608].
72 Smeeding SJ, Bradshaw DH, Kumpfer K, et al. Outcome evaluation of the Veterans Affairs Salt Lake City Integrative Health Clinic for chronic pain and stress-related depression, anxiety, and post-traumatic stress disorder. J Altern Complement Med. 2010;16(8):823-35. [pmid: 20649442].
73 Langevin HM, Wayne PM, Macpherson H, et al. Paradoxes in acupuncture research: strategies for moving forward. Evid Based Complement Alternat Med. 2011;2011:180805. [pmid: 20976074].
74 Leon AC, Davis LL. Enhancing clinical trial design of interventions for posttraumatic stress disorder. J Trauma Stress. 2009;22(6):603-11. [pmid: 19902462].
75 Glasziou P, Chalmers I, Altman DG, et al. Taking healthcare interventions from trial to practice. BMJ. 2010;341:c3852. [pmid: 20709714].