# METHODS

## TOPIC DEVELOPMENT

This review was commissioned by the Department of Veterans Affairs’ Evidence-based Synthesis Program. The key questions (KQs) were developed after a topic refinement process that included a preliminary review of published, peer-reviewed literature and consultations with content experts and key stakeholders in the treatment of PTSD. During this topic refinement process, selected CAM therapies were prioritized for the report; natural products (e.g., dietary supplements) were excluded. CAM therapies were classified using categories proposed by the NCCAM, and the KQs reflect this classification.

The final KQs were:

KQ 1 In adults with PTSD, are mind-body complementary and alternative medicine therapies (e.g., acupuncture, yoga, meditation) more efficacious than control for PTSD symptoms and health-related quality of life?
KQ 2 In adults with PTSD, are manipulative and body-based complementary and alternative medicine therapies (e.g., spinal manipulation, massage) more efficacious than control for PTSD symptoms and health-related quality of life?
KQ 3 In adults with PTSD, are complementary and alternative medicine therapies that are movement-based or involve energy therapies more efficacious than control for PTSD symptoms and health-related quality of life?
KQ 4 For treatments evaluated in KQs 1–3 that lack randomized controlled trials, is there evidence from other study designs that suggests the potential for treatment efficacy?

## ANALYTIC FRAMEWORK

We developed and followed a standard protocol for all steps of this review. Our approach was guided by the analytic framework shown in Figure 1.

Figure 1 Analytic framework for CAM therapies for PTSD

Examples of interventions:

- Mind-body therapies: acupuncture, meditation, yoga, deep-breathing exercises, guided imagery, hypnotherapy, progressive relaxation, and tai chi
- Manipulative and body-based therapies: spinal manipulation and massage therapy
- Movement-based therapies: Feldenkrais method, Alexander technique, Pilates, Rolfing Structural Integration, and Trager Psychophysical Integration
- Energy therapies: magnet therapy, light therapy, qi gong, Reiki, and healing touch

## SEARCH STRATEGY

We searched English-language publications in MEDLINE^®^ (via PubMed^®^), Embase^®^, PsycINFO^®^, Cumulative Index to Nursing and Allied Health Literature® (CINAHL), and the Cochrane Controlled Trials Registry from database inception through December 22, 2010. Search terms included terms for CAM therapies (acupuncture, mind-body, sensory art, yoga, reflexotherapy, musculoskeletal manipulation), PTSD, and RCTs. We used these limit terms: all adults ≥ 19 years of age, humans, and English. In addition, we searched the Published International Literature on Traumatic Stress (PILOTS) database (April 26, 2011), a specialized PTSD database maintained by the National Center for Posttraumatic Stress Disorder, to identify existing systematic reviews and studies of relaxation treatments.

We supplemented electronic searching by examining the bibliographies of included studies and review articles. When RCTs were not identified, we searched for prospective studies by adapting the sensitive “therapy filter” contained in PubMed clinical queries. To assure completeness, search strategies were developed in consultation with a master librarian. The search terms and MeSH headings for the search strategies appear in Appendix A. In addition to searching the published literature, we searched ClinicalTrials.gov (www.clinicaltrials.gov) (April 7, 2011) to identify studies in progress or completed studies that have not been published in the peer-reviewed literature.

## STUDY SELECTION

Using prespecified inclusion/exclusion criteria, two reviewers assessed the list of titles and abstracts. Full-text articles identified by either reviewer as potentially relevant were retrieved for further review. Each article retrieved was reviewed by two reviewers using the eligibility criteria in Appendix B; disagreements were resolved by discussion or by a third reviewer. To be included in the evidence synthesis, a study had to (1) be an RCT, (2) compare an eligible treatment to an empirically-based treatment or to a control condition, and (3) include a sample diagnosed with PTSD. Because relaxation is often used as a placebo control in trials of psychotherapy, we further specified that relaxation interventions must be presented as an active treatment and described in sufficient detail to understand the key components. As noted earlier, studies that included relaxation training introduced within the context of a standard PTSD therapy, such as prolonged exposure or SIT, were conceptualized as non-CAM and thus ineligible for this review. In the absence of any RCT for a given treatment, we examined other prospective study designs. In response to a request from stakeholders, we categorized reasons for exclusion in a subsample of 600 studies excluded during the initial abstract review. Detailed eligibility criteria are described in Table 1.

Table 1 Summary of inclusion and exclusion criteria

Study characteristic | Inclusion criteria | Exclusion criteria
Study design | KQs 1–3: RCTs KQ 4: Other study designs when no RCTs were identified^a^ | Non–English language publication Non–peer-reviewed publication
Population | Adults ≥ 19 diagnosed with PTSD using DSM criteria, validated severity measures (e.g., PTSD checklist), or clinical diagnosis Patients in acute-phase treatment (i.e., not selected for treatment-resistant PTSD) | Patients with complicated PTSD or acute suicidality Studies with eligibility criteria requiring a diagnosis of PTSD comorbid with another mental or physical illness (e.g., PTSD and substance abuse)
Interventions | Any of the following eligible treatments:; - Mind-body therapies: acupuncture, meditation, yoga, deep-breathing exercises, guided imagery, hypnotherapy, progressive relaxation, and tai chi; - Manipulative and body-based therapies: spinal manipulation and massage therapy; - Movement-based therapies: Feldenkrais method, Alexander technique, Pilates, Rolfing Structural Integration, and Trager Psychophysical Integration; - Energy therapies: magnet therapy, light therapy, qi gong, Reiki, and healing touch | Interventions used in a continuation or maintenance phase Dietary supplements Standard psychotherapies (e.g., prolonged exposure) and extensions of these therapies (e.g., mindfulness-based cognitive therapy) Relaxation used as a control arm or reported without describing the key components Biofeedback
Comparators | Studies comparing an eligible treatment to a control condition such as usual care (including no treatment), supportive therapy, attention control, sham intervention, or a waitlist Studies comparing an eligible treatment to an empirically based treatment, prolonged exposure, cognitive processing therapy, or antidepressant medication | None
Outcomes | Change in level of PTSD symptoms (i.e., on self- report and/or clinician-administered measures, including remission rates) or change in quality of life (i.e., functional status and health-related quality of life) Social functioning, patient satisfaction with treatment, treatment adherence/retention (e.g., proportion of prescribed sessions that are completed, completion of between-session assignments), and adverse treatment effects Reported at ≥ 6 weeks after treatment initiation | None
Setting | Patients recruited from community or outpatient mental health or general medical settings | Studies conducted outside North America, Western Europe, Australia, or New Zealand. Studies conducted outside of these countries were unlikely to be applicable to VA populations because of important differences in culture and health care systems.

a The eligibility criteria for nonrandomized controlled trials matched the criteria for KQs 1–3 except for study design. For each intervention that lacked eligible RCTs, we included prospective studies (nonrandomized controlled trials, controlled before-and-after studies, and prospective cohort studies and case series).

Abbreviations: DSM = Diagnostic and Statistical Manual of Mental Disorders, PTSD = posttraumatic stress disorder, RCT = randomized controlled trial, VA = Veterans Affairs

Studies identified from the ClinicalTrials.gov search were included if they were an RCT of an eligible CAM intervention and evaluated adults with PTSD. In addition, we included completed studies when a MEDLINE search (April 2011) using the name of the principal investigator did not identify a published study reporting clinical outcomes.

## DATA ABSTRACTION

A trained researcher abstracted data from published reports into a data abstraction form (Appendix C); a second reviewer overread the abstracted data. We resolved disagreements by consensus among the first and second reviewer or by obtaining a third reviewer’s opinion when consensus could not be reached. We abstracted the following data for each included study:

- study design
- setting
- population characteristics
- subject eligibility and exclusion criteria
- number of subjects and providers
- intervention(s)
- comparison(s)
- length of followup
- outcome(s)

For studies identified in ClinicalTrials.gov with no identified peer-reviewed publication of study results, we abstracted a limited set of data: study title, intervention, comparator, funding agency, funding dates, and study status.

## QUALITY ASSESSMENT

We assessed the risk of bias pertaining to the key questions using the quality criteria described in the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews (hereafter referred to as the Methods Guide),31 adapted for this specific topic. For RCTs, we abstracted data on adequacy of randomization and allocation concealment, comparability of groups at baseline, blinding, completeness of followup and differential loss to followup, whether incomplete data were addressed appropriately, validity of outcome measures and completeness of outcomes reporting, and conflict of interest. Using these data elements, we assigned a summary quality score of Good, Fair, or Poor to individual RCTs. Because non-RCT studies were included for descriptive purposes, we did not assess their quality.

We assessed studies for applicability to U.S. Veterans. In addition to the quality rating for individual studies, we evaluated the overall quality of the evidence for each KQ as proposed by the Grades of Recommendation, Assessment, Development, and Evaluation (GRADE) Working Group (Appendix D).32

## DATA SYNTHESIS

We critically analyzed studies to compare their characteristics, methods, and findings. We compiled a summary of findings for each KQ or clinical topic and drew conclusions based on a qualitative synthesis of the findings. There were not sufficient studies to perform quantitative meta-analyses. When the evidence was sufficient to estimate an effect, we computed the standardized mean difference (SMD) using Hedges g for continuous outcomes, to facilitate comparisons across studies. The SMD is useful when studies assess the same outcome, but with different measures. In this circumstance, it is necessary to standardize the results for the studies to a uniform scale to facilitate comparisons and to combine in meta-analysis. We calculated the SMD for each study by subtracting (at posttest) the average score of the control group from the average score of the experimental group and dividing the result by the pooled standard deviations (SDs) of the experimental and control groups. A negative SMD indicates a greater effect in the intervention group. For example, an effect size of −0.5 indicates that the mean decline in PTSD symptom severity for the experimental group is half an SD greater than the mean decline in the control group. SMD is commonly interpreted as small (0.2), moderate (0.5), or large (≥ 0.80).33,34

## RATING THE BODY OF EVIDENCE

We assessed the overall body of evidence for outcomes using a method developed by the GRADE Working Group, which classified the grade of evidence across outcomes according to the following criteria:

- High—Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate—Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low—Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Insufficient—Evidence on an outcome is absent or too weak, sparse, or inconsistent to estimate an effect.

## PEER REVIEW

A draft version of the report was reviewed by technical experts and clinical leadership, and their comments are provided in Appendix E.