# INTRODUCTION

Posttraumatic stress disorder (PTSD) is among the most common Axis I disorders, with an estimated lifetime prevalence in the U.S. of approximately 7 percent.1 PTSD is often chronic and is associated with significant adverse consequences, including high rates of depression and other psychiatric comorbidities; substance abuse; suicidality; impaired social, occupational, and family functioning; decreased quality of life; and increased rates of medical morbidity, health risk behaviors, and health service use.1–9 PTSD is the emotional disorder most frequently associated with combat and other potentially traumatic experiences that may occur during the course of military service (e.g., sexual assault, motor vehicle injury). Over 2.2 million U.S. troops have deployed in Operation Enduring Freedom and Operation Iraqi Freedom (OEF/OIF).10 One anticipated consequence of this sustained period of military operations is the increased incidence of PTSD among Veterans. Among OEF/OIF Veterans who received Department of Veterans Affairs (VA) care between 2002 and 2008, 22 percent were diagnosed with PTSD.11 In addition to increased mental health service use among this newest generation of Veterans, the VA has witnessed the sharpest increase in mental health service use among Vietnam-era Veterans.12 As the VA strives to anticipate and serve the treatment needs of the Veteran population, including those returning from current Middle East conflicts as well as Veterans of previous service eras, identifying and implementing effective PTSD treatment approaches remains a critical priority.

Complementary and alternative medicine (CAM) interventions are popular among consumers and are widely employed to treat diverse physical and mental health conditions.13 The results of a recent national survey show that nearly 38 percent of U.S. adults use CAM approaches to manage a range of physical and emotional health concerns, including pain, anxiety, and depression.14,15 Such widely used practices deserve careful evaluation and may hold promise as either adjunctive or primary PTSD therapies. Thus, this evidence synthesis was requested by VA Research and Development to inform decisions on the need for research in this area. This report reviews the evidence for common CAM approaches for PTSD—excluding natural products such as nutritional supplements—and examines mind-body therapies, manipulative and body-based practices, and practices that are movement-based or involve energy therapies.

## BACKGROUND

The current VA/Department of Defense (DoD) Clinical Practice Guideline for the Management of Posttraumatic Stress (October 2010)16 recommends the following evidence-based, first-line therapies for PTSD: (1) trauma-focused cognitive behavioral psychotherapies, (2) stress inoculation training (SIT), and (3) pharmacotherapies. These recommendations are largely consistent with previously published practice guidelines and systematic reviews (e.g., Bisson and Andrew,17 Foa and colleagues,18 Institute of Medicine19).

### Overview of Current Evidence-based PTSD Therapies

#### Trauma-focused psychotherapies

The category of trauma-focused psychotherapies incorporates several multicomponent, PTSD-specific interventions that share a theoretical foundation in cognitive behavioral principles. Consistent with a cognitive behavioral framework, the key components of trauma-focused psychotherapies may include in vivo and narrative/imaginal exposure as well as cognitive restructuring exercises. These treatments are designed to decrease emotional response through habituation and to modify maladaptive thoughts, behaviors, and emotions associated with PTSD. Most trauma-focused psychotherapy protocols combine administration of these exercises with psychoeducation and training in relaxation and anxiety-management techniques. Of note, several commonly employed relaxation techniques, such as breathing and muscle relaxation, are also consistent with CAM approaches. However, in the case of trauma-focused psychotherapies, these strategies are not hypothesized to be core mechanisms of change. Rather, they are introduced early in treatment to support the patient’s later engagement in key trauma-focused elements of treatment (e.g., exposure techniques and cognitive exercises).

The most well established of the trauma-focused psychotherapies are prolonged exposure therapy, cognitive processing therapy, and eye movement desensitization and reprocessing (EMDR). Although the comparative efficacy of these interventions has not yet been established,17 collectively the category of trauma-focused therapies has a strong empirical base. On average, 56 percent of patients who enter treatment (intent-to-treat) and 67 percent of patients who complete treatment no longer meet criteria for PTSD at posttreatment.20 In clinical trials, trauma-focused therapies show large effects compared to waitlist control (average effect size = 1.11) and moderate effects compared to supportive therapy (average effect size = 0.82).20

#### Stress inoculation training approaches

SIT protocols for PTSD provide training in anxiety management and coping skills to “inoculate” against heightened stress responses that are presumed central to the maintenance of PTSD. SIT protocols provide a tool kit of cognitive behavioral and mind-body stress management techniques, including progressive muscle relaxation, breathing retraining, positive thinking and self-talk, assertiveness training, and thought stopping.16 As with trauma-focused psychotherapies, several CAM techniques (e.g., release of muscle tension and breathing techniques to invoke relaxation) are common components of these interventions. However, SIT approaches (like trauma-focused psychotherapies) are theoretically grounded in cognitive behavioral theories of change and impart training in cognitive behavioral stress management techniques. Hence, for this review, and consistent with the theoretical basis of this treatment approach, SIT is considered a cognitive behavioral intervention.

#### Pharmacotherapies

First-line, evidence-based pharmacotherapies for PTSD include selective serotonin reuptake inhibitors (SSRIs) and serotonin norepinephrine reuptake inhibitors (SNRIs), administered as monotherapies.16,18,21 Both SSRIs and SNRIs are presumed to improve psychobiological dysfunction believed to be characteristic of the syndrome of PTSD. Of the SSRIs, the strongest evidence base currently exists for paroxetine and sertraline, for which response rates are near 60 percent.21,22

Among the SNRIs, venlafaxine has the strongest support.16 For example, one recent randomized controlled trial (RCT) found that 78 percent of patients treated with venlafaxine experienced a positive clinical response (i.e., > 30% decrease in symptom severity) although only 40 percent achieved remission.23 In contrast to current clinical practice guideline recommendations, it should be noted that the Institute of Medicine’s recent review of PTSD therapies (2007)19 concluded that there is insufficient evidence to support the use of pharmacotherapies for PTSD. In response to this controversial recommendation, one committee member appended19 an alternative conclusion in support of SSRIs as well as novel antipsychotics. Despite current controversies, pharmacotherapies—particularly SSRIs and SNRIs—are widely accepted as standard first-line treatment.

### Limitations of Current Evidence-based PTSD Therapies

Despite mounting empirical support for the treatments summarized above and tremendous efforts within the clinical research community to refine and optimize these approaches, each is associated with limitations and potential barriers to broad dissemination and uptake. Issues of access, patient preference/acceptability, and suitability are the primary limiting factors. For example, trauma-focused psychotherapies may provoke emotional responses, and some patients may have difficulty managing these reactions, or may choose not to engage in therapies that can cause emotional (albeit short-term) discomfort. Thus, the current VA/DoD Clinical Practice Guideline recommends careful screening of patients’ suitability for these modalities and recommends against their use with certain patients (e.g., those with current substance abuse, psychosis, or health problems for which intense physiological arousal is contraindicated).16 Also, all current evidence-based psychotherapies require specialized training and frequent provider contact, which may limit their accessibility. This potential limitation is of particular relevance for patients located in areas in which clinical resources are limited (e.g., rural) and those whose schedules cannot readily accommodate frequent sessions (e.g., because of work constraints or lack of childcare). Finally, psychotherapies are typically delivered in mental health specialty clinics, which may present a barrier for those concerned about perceived stigma associated with receiving care in a mental health setting, or for those who distrust mental health providers.24

In contrast to psychotherapies for PTSD, pharmacotherapies generally require less frequent and shorter contact with a provider and are routinely administered in both mental health and primary care clinics. However, some patients are not amenable to pharmacological interventions,25 and current evidence indicates that nearly 27 percent of patients will prematurely discontinue SSRIs due to treatment failure or adverse side effects, including sexual dysfunction, weight gain, and sleep disturbance.26 Finally, existing studies suggest that medications alone are often not sufficient to relieve symptoms, and there is some evidence that men are less likely than women to benefit from pharmacological PTSD treatments.27 Therefore, current evidence-based treatments for PTSD are not always appropriate, well-tolerated, accessible, adequate, or congruent with patient preferences.

### Complementary and Alternative Medicine

CAM is commonly used to describe a wide range of therapies that are not generally considered standard components of modern medicine as practiced by physicians in the U.S. Yet, many CAM treatments, such as acupuncture, are part of traditional medical practices in other parts of the world. The National Center for Complementary and Alternative Medicine (NCCAM) in the National Institutes of Health (NIH) has proposed a classification system for CAM therapies that includes natural products (e.g., dietary supplements, herbal remedies, probiotics), mind-body medicine (e.g., meditation, yoga, acupuncture), manipulative and body-based practices (e.g., spinal manipulation, massage therapy), whole medical systems (e.g., traditional Chinese medicine, Ayurvedic medicine), and other alternative practices (e.g., light or magnet therapy, movement therapies). Although this definition and classification system is helpful, it is imperfect since some treatments, such as biofeedback, are considered conventional treatment by some experts and CAM treatment by others. For some CAM therapies, such as acupuncture, there is a growing body of scientific literature evaluating efficacy or possible mechanisms of action. However, for many CAM therapies there remains a lack of scientific evidence on efficacy, harms, indications, appropriate dosing, or mechanisms of action.

### Rationale for an Evidence-based Synthesis of CAM Therapies for PTSD

CAM interventions are widely requested and used by mental health consumers including Veterans and active duty personnel; mental health–related concerns are among the most common reasons for seeking care from a CAM provider.13–15,28,29 If efficacious, these treatments may merit consideration as either first-line or adjunctive PTSD treatments. Most CAM treatments considered in this report are noninvasive or minimally invasive; considered unlikely to result in adverse side effects; and in some cases may be more congruent with individual treatment preferences than currently recommended traditional treatment options. Numerous stakeholders have expressed strong interest in fostering the evidence base for these approaches in PTSD.16,30 Consistent with these directives, this evidence synthesis was requested by VA Research and Development to inform decisions on the need for further research in this area. This report thus reviewed the evidence for common CAM approaches for treating PTSD.