# GLOSSARY

Acupuncture: A family of procedures involving stimulation of anatomical points on the body by a variety of techniques. American practices of acupuncture incorporate medical traditions from China, Japan, Korea, and other countries. The acupuncture technique that has been most studied scientifically involves penetrating the skin with thin, solid, metallic needles that are manipulated by the hands or by electrical stimulation.
Alexander technique: A movement therapy that uses guidance and education about ways to improve posture and movement. The intent is to teach a person how to use muscles more efficiently in order to improve the overall functioning of the body.
Ayurvedic medicine: A system of medicine that originated in India thousands of years ago. Ayurveda is based on theories of health and illness and on ways to prevent, manage, or treat health problems. A chief aim of Ayurvedic practices is to cleanse the body of substances that can cause disease, and this is believed to help reestablish harmony and balance.
Biofeedback: A technique that uses simple electronic devices to teach clients how to consciously regulate bodily functions, such as breathing, heart rate, and blood pressure, in order to improve overall health. Biofeedback is used to reduce stress, eliminate headaches, recondition injured muscles, control asthmatic attacks, and relieve pain.
Chiropractic care: A type of care that involves the adjustment of the spine and joints to influence the body’s nervous system and natural defense mechanisms to alleviate pain and improve general health. It is primarily used to treat back problems, headaches, nerve inflammation, muscle spasms, and other injuries and traumas.
Cognitive behavioral therapy (CBT): A psychotherapeutic approach that aims to solve problems concerning dysfunctional emotions, behaviors, and cognitions through a goal-oriented, systematic procedure. The term is used in diverse ways to designate behavior therapy, cognitive therapy, or therapy based on a combination of the two.
Cognitive processing therapy (CPT): A cognitive behavioral therapy for PTSD and related conditions. CPT conceptualizes PTSD as a disorder of “nonrecovery” in which erroneous beliefs about the causes and consequences of traumatic events produce strong negative emotions and prevent accurate processing of the trauma memory and natural emotions emanating from the event.
Complementary and alternative medicine (CAM): A group of diverse medical and health care systems, practices, and products that are not generally considered part of conventional medicine. Complementary medicine is used together with conventional medicine, and alternative medicine is used in place of conventional medicine.
Energy therapy: A practice that involves channeling of energy through the hands of a practitioner into the patient’s body to restore a normal energy balance and health. It is often used in conjunction with alternative and conventional medical treatments.
Eye movement desensitization and reprocessing (EMDR): A form of psychotherapy developed to resolve symptoms resulting from disturbing and unresolved life experiences. EMDR uses a structured approach to address past, present, and future aspects of disturbing memories.
Exposure therapy: A type of behavior therapy in which the patient confronts a feared situation, object, thought, or memory. Sometimes exposure therapy involves reliving a traumatic experience in a controlled, therapeutic environment. The goal is to reduce the distress, physical or emotional, felt in certain situations.
Feldenkrais: A movement therapy that uses a method of education in physical coordination and movement. The intent is to help the person become more aware of how the body moves through space and to improve physical functioning.
Frontalis muscle tension: Tension or pain in the muscle tissues that run vertically on the forehead.
Guided imagery: A mind-body approach involving a series of relaxation techniques followed by visualization of detailed images, usually calm and peaceful in nature. If used for treatment, the individual will visualize their body free of the specific problem or condition.
Health-related quality of life (HRQOL): Aspects of overall quality of life that can be clearly shown to affect health—either physical or mental.
Image habituation training (IHT): A form of exposure therapy that involves the patient in generating verbal descriptions of the traumatic event and recording these onto an audiotape.
Intent-to-treat analysis: A method of analyzing results of a randomized controlled trial that includes in the analysis all cases that should have received a treatment regimen but for some reason did not. All cases allocated to each arm of the trial are analyzed together as representing that treatment arm, regardless of whether they received or completed the prescribed regimen.
Magnet therapy: An approach that applies a magnetic field to the body for purported health benefits including pain control. Magnets in products such as magnetic patches and disks, shoe insoles, bracelets, and mattress pads are used for pain in the foot, wrist, back, and other parts of the body.
Manipulative and body-based practices: Practices that focus primarily on the structures and systems of the body, including the bones and joints, soft tissues, and circulatory and lymphatic systems. Two commonly used therapies in this category are spinal manipulation and massage therapy.
Mantram: A sound, syllable, word, or group of words used in meditation practice to focus attention and achieve a state of greater calmness, physical relaxation, and psychological balance.
Massage therapy: A practice where therapists manipulate muscle and connective tissue to enhance function of those tissues and promote relaxation and well-being.
Mind-body medicine: Practices that focus on the interactions among the brain, mind, body, and behavior, with the intent to use the mind to affect physical functioning and promote health.
Mindfulness-based stress reduction (MBSR): A type of meditation with origins in religious and spiritual traditions. Mindfulness meditation focuses attention on breathing to develop increased awareness of the present. The intent is to reduce stress and control emotions in order to improve health.
Movement-based therapy: The psychotherapeutic use of movement to promote emotional, cognitive, physical, and social integration of individuals.
Musculoskeletal manipulation: Manipulation of the bones and joints, soft tissues, and circulatory and lymphatic systems.
National Center for Complementary and Alternative Medicine (NCCAM): An agency of the NIH dedicated to exploring complementary and alternative healing practices in the context of rigorous science; training CAM researchers; and disseminating authoritative information to the public and professionals.
National Institutes of Health (NIH): An agency of the U.S. Department of Health and Human Services that is responsible for biomedical and health-related research.
Olfactory hypnotherapy: A technique that uses scents to arouse potent emotional reactions in the patient. During hypnosis, the patient learns to associate pleasant scents with a sense of security and self-control to overcome phobias and prevent panic attacks.
Pilates: A movement therapy that uses a method of physical exercise to strengthen and build control of muscles, especially those used for posture. Awareness of breathing and precise control of movements are integral components of this approach.
Posttraumatic stress disorder (PTSD): A severe anxiety disorder that can develop after exposure to any event that results in psychological trauma.
Progressive relaxation: A technique used to relieve tension and stress by systematically tensing and relaxing successive muscle groups.
Prolonged exposure: A form of behavior therapy and cognitive behavioral therapy for PTSD characterized by reexperiencing a traumatic event through remembering it and engaging with reminders of the trauma (triggers).
Qi gong: A practice with origins in Chinese philosophy involving gentle physical movement, mental focus, and deep breathing directed toward specific parts of the body.
Reflexotherapy: A treatment method that uses fingers, needles, and magnet applicators to influence biologically active spots on a human body that are situated where nerve terminals and vessels are concentrated.
Reiki: An energy medicine practice that originated in Japan. In Reiki, the practitioner places hands on or near the person receiving treatment, with the intent to transmit “ki,” believed to be life-force energy.
Relaxation therapy: A practice that focuses on using a combination of breathing and muscle relaxation to deal with stress.
Rolfing Structural Integration: A form of deep tissue massage used to realign the tissues that cover and connect all muscles and body organs (fascia). Bringing the body back into proper alignment is thought to reduce pain, improve flexibility and energy, and reduce muscle tension.
Sensory arts therapy: An expressive arts therapy that encourages the patient to express and understand emotions through artistic expression and the creative process.
Serotonin norepinephrine reuptake inhibitors (SNRI): A class of antidepressant drugs used in the treatment of major depression and other mood disorders. They are sometimes also used to treat anxiety disorders. SNRIs act upon and increase the levels of two neurotransmitters in the brain that are known to play an important part in mood, serotonin and norepinephrine.
Serotonin reuptake inhibitor (SSRI): A class of medications used to treat psychological conditions including depression and anxiety disorders. SSRIs help increase levels of serotonin in the brain, thus improving mood.
Spinal manipulation: A practice performed by chiropractors and other health care professionals such as physical therapists, osteopaths, and some conventional medical doctors. It involves the use of hands or a device to apply a controlled force to a joint of the spine, moving it beyond its passive range of motion; the amount of force applied depends on the form of manipulation used.
Stress inoculation therapy (SIT): A cognitive behavioral treatment for PTSD where the goal is to help a patient gain confidence in his or her ability to cope with anxiety and fear stemming from trauma-related reminders. In SIT, the client becomes more aware of reminders for anxiety and fear and learns coping skills that are useful in managing anxiety, such as muscle relaxation and deep breathing.
Tai chi: A mind-body practice, originated in China as a martial art, that involves moving the body in a slow, relaxed, and graceful series of movements. Many practitioners believe that tai chi helps the flow throughout the body of a vital energy called “qi.”
Trager Psychophysical Integration: A movement therapy in which practitioners apply a series of gentle, rhythmic rocking movements to the joints. The intent is to release physical tension and increase the body’s range of motion.
Trauma-focused therapy: A therapy designed to reduce negative emotional and behavioral responses following child sexual abuse and other traumatic events. The treatment addresses distorted beliefs and attributions related to the abuse and provides a supportive environment in which the patient is encouraged to talk about their traumatic experience.
Whole medical system: A complete system of theory and practice that has evolved over time in different cultures and apart from conventional medicine. Examples of whole medical systems include traditional Chinese medicine, Ayurvedic medicine, homeopathy, and naturopathy.
Yoga: A system of physical postures, breathing techniques, and meditation practiced to promote bodily or mental control and well-being.