# EXCLUDED STUDIES

All studies listed below were reviewed in their full-text version and excluded for the reason indicated. An alphabetical reference list follows the table.

Reference | Population not PTSD | Setting not outpatient, PC, MH, or community | Intervention not eligible CAM treatment | Control or comparator not eligible condition | Location not US/Europe/New Zealand/Australia | Language not English | Not peer reviewed/not primary data
Bob, 2004 (1220) | X
Branstrom, 2010 (43) | X
Bryant, 2005 (243) | X
Cardena, 2000 (732) | | | | | | | X
Carlson, 1998 (259) | | | X
Carter, 2006 (402) | | | | | | | X
Descilo, 2010 (357) | | | | | X
Dunn, 2009 (950) | X
Echeburúa 1997 (260) | | | X
Frueh, 2007 (1388) | | | X
Gordon, 2004 (313) | | | | X
Hiley-Young, 1990 (1874) | | | X
Kraft, 2010 (490) | X
Marks, 1998 (258) | | | X
Nakamura, 2010 (748) | X
Peeke, 2002 (483) | | | | | | | X
Salerno, 2005 (1312) | | X
Shore, 2004 (1793) | X
Short, 2007 (1315) | X
Spira, 2006 (758) | X
Stapleton, 2006 (401) | | | X
Stapleton, 2007 (1057) | | | X
Tacón, 2009 (1137) | | X
Tarrier, 1999 (257) | | | X
Taylor, 2003 (425) | | | X
Taylor, 2003 (1157) | | | X
Trzepacz, 2004 (1056) | | | X
Valentine, 2001 (1522) | | | | | | X
Waelde, 2008 (954) | X

## LIST OF EXCLUDED STUDIES

Bob P. Psychophysiology of hypnotic abreaction. Homeost Health Dis. 2004;43(2):109-111.
Branstrom R, Kvillemo P, Brandberg Y, et al. Self-report mindfulness as a mediator of psychological well-being in a stress reduction intervention for cancer patients--a randomized study. Ann Behav Med. 2010;39(2):151-61. [pmid: 20177843].
Bryant RA, Moulds ML, Guthrie RM, et al. The additive benefit of hypnosis and cognitive-behavioral therapy in treating acute stress disorder. J Consult Clin Psychol. 2005;73(2):334-40. [pmid: 15796641].
Cardena E. Hypnosis in the treatment of trauma: A promising, but not fully supported, efficacious intervention. Int J Clin Exp Hypn. 2000;48(2):225-238. [pmid: 10769985].
Carlson JG, Chemtob CM, Rusnak K, et al. Eye movement desensitization and reprocessing (EDMR) treatment for combat-related posttraumatic stress disorder. J Trauma Stress. 1998;11(1):3-24. [pmid: 9479673].
Carter JJ. Evaluation of a multi-component yoga intervention as adjunct to psychiatric treatment for Vietnam veterans with posttraumatic stress disorder (PTSD): A randomized controlled trial (RCT). controlled-trials.com. 2006.
Descilo T, Vedamurtachar A, Gerbarg PL, et al. Effects of a yoga breath intervention alone and in combination with an exposure therapy for post-traumatic stress disorder and depression in survivors of the 2004 SouthEast Asia tsunami. Acta Psychiatr Scand. 2010:289-300. [pmid: 19694633].
Dunn AS, Passmore SR, Burke J, et al. A cross-sectional analysis of clinical outcomes following chiropractic care in veterans with and without post-traumatic stress disorder. Mil Med. 2009;174(6):578-583. [pmid: 19585768].
Echeburua E, de Corral P, Zubizarreta I, et al. Psychological treatment of chronic posttraumatic stress disorder in victims of sexual aggression. Behav Modif. 1997;21(4):433-56. [pmid: 9337600].
Frueh BC, Monnier J, Yim E, et al. A randomized trial of telepsychiatry for post-traumatic stress disorder. J Telemed Telecare. 2007;13(3):142-147. [pmid: 17519056].
Gordon JS, Staples JK, Blyta A, et al. Treatment of posttraumatic stress disorder in postwar Kosovo high school students using mind-body skills groups: a pilot study. J Trauma Stress. 2004;17(2):143-7. [pmid: 15141787].
Hiley-Young B. Facilitating Cognitive-Emotional Congruence in Anxiety Disorders During Self-Determined Cognitive Change: An Integrative Model. J Cogn Psychother. 1990;4(2):225-236.
Kraft K, Telles S. Yoga practice may be useful after post-traumatic stress. Focus on Alternative and Complementary Therapies. 2010;15(3):255-256.
Marks I, Lovell K, Noshirvani H, et al. Treatment of posttraumatic stress disorder by exposure and/or cognitive restructuring: a controlled study. Arch Gen Psychiatry. 1998;55(4):317-25. [pmid: 9554427].
Nakamura Y, Lipschitz DL, Landward R, et al. Two sessions of sleep-focused mind-body bridging improve self-reported symptoms of sleep and PTSD in veterans: A pilot randomized controlled trial. J Psychosom Res. 2010.
Peeke PM, Frishett S. The role of complementary and alternative therapies in women’s mental health. Primary Care - Clinics in Office Practice. 2002;29(1):183-197. [pmid: 11856666].
Salerno N. The Use of Hypnosis in the Treatment of Post-traumatic Stress Disorder in a Female Correctional Setting. Australian Journal of Clinical & Experimental Hypnosis. 2005;33(1):74-81.
Shore A. Long-term effects of energetic healing on symptoms of psychological depression and self-perceived stress. Altern Ther Health Med. 2004;10(3):42-8. [pmid: 15154152].
Short A. Theme and variations on quietness: Relaxation-focused music and imagery in aged care. Australian Journal of Music Therapy. 2007;18:39-61.
Spira JL, Pyne JM, Wiederhold B, et al. Virtual reality and other experiential therapies for combat-related posttraumatic stress disorder. Primary Psychiatry. 2006;13(3):58-64.
Stapleton JA, Taylor S, Asmundson GJ. Effects of three PTSD treatments on anger and guilt: exposure therapy, eye movement desensitization and reprocessing, and relaxation training. J Trauma Stress. 2006;(1):19-28. [pmid: 16568469].
Stapleton JA, Taylor S, Asmundson GJG. Efficacy of various treatments for PTSD in battered women: Case studies. J Cogn Psychother. 2007;21(1):91-102.
Tacón AM, McComb J. Mindful exercise, quality of life, and survival: A mindfulness-based exercise program for women with breast cancer. The Journal of Alternative and Complementary Medicine. 2009;15(1):41-46. [pmid: 19769475].
Tarrier N, Pilgrim H, Sommerfield C, et al. A randomized trial of cognitive therapy and imaginal exposure in the treatment of chronic posttraumatic stress disorder. J Consult Clin Psychol. 1999;67(1):13-8. [pmid: 10028204].
Taylor S, Thordarson DS, Maxfield L, et al. Comparative efficacy, speed, and adverse effects of three ptsd treatments: exposure therapy, emdr, and relaxation training. J Consult Clin Psychol. 2003;(2):330-8. [pmid: 12699027].
Taylor S. Outcome Predictors for Three PTSD Treatments: Exposure Therapy, EMDR, and Relaxation Training. J Cogn Psychother. 2003;17(2):149-161.
Trzepacz AM, Luiselli JK. Efficacy of Stress Inoculation Training in a Case of Posttraumatic Stress Disorder (PTSD) Secondary to Emergency Gynecological Surgery. Clinical Case Studies. 2004;3(1):83-92.
Valentine PV, Smith TE. Evaluating traumatic incident reduction therapy with female inmates: a randomized controlled clinical trial. Research on Social Work Practice. 2001;11(1):40-52.
Waelde LC, Uddo M, Marquett R, et al. A pilot study of meditation for mental health workers following Hurricane Katrina. J Trauma Stress. 2008;21(5):497-500. [pmid: 18956453].