# PEER REVIEW COMMENTS/AUTHOR RESPONSES

Reviewer | Comment | Response
Question 1: Are the objectives, scope, and methods for this review clearly described?
1 | Yes | Acknowledged
2 | Yes | Acknowledged
3 | Yes - This is an excellent review and evidence synthesis. | Thank you.
4 | Yes | Acknowledged
5 | Yes – This was a clearly and well-defined project. The authors are to be congratulated on the organization of the report which made for easy reading. | Thank you.
5 | This reviewer would appreciate a formal definition of CAM (if there is such) early in the introductory material. | This definition is provided on the first page of the Executive Summary and in the background section of the Introduction of the report.
5 | Also, I realize that natural products such as nutritional supplements were excluded from review, but there was no convincing rationale for this decision. Given the paucity of information from other CAM approaches, it might be worth reconsidering this decision. | The decision to exclude nutritional supplements was made by the stakeholders, not the research team.
6 | Yes | Acknowledged
Question 2: Is there any indication of bias in our synthesis of the evidence?
1 | No | Acknowledged
2 | Yes – The exclusion criteria listed on p 12–13 show a clear bias toward western medicine centric locations. Given the paucity of studies, inclusion of a wider selection of studies particularly from countries where CAM is more common would be warranted. This would also involve non-English language publications. | The reviewer raises a valid point. Our conceptual framework was to review settings and subjects similar to the VA and Veterans—thus the focus on studies conducted in the U.S. and economically similar countries. Our staff is not resourced to include non-English publications. We note this limitation in the discussion.
3 | No | Acknowledged
4 | No | Acknowledged
5 | No | Acknowledged
6 | Yes - There is no evidence of intentional bias. The authors have done a very fair job of reporting the evidence. However, I believe the selection criteria may have limited what can be learned from the existing evidence, and therefore, have created an unintentional bias in the conclusions. | See response to Question 7, Reviewer 6
Question 3: Are there any studies of interest to the VA that we have overlooked?
1 | Yes Rosenthal, et al. (2011). Military Medicine, 176:626–630 | Thank you for making us aware of this article. Although it was published after our literature search date (Dec 22, 2010) and thus excluded from our formal literature synthesis, we now include a description of this study in our Results section, Key Question 4.
2 | Yes - see comments above on excluded studies. since PTSD is commonly comorbid with substance abuse, exclusion of studies requiring both diagnoses limits applicability of findings | Acknowledged
2 | The listing of the references for the excluded studies is a plus, as the reader can draw their own conclusions. Shore 2004 is missing from that list. | Shore 2004 is included in the excluded studies table in Appendix F.
2 | Management of Operation Iraqi Freedom and Operation Enduring Freedom veterans in a Veterans Health Administration chiropractic clinic: a case series. Lisi AJ. Journal of Rehabilitation Research & Development. 47(1):1–6, 2010 | Thank you for bringing this article to our attention. However, it does not meet our inclusion criteria since PTSD diagnosis was not a study inclusion criteria, nor was change in PTSD a reported outcome.
3 | No – none that I am aware of, but this is not my field | Acknowledged
4 | No - none that I am aware of | Acknowledged
5 | No | Acknowledged
6 | Yes - There is an RCT of mindfulness meditation by Barbara Niles that is relevant. I believe that the authors attempted to get a copy of the paper but could not for some reason. However, the trial was well-done and positive, so it would be helpful to try to include it if at all possible. | We have obtained a prepublication draft of this manuscript but do not include it in the current report since our literature review strategy stipulates that included studies be published in peer-reviewed journals.
Question 4: Are there any clinical performance measures, programs, quality improvement measures, patient care services, or conferences that will be directly affected by this report? If so, please provide detail.
1 | The findings of this report will be used while designing demonstration projects in the field, in an attempt to address some of the methodological limitations identified in the report. | Acknowledged
2 | None
3 | No, the evidence base is too limited | Acknowledged
4 | The finding of limitations of current scientific evidence to review and the recommendation for investment in adequately powered trials may affect and push such research trials. This could result in positive results for patient care services. | Acknowledged
5 | In order to facilitate health services research in this area I the VA, it would be great to have some procedure codes that could be universally adopted that would capture various CAM approaches. | Thank you for this suggestion. We have added it to our Future Research section.
6 | None that I can think of | Acknowledged
Question 5: Please provide any recommendations on how this report can be revised to more directly address or assist implementation needs.
1 | We would like to immediately be able to provide the draft version of this report to our evaluation team from the University of Rochester, who will be designing the evaluation structure of our demonstration projects. Please advise if this is possible, or if not, when the report can be available to them. This work will begin very soon, so this is time sensitive. | Acknowledged
2 | None
3 | This is an excellent report and I have only a few suggestions for how to revise it to improve it. | Thank you.
3 | 1. Page 15. The description of the data synthesis is somewhat difficult to understand, especially the last couple of lines. It may not be to experts in this field however. It would be nice if this could be a little clearer. | We revised the data synthesis section to more clearly describe the standardized mean difference.
3 | 2. I think it would be very helpful to include the quality ratings on Table 4 as well as a brief sentence or 2 interpreting the important findings in the study rather than relying on the reader either understanding the measurements or referring back to them to understand what the findings mean. | We added the quality ratings for each study in Table 4. Outcomes are summarized in text. There was not adequate space to summarize the results narratively in the table.
3 | 3. On page 26, clarify that the study by Echeburua is a study of CBT/coping not of relaxation (if I understand it correctly) | Echeburúa and colleagues conducted a comparative effectiveness study of relaxation training (progressive muscle relaxation; PMR) to an intervention that included cognitive behavioral therapy, coping, and PMR. We have updated the description of the study and Table 4 to better describe the two treatment arms.
3 | 4. Page 41 last paragraphwhy so much discussion about Vujanovic and their thoughts. is there data on mindfulness to support this contention? Does it deserve this much space in this report if no data and only opinion? | We agree. In the final report, we have markedly streamlined this portion of the discussion.
4 | None
5 | None
6 | Given the widespread use of CAM across the VA, clinicians, researchers, and administrators may find the report to be useful in helping them understand the evidence base on CAM for PTSD. | Thank you.
Question 6: Please provide us with contact details of any additional individuals/stakeholders who should be made aware of this report.
1 | Dr. Madhu Agarwal, info in VA Outlook | Thank you. We will be sure Dr. Agarwal is made aware of the report.
2 | None
3 | None
4 | None
5 | None
6 | None
Question 7: Please write additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
1 | p.10, I believe that the number who have deployed in the current conflicts is closer to 2.2 million | Thank you for this comment. The report introduction now reflects an estimated 2.2 million deployed.
1 | Overall, I am not sure why nonscientific “energy therapies” are included with movement based therapies, but since you didn’t find any efficacy, I guess it doesn’t matter. | We included energy therapies and movement therapies within the same category, consistent with NCCAM’s classification system for these modalities.
2 | None
3 | I would like to identify some features of this report that are very helpful in understanding this literature synthesis and might be applicable to other ESP reports. These include:; 1. Table 1 is excellent and a nice model for our reports. It is very clear.; 2. Table 5 is really nice. Very helpful.; 3. Table 9 is great! again, an interpretation of the findings might be helpful to the less knowledgeable reader | Thank you!
4 | None
5 | It would be terrific if there could be a parallel review of CAM therapies related to major depression and some of the non-PTSD anxiety disorders. These conditions tend to be comorbid with PTSD as well as share some symptomatology. More importantly, there are many treatments that are identical for these conditions and PTSD (e.g., SSRI’s, sleep medications), so it would make sense that some CAM approaches that are successful for these conditions might also be successful for PTSD. Thus, it would be extremely useful to have such a review. In addition to the efficacy results, such a review could also point to methodological considerations as well as touch on patient acceptability. | We thank the reviewer for this suggestion. This supplementary report has already been commissioned, is underway, and should be available in the fall of 2011.
5 | It would be helpful to include a brief description of the AHRQ study quality methods in the text. | A brief description of the AHRQ quality methods is presented in the Methods section under Quality Assessment.
5 | I would remove the statement on page 4 (and elsewhere in the text) that lower standards of evidence may be applicable when CAM treatments are offered as adjuncts to conventional, evidence-based PTSD therapies. Even in the context of an add-on therapy, it is important to conduct high quality studies. | We appreciate this reviewer’s comment. The Future Research section has been revised substantially and this statement has been omitted from the discussion.
5 | Page 6: It is problematic to omit mention of veterans of previous wars (e.g., Persian Gulf, Vietnam, etc.). Vietnam veterans are by far the most numerous in the VA system, so they and other previous war era veterans should be included in this introductory paragraph. | Thank you for this suggestion. We have expanded the introductory text to acknowledge Veterans of all service eras.
5 | At some point in the paper (perhaps when discussing future research?), it may be a good idea to discuss some of the complexities of PTSD research. These include a variety of traumas (e.g., natural disasters, combat, rape, etc) which may respond differentially to treatments, time since trauma (which may impact on symptom severity), and comorbidity (both psychiatric and medical). | We thank the reviewer for this observation. A full discussion of the complexities of PTSD research was beyond the scope of this report, but we have highlighted some key challenges and referred the reader to more in-depth discussions.
5 | Thank you for the opportunity to review this report. I hope these comments will be useful to increase the report’s utility. | Thank you!
6 | The study team did a very careful job in preparing this document. The writing is clear and thorough. However, I feel that the document could be more useful if the authors made several revisions. | Thank you.
6 | The approach, which is very strict about inclusion and exclusion, would be a better fit with a literature that was more evolved, in which there were more studies and more definitive studies. With such a small and underdeveloped literature, it would have been informative to include a broader range of studies. Doing so could have influenced the conclusions about what appears to be promising—even if those conclusions were not definitive. | The research team understands this observation by the reviewer. However, our conceptual framework was to review settings and subjects similar to the VA and Veterans for ease of implementation if there was strong evidence for a therapy.
6 | The most important example of this concerns the exclusion of studies that used relaxation as a comparison treatment but did not provide an adequate description of the relaxation protocol. At least a couple of these studies (Carlson and Marks) found that relaxation was less effective than treatments recommended in the VA/DoD PTSD practice guideline. The Marks study, which was published in the Archives of General Psychiatry, would be considered to be at least good or better quality. Although the statement about relaxation on p.29 is not very favorable, by not reviewing studies such as Carlson and Marks, it might appear that relaxation is an intervention in need of evaluation. However, its performance in the 3 studies reviewed and these 2 additional studies suggests that it may not have promise. Of course, this conclusion needs to be tempered by the absence of detail about what study participants actually received. However, the information could be presented to readers, with this caveat mentioned. | We have added text to the Limitation section to acknowledge this important point.
6 | I do not know how the criteria that caused other studies to be excluded might have affected the results. The point is a more inclusive review that extracted more information from the existing literature could provide useful guidance about future directions. | Acknowledged
6 | I also recommend that the authors revise content in the section on Future Directions (p. 4), and carry these revisions into the more extensive summary on pp. 41–45. Using the p. 4 content as a reference:
6 | - The first paragraph discusses usual care and no care interventions as if they are the same, when they are not. The inferences drawn from a usual care design are different and stronger than the inferences drawn from a no care design. | The text has been revised to refer to no care (waitlist) controls.
6 | - The second paragraph suggests that “evidence of benefit from less rigorous trial designs may be sufficient” for CAM treatments for PTSD that are los costs, responsive to patient preferences, and have few adverse effects. There is nothing in the review to support this suggestion. Low cost, low risk intervention that patients like may not be a good use of resources at a system level and could interfere with the delivery of effective care. Except for the patient-centeredness of this suggestion, I do not think it fits with VA’s model of quality care. Furthermore, why would a lower standard of evidence be a good idea in any case? | The Future Research section has been revised substantially, and the endorsement of lower quality evidence and discussion of costs have been removed.
6 | - The third paragraph concludes that medication, acupuncture, relaxation, and mind-body interventions are feasible and acceptable to patients and “may hold promise as adjunctive of monotherapies for PTSD.” Based on the literature review, it is not possible to draw such a broad, if suggestive, conclusion about the benefits of monotherapy and adjunctive therapy for all of these treatments. None of them were tested in both formats. Furthermore, the tone of the conclusion does not fit with the summary of the evidence on p. 29 or the table on pp. 39–40. Findings based on small, primarily poor or fair quality studies (for which the strength of evidence for all treatment/comparator combinations is rated as low or insufficient except for acupuncture), are not an adequate basis for concluding that the interventions tested may be promising. There is only one good-quality study, of acupuncture as monotherapy (although study participants were allowed to use medication and receive supportive therapy). | We agree that the conclusions were overly broad. The conclusions have been modified and reflect the concerns raised by this reviewer.
6 | The recommendations for future research should include recommendations about completeness of reporting and fidelity monitoring, both of which are problems in the literature reviewed. Testing CAM interventions as monotherapy versus adjunctive therapies also would be helpful. There could be an argument that CAM as monotherapy should use EBT as a comparator given the strength of data now available for the EBTs. | Recommendations about fidelity monitoring and completeness of outcomes reporting have been specifically addressed in the revised Future Research section.
6 | The content on mindfulness on pp. 41–42 seems out of place in a section on limitations. This content is not about the limitations of the report. | We concur and now omit this content from the limitations section.
6 | I recommend that the authors standardize the level of detail provided about different studies. For example, in the section on relaxation (pp. 26–29), F and p-values are reported for the Watson study, p-values are reported for the Vaughn study, and Ms and SDs are reported for the Echeburúa study. | Thank you for this observation. We have attempted to standardize this section.
6 | I also recommend that the authors try to reduce jargon when possible. Sentences like the 3rd bullet on 0. 29 are difficult to understand. | Thank you for this observation. We have attempted this where possible.