# STUDY SELECTION FORM

[underlined: Citation Screening Instructions:] Turn on revision marks and label each citation with your decision. For studies that you can definitively exclude (≥ 90%), mark with “E.” For studies that are relevant to CAM for PTSD but not eligible (e.g., a review article), mark with a “B” for background. For an article that appears to meet eligibility criteria, mark with “IN” for include. We will need to be able to identify comparative studies that appear to meet our eligibility criteria but are excluded because they are not RCTs. Mark these studies with “F” for flag, and in the absence of RCTs for a therapy, we will give these studies further scrutiny.

[underlined: Inclusion criteria:]

- Study must be an RCT
- Sample population must have diagnosis of PTSD using DSM criteria, validated severity measures (e.g., PTSD Checklist), or clinical diagnosis by a physician
- Sample population is ≥ 19 years of age
- Setting: Patients are recruited from community or outpatient mental health or general medical settings
- Any of the following eligible treatments:
  ○ Mind-body therapies: Acupuncture, meditation, yoga, deep-breathing exercises, guided imagery, mindfulness-based stress reduction, hypnotherapy, progressive relaxation, qi gong, and tai chi
  ○ Manipulative and body-based therapies: spinal manipulation, massage therapy
  ○ Other CAM therapies:
    ▪ Movement-based therapies: Feldenkrais method, Alexander technique, Pilates, Rolfing Structural Integration, and Trager psychophysical integration
  ○ Manipulation of various energy fields to affect health: magnet therapy, light therapy, qi gong, Reiki, and healing touch
- Comparative studies:
  ○ Studies that compare an eligible treatment to a control condition—such as usual care (including no treatment, supportive therapy), an attention control, sham intervention, or a waitlist—will be included
  ○ Studies that compare an eligible treatment to an empirically based treatment such as CBT, PE, or antidepressant medication
- Outcome is reported at ≥ 6 weeks after treatment initiation
- Patients are in acute phase treatment (i.e., not selected for treatment-resistant PTSD)
- Study must be published in a peer-reviewed publication

[underlined: Exclusion criteria:]

- Study is a non–English language publication
- Study is conducted outside of North America, Western Europe, Australia, or New Zealand. Studies conducted outside of these countries are unlikely to be applicable to a VA population because of important differences in culture and the health care system.
- Study populations are patients with complicated PTSD: psychosis or acute suicidality
- Studies in which the eligibility criteria require a diagnosis of PTSD comorbid with another mental illness (e.g., PTSD and substance abuse)
- Intervention is used in a continuation phase or maintenance phase
- Excluded interventions:
  ○ cognitive processing therapy
  ○ eye movement desensitization and reprocessing (EMDR)
  ○ generic counseling
  ○ life review therapy
  ○ psychoeducational therapy
  ○ social support or supportive therapy
  ○ standard psychodynamic therapy
  ○ “third wave” cognitive and behavioral therapies: mindfulness-based cognitive therapy, dialectical behavioral therapy, and acceptance and commitment therapy
  ○ other treatments that are a direct extension of an established conventional therapy (e.g., Imagery Rehearsal Therapy)
  ○ incident stress debriefing, psychological debriefing
  ○ trauma-focused therapy
  ○ present-focused therapy
  ○ seeking-safety treatment
  ○ relaxation therapy used as a control arm or not described in sufficient detail to understand the key components