# SEARCH STRATEGIES

Step | Goal | Terms | Result^a^
1 | PTSD terms | Stress Disorders, Traumatic[MeSH] OR stress disorders, post-traumatic[MeSH] OR (post AND traumatic AND stress AND disorder[All Fields]) OR (post-traumatic AND stress AND disorder [All Fields]) OR (post traumatic stress disorder[All Fields]) or (post-traumatic stress disorders[All Fields]) OR ptsd[All Fields] AND | 1069
2 | Interventions | Acupuncture Therapy[Mesh:noexpl] OR Acupuncture Analgesia[Mesh] OR Acupuncture, Ear[Mesh] OR Electroacupuncture[Mesh] OR Acupuncture[Mesh] OR Acupressure[Mesh] OR Auriculotherapy[Mesh] OR acupuncture[All Fields] OR (acupuncture[All Fields] AND therapy[All Fields]) OR (acupuncture therapy[All Fields]) OR acupressure[All Fields] OR auriculotherapy[All Fields] OR Mind-Body Therapies[Mesh:noexpl] OR Breathing Exercises[Mesh] OR Hypnosis[Mesh] OR Imagery (Psychotherapy)[Mesh] OR Meditation[Mesh] OR Mental Healing[Mesh] OR Relaxation Therapy[Mesh] OR Tai Ji[Mesh] OR Therapeutic Touch[Mesh] OR Yoga[Mesh] OR Mind-Body Relations, Metaphysical[Mesh] OR breath[All Fields] OR breath[All Fields:expl] OR Complementary Therapies[Mesh:noexpl] OR Holistic Health[Mesh] OR Medicine, East Asian Traditional[Mesh] OR Reflexotherapy[Mesh] OR Spiritual Therapies[Mesh] OR acoustics[MeSH] OR acoustics[All Fields] OR acoustic[All Fields] OR aromatherapy [MeSH] OR sensory[All Fields] OR aromatherapy[All Fields] OR art[MeSH] OR art[All Fields] OR colour[All Fields] OR color[MeSH] OR color[All Fields] OR dance[All Fields] OR music[MeSH] OR music[All Fields] OR play and playthings[MeSH] OR (play AND playthings[All Fields]) OR play and playthings[All Fields] OR play[All Fields] OR sensory art therapies[MeSH] OR reflexotherapy[All Fields] OR craniosacral[All Fields] OR magnet[All Fields] OR light[MeSH ] OR light[All Fields] OR feldenkrais[Tiab] OR Alexander[Tiab] OR pilates[All Fields] OR trager[All Fields] OR movement therapeutic[All Fields] OR movement therapies[All Fields] OR movement therapy[All Fields] OR healers[All Fields] OR energy[All Fields] OR therapeutic touch[MeSH] OR (therapeutic[All Fields] AND touch[All Fields]) OR therapeutic touch[All Fields] OR reiki[All Fields]) OR ayurvedic[All Fields] AND | 83692
3 | Study designs | Randomized controlled trial[publication type] OR clinical trial[publication type] OR Comparative study[Publication type] OR clinical trials as topic[MeSH] OR (randomized AND controlled AND trial[Tiab]) OR (clinical AND trial[Tiab] OR trial[Tiab:expl] AND | 13973
4 | Combine results and apply limits | #1 AND #2 AND #3 LIMITS: English and Human and Adult | 353

a Numbers reflect the result of the PubMed search only.