# SUMMARY AND LIMITATIONS

Most research is available for general overviews on health benefits or psychological wellbeing, and in the more specific areas chronic illness, depression, substance use, somatization disorders, distress, and mental illness. Reviews suggest differential effects of MBSR, MBCT, and other mindfulness-based interventions, and definitions of “mindfulness-based” varied. The most consistent effect was reported for depression, but published meta-analyses also indicated positive effects of MBSR on overall health, chronic illness, and psychological variables, positive effects of MBCT in mental illness, and positive effects of mindfulness interventions for somatization disorders, compared to passive control groups. Limited evidence, judging from existing systematic reviews reporting pooled treatment effects, is also available for mindfulness interventions for pain, anxiety, and psychosis, compared to passive control groups.

The evidence map is not designed to provide detailed and definitive information on the effectiveness of interventions and mindfulness interventions represent a large spectrum of interventions. Furthermore, the implementation of the reviewed interventions in practice will require additional steps (eg, identifying the optimal intervention format, validation of facilitators). Evidence maps are a very broad overview of the evidence base, indicating areas in which research has been conducted, to help stakeholders interpret the state of the evidence to inform policy and clinical decision making.