# REFERENCES

1 Bishop SR, Lau M, Shapiro S, et al. Mindfulness: A proposed operational definition. Clinical Psychology: Science and Practice. 2004;11(3):230-241.
2 Cuellar NG. Mindfulness meditation for veterans---implications for occupational health providers. AAOHN journal : official journal of the American Association of Occupational Health Nurses. Aug. 2008;56(8):357-363. [pmid: 18717302].
3 Goyal M, Singh S, Sibinga EM, et al. Meditation Programs for Psychological Stress and Well-Being. Comparative Effectiveness Review No. 124. (Prepared by Johns Hopkins University Evidence-based Practice Center under Contract No. 290-2007-10061–I.) AHRQ Publication No. 13(14)-EHC116-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2014.
4 Chiesa A, Malinowski P. Mindfulness-based approaches: are they all the same?. Journal of clinical psychology. Apr. 2011;67(4):404-424. [pmid: 21254062].
5 Marchand WR. Mindfulness-based stress reduction, mindfulness-based cognitive therapy, and Zen meditation for depression, anxiety, pain, and psychological distress. Journal of Psychiatric Practice®. 2012;18(4):233-252. [pmid: 22805898].
6 Boteva K. Mindfulness meditation in patients with mood disorders Feasibility, safety and efficacy: An empirical review. International Journal of Child Health and Human Development. 2008. 2008;1(2):135-154.
7 Coelho HF, Canter PH, Ernst E. Mindfulness-based cognitive therapy: evaluating current evidence and informing future research. Journal of consulting and clinical psychology. Dec. 2007;75(6):1000-1005. [pmid: 18085916].
8 de Vibe M, Bjørndal A, Tipton E, Hammerstrøm K, Kowalski K. Mindfulness based stress reduction (MBSR) for improving health, quality of life, and social functioning in adults. Campbell Systematic Reviews. 2012;3.
9 Eberth J, Sedlmeier P. The effects of mindfulness meditation: A meta-analysis. Mindfulness. Sep. 2012. 2012;3(3):174-189.
10 Escuriex BF, Labbé EE. Health care providers' mindfulness and treatment outcomes: A critical review of the research literature. Mindfulness. Dec. 2011. 2011;2(4):242-253.
11 Kim SH, Schneider SM, Kravitz L, Mermier C, Burge MR. Mind-body practices for posttraumatic stress disorder. Journal of investigative medicine : the official publication of the American Federation for Clinical Research. Jun. 2013;61(5):827-834. [pmid: 23609463].
12 Malpass A, Carel H, Ridd M, et al. Transforming the perceptual situation: A meta-ethnography of qualitative work reporting patients' experiences of mindfulness-based approaches. Mindfulness. Mar. 2012. 2012;3(1):60-75.
13 McCarney R, Schulz J, Grey A. Effectiveness of mindfulness-based therapies in reducing symptoms of depression: A meta-analysis. European Journal of Psychotherapy and Counselling S2- European Journal of Psychotherapy, Counselling and Health. Sep. 2012. 2012;14(3):279-299.
14 Morone NE, Greco CM. Mind-body interventions for chronic pain in older adults: a structured review. Pain medicine (Malden, Mass.). May-Jun. 2007;8(4):359-375.
15 Ospina MB, Bond K, Karkhaneh M, et al. Clinical trials of meditation practices in health care: characteristics and quality. Journal of alternative and complementary medicine (New York, N.Y.). Dec. 2008;14(10):1199-1213.
16 Regehr C, Glancy D, Pitts A. Interventions to reduce stress in university students: a review and meta-analysis. Journal of affective disorders. May. 15. 2013;148(1):1-11. [pmid: 23246209].
17 Shapiro SL, S DE, S GE, Grossman P, N L, S S, W H. Stress management in medical education: a review of the literature Mindfulness-based stress reduction and health benefits: a meta-analysis. Academic Medicine. 2000;75(7).
18 Shiralkar MT, Harris TB, Eddins-Folensbee FF, Coverdale JH. A systematic review of stress-management programs for medical students. Academic psychiatry : the journal of the American Association of Directors of Psychiatric Residency Training and the Association for Academic Psychiatry. May. 1. 2013;37(3):158-164.
19 Shonin E, Van Gordon W, Slade K, Griffiths MD. Mindfulness and other Buddhist-derived interventions in correctional settings: A systematic review. Aggression and Violent Behavior. May-Jun. 2013. 2013;18(3):365-372.
20 Teleki JW. Mindfulness-based stress reduction: A meta-analysis of psychological outcomes. Dissertation Abstracts International: Section B: The Sciences and Engineering S2- Dissertation Abstracts International. 2010. 2010;71(3-B):2063.
21 Virgili M. Mindfulness-based interventions reduce psychological distress in working adults: a meta-analysis of intervention studies. Mindfulness. 2013.
22 Winbush NY, Gross CR, Kreitzer MJ. The effects of mindfulness-based stress reduction on sleep disturbance: a systematic review. Explore (New York, N.Y.). Nov-Dec. 2007;3(6):585-591.
23 Baer RA. Mindfulness training as a clinical intervention: a conceptual and empirical review. Clinical Psychology: Science and Practice. 2003;10(2).
24 Bernardy K, F N, K V, H W. Efficacy of cognitive-behavioral therapies in fibromyalgia syndrome: a systematic review and metaanalysis of randomized controlled trials. Journal of Rheumatology. 2010;37(10).
25 Bohlmeijer E, Prenger R, Taal E, Cuijpers P. The effects of mindfulness-based stress reduction therapy on mental health of adults with a chronic medical disease: a meta-analysis. Journal of psychosomatic research. Jun. 2010;68(6):539-544. [pmid: 20488270].
26 Carim-Todd L, Mitchell SH, Oken BS. Mind-body practices: an alternative, drug-free treatment for smoking cessation? A systematic review of the literature. Drug and alcohol dependence. Oct. 1. 2013;132(3):399-410. [pmid: 23664122].
27 Carmody J, Baer RA. How long does a mindfulness-based stress reduction program need to be? A review of class contact hours and effect sizes for psychological distress. Journal of clinical psychology. Jun. 2009;65(6):627-638. [pmid: 19309694].
28 Casellas-Grau A, Font A, Vives J. Positive psychology interventions in breast cancer. A systematic review. Jan. 2014;23(1):9-19.
29 Chiesa A, Calati R, Serretti A. Does mindfulness training improve cognitive abilities? A systematic review of neuropsychological findings. Clinical psychology review. Apr. 2011;31(3):449-464. [pmid: 21183265].
30 Chiesa A, Serretti A. Mindfulness-based stress reduction for stress management in healthy people: a review and meta-analysis. Journal of alternative and complementary medicine (New York, N.Y.). May. 2009;15(5):593-600.
31 Chiesa A, Serretti A. A systematic review of neurobiological and clinical features of mindfulness meditations. Psychological medicine. Aug. 2010;40(8):1239-1252. [pmid: 19941676].
32 Chiesa A, Serretti A. Mindfulness-based interventions for chronic pain: a systematic review of the evidence. Journal of alternative and complementary medicine (New York, N.Y.). Jan. 2011;17(1):83-93.
33 Chiesa A, Serretti A. Mindfulness based cognitive therapy for psychiatric disorders: a systematic review and meta-analysis. Psychiatry research. May. 30. 2011;187(3):441-453. [pmid: 20846726].
34 Chiesa A, Serretti A. Are Mindfulness-Based Interventions Effective for Substance Use Disorders? A Systematic Review of the Evidence. Substance use & misuse. Mar. 5. 2013.
35 Cramer H, Haller H, Lauche R, Dobos G. Mindfulness-based stress reduction for low back pain. A systematic review. BMC complementary and alternative medicine. 2012;12:162. [pmid: 23009599].
36 Cramer H, Lauche R, Paul A, Dobos G. Mindfulness-based stress reduction for breast cancer-a systematic review and meta-analysis. Current oncology (Toronto, Ont.). Oct. 2012;19(5):e343-352.
37 Crawford C, Wallerstedt DB, Khorsan R, Clausen SS, Jonas WB, Walter JA. A Systematic Review of Biopsychosocial Training Programs for the Self-Management of Emotional Stress: Potential Applications for the Military. Evidence-based complementary and alternative medicine : eCAM. 2013. 2013:747694. [pmid: 24174982].
38 Davis L, Kurzban S. Mindfulness-Based Treatment for People With Severe Mental Illness: A Literature Review. American Journal of Psychiatric Rehabilitation. 2012;15(2):202-232.
39 Feng Cy, C H, C CH, C YS, C TH, C YH, C YC, C KR. The effect of cognitive behavioral group therapy for depression: a meta-analysis 2000-2010. Worldviews on Evidence-Based Nursing. 2012;9(1).
40 Fjorback LO, Arendt M, Ornbol E, Fink P, Walach H. Mindfulness-based stress reduction and mindfulness-based cognitive therapy: a systematic review of randomized controlled trials. Acta psychiatrica Scandinavica. Aug. 2011;124(2):102-119. [pmid: 21534932].
41 Galante J, Iribarren SJ, Pearce PF. Effects of mindfulness-based cognitive therapy on mental disorders: a systematic review and meta-analysis of randomised controlled trials. Journal of Research in Nursing. 2013;18(2):133-155.
42 Glombiewski Ja, S AT, G J, K K, R W, H SG. Psychological treatments for fibromyalgia: a meta-analysis. Pain. 2010;151(2).
43 Goyal M, Singh S, Sibinga EM, et al. Meditation Programs for Psychological Stress and Well-being: A Systematic Review and Meta-analysis. JAMA internal medicine. Jan. 6. 2014.
44 Grossman P, Niemann L, Schmidt S, Walach H. Mindfulness-based stress reduction and health benefits. A meta-analysis. Journal of psychosomatic research. Jul. 2004;57(1):35-43. [pmid: 15256293].
45 Hofmann SG, Sawyer AT, Witt AA, Oh D. The effect of mindfulness-based therapy on anxiety and depression: A meta-analytic review. Journal of consulting and clinical psychology. Apr. 2010;78(2):169-183. [pmid: 20350028].
46 Katz D, Toner B. A systematic review of gender differences in the effectiveness of mindfulness-based treatments for substance use disorders. Mindfulness. Dec. 2013. 2013;4(4):318-331.
47 Khoury B, Lecomte T, Fortin G, et al. Mindfulness-based therapy: a comprehensive meta-analysis. Clinical psychology review. Aug. 2013;33(6):763-771. [pmid: 23796855].
48 Khoury B, Lecomte T, Gaudiano BA, Paquin K. Mindfulness interventions for psychosis: a meta-analysis. Schizophrenia research. Oct. 2013;150(1):176-184. [pmid: 23954146].
49 Klainin-Yobas P, Cho MA, Creedy D. Efficacy of mindfulness-based interventions on depressive symptoms among people with mental disorders: a meta-analysis. International journal of nursing studies. Jan. 2012;49(1):109-121. [pmid: 21963234].
50 Krisanaprakornkit T, Krisanaprakornkit W, Piyavhatkul N, Laopaiboon M. Meditation therapy for anxiety disorders. The Cochrane database of systematic reviews. 2006;(1). CD004998.
51 Lakhan SE, Schofield KL. Mindfulness-based therapies in the treatment of somatization disorders: a systematic review and meta-analysis. PloS one. 2013;8(8):e71834. [pmid: 23990997].
52 Lauche R, Cramer H, Dobos G, Langhorst J, Schmidt S. A systematic review and meta-analysis of mindfulness-based stress reduction for the fibromyalgia syndrome. Journal of psychosomatic research. Dec. 2013;75(6):500-510. [pmid: 24290038].
53 Lawrence M, Booth J, Mercer S, Crawford E. A systematic review of the benefits of mindfulness-based interventions following transient ischemic attack and stroke. International journal of stroke : official journal of the International Stroke Society. Aug. 2013;8(6):465-474. [pmid: 23879751].
54 Lazaridou A, Philbrook P, Tzika AA. Yoga and mindfulness as therapeutic interventions for stroke rehabilitation: a systematic review. Evidence-based complementary and alternative medicine : eCAM. 2013;2013:357108. [pmid: 23781259].
55 Ledesma D, Kumano H. Mindfulness-based stress reduction and cancer: a meta-analysis. Psycho-oncology. Jun. 2009;18(6):571-579. [pmid: 19023879].
56 Mars TS, Abbey H. Mindfulness meditation practise as a healthcare intervention: a systematic review. International Journal of Osteopathic Medicine. 2010;13(2):56-66.
57 Matchim Y, Armer JM. Measuring the psychological impact of mindfulness meditation on health among patients with cancer: a literature review. Oncology nursing forum. Sep. 2007;34(5):1059-1066. [pmid: 17878133].
58 Matchim Y, Armer JM, Stewart BR. Mindfulness-based stress reduction among breast cancer survivors: a literature review and discussion. Oncology nursing forum. Mar. 2011;38(2):E61-71. [pmid: 21356643].
59 Merkes M. Mindfulness-based stress reduction for people with chronic diseases. Australian Journal of Primary Health. 2010;16(3).
60 Musial F, Bussing A, Heusser P, Choi KE, Ostermann T. Mindfulness-based stress reduction for integrative cancer care: a summary of evidence. Forschende Komplementarmedizin (2006). 2011;18(4):192-202. [pmid: 21934319].
61 Niazi AK, Niazi SK. Mindfulness-based stress reduction: a non-pharmacological approach for chronic illnesses. North American journal of medical sciences. Jan. 2011;3(1):20-23. [pmid: 22540058].
62 Ott MJ, Norris RL, Bauer-Wu SM. Mindfulness meditation for oncology patients: a discussion and critical review. Integrative cancer therapies. Jun. 2006;5(2):98-108. [pmid: 16685074].
63 Parikh SV, Segal ZV, Grigoriadis S, et al. Canadian Network for Mood and Anxiety Treatments (CANMAT) clinical guidelines for the management of major depressive disorder in adults. II. Psychotherapy alone or in combination with antidepressant medication. Journal of affective disorders. Oct. Suppl 1. 2009;117:S15-25. [pmid: 19682749].
64 Piet J, Hougaard E. The effect of mindfulness-based cognitive therapy for prevention of relapse in recurrent major depressive disorder: a systematic review and meta-analysis. Clinical psychology review. Aug. 2011;31(6):1032-1040. [pmid: 21802618].
65 Piet J, Wurtzen H, Zachariae R. The effect of mindfulness-based therapy on symptoms of anxiety and depression in adult cancer patients and survivors: a systematic review and meta-analysis. Journal of consulting and clinical psychology. Dec. 2012;80(6):1007-1020. [pmid: 22563637].
66 Proulx K. Integrating mindfulness-based stress reduction. Holistic Nursing Practice. 2003;17(4):201-208. [pmid: 12889548].
67 Querstret D, Cropley M. Assessing treatments used to reduce rumination and/or worry: a systematic review. Clinical psychology review. Dec. 2013;33(8):996-1009. [pmid: 24036088].
68 Rakofsky JJ, Dunlop BW. Treating nonspecific anxiety and anxiety disorders in patients with bipolar disorder: a review. The Journal of clinical psychiatry. Jan. 2011;72(1):81-90. [pmid: 21208580].
69 Reiner K, Tibi L, Lipsitz JD. Do mindfulness-based interventions reduce pain intensity? A critical review of the literature. Pain medicine (Malden, Mass.). Feb. 2013;14(2):230-242.
70 Sarris J, Camfield D, Berk M. Complementary medicine, self-help, and lifestyle interventions for obsessive compulsive disorder (OCD) and the OCD spectrum: a systematic review. Journal of affective disorders. May. 2012;138(3):213-221. [pmid: 21620478].
71 Senders A, Wahbeh H, Spain R, Shinto L. Mind-body medicine for multiple sclerosis: a systematic review. Autoimmune diseases. 2012;2012:567324. [pmid: 23227313].
72 Shennan C, Payne S, Fenlon D. What is the evidence for the use of mindfulness-based interventions in cancer care? A review. Psycho-oncology. Jul. 2011;20(7):681-697. [pmid: 20690112].
73 Shneerson C, Taskila T, Gale N, Greenfield S, Chen YF. The effect of complementary and alternative medicine on the quality of life of cancer survivors: a systematic review and meta-analyses. Complementary therapies in medicine. Aug. 2013;21(4):417-429. [pmid: 23876573].
74 Simpson R, Booth J, Lawrence M, Byrne S, Mair F, Mercer S. Mindfulness based interventions in multiple sclerosis - a systematic review. BMC neurology. 2014;14(1):15. [pmid: 24438384].
75 Smith JE, Richardson J, Hoffman C, Pilkington K. Mindfulness-Based Stress Reduction as supportive therapy in cancer care: systematic review. Journal of advanced nursing. Nov. 2005;52(3):315-327. [pmid: 16194185].
76 Veehof MM, Oskam MJ, Schreurs KM, Bohlmeijer ET. Acceptance-based interventions for the treatment of chronic pain: a systematic review and meta-analysis. Pain. Mar. 2011;152(3):533-542. [pmid: 21251756].
77 Vollestad J, Nielsen MB, Nielsen GH. Mindfulness- and acceptance-based interventions for anxiety disorders: a systematic review and meta-analysis. The British journal of clinical psychology / the British Psychological Society. Sep. 2012;51(3):239-260. [pmid: 22803933].
78 Zainal NZ, Booth S, Huppert FA. The efficacy of mindfulness-based stress reduction on mental health of breast cancer patients: a meta-analysis. Psycho-oncology. Jul. 2013;22(7):1457-1465. [pmid: 22961994].
79 Zgierska A, Rabago D, Chawla N, Kushner K, Koehler R, Marlatt A. Mindfulness meditation for substance use disorders: a systematic review. Substance abuse : official publication of the Association for Medical Education and Research in Substance Abuse. Oct-Dec. 2009;30(4):266-294. [pmid: 19904664].
80 Chiesa A. Vipassana meditation: systematic review of current evidence. Journal of alternative and complementary medicine (New York, N.Y.). Jan. 2010;16(1):37-46.
81 Fann Jr, H T, S KG. Treatment for depression after traumatic brain injury: a systematic review. Journal of NeuroTrauma. 2009;26(12).
82 Tremblay A, Sheeran L, Aranda SK. Psychoeducational interventions to alleviate hot flashes: a systematic review. Menopause (New York, N.Y.). Jan-Feb. 2008;15(1):193-202.
83 Wanden-Berghe RG, Sanz-Valero J, Wanden-Berghe C. The application of mindfulness to eating disorders treatment: a systematic review. Eating disorders. Jan-Feb. 2011;19(1):34-48. [pmid: 21181578].
84 Woltz PC, Chapa DW, Friedmann E, Son H, Akintade B, Thomas SA. Effects of interventions on depression in heart failure: a systematic review. Heart & lung : the journal of critical care. Sep-Oct. 2012;41(5):469-483. [pmid: 22938627].
85 Harper SK, Webb TL, Rayner K. The effectiveness of mindfulness-based interventions for supporting people with intellectual disabilities: a narrative review. Behavior modification. May. 2013;37(3):431-453. [pmid: 23420077].
86 Toneatto T, Nguyen L. Does mindfulness meditation improve anxiety and mood symptoms? A review of the controlled research. Canadian journal of psychiatry. Revue canadienne de psychiatrie. Apr. 2007;52(4):260-266.
87 Ospina MB, Bond K, Karkhaneh M, et al. Meditation practices for health: state of the research. Evidence report/technology assessment. 2007;(155):1-263. [pmid: 17764203].
88 Branstrom R, Kvillemo P, Moskowitz JT. A randomized study of the effects of mindfulness training on psychological well-being and symptoms of stress in patients treated for cancer at 6-month follow-up. Int J Behav Med. Dec. 2012;19(4):535-542. [pmid: 21931958].
89 Price CJ, McBride B, Hyerle L, Kivlahan DR. Mindful awareness in body-oriented therapy for female veterans with post-traumatic stress disorder taking prescription analgesics for chronic pain: a feasibility study. Alternative therapies in health and medicine. Nov-Dec. 2007;13(6):32-40. [pmid: 17985809].
90 Nakamura Y, Lipschitz DL, Landward R, Kuhn R, West G. Two sessions of sleep-focused mind-body bridging improve self-reported symptoms of sleep and PTSD in veterans: A pilot randomized controlled trial. Journal of psychosomatic research. Apr. 2011;70(4):335-345. [pmid: 21414453].
91 Kim SH, Schneider SM, Bevans M, et al. PTSD symptom reduction with mindfulness-based stretching and deep breathing exercise: randomized controlled clinical trial of efficacy. J Clin Endocrinol Metab. Jul. 2013;98(7):2984-2992. [pmid: 23720785].
92 Kearney DJ, McDermott K, Malte C, Martinez M, Simpson TL. Effects of participation in a mindfulness program for veterans with posttraumatic stress disorder: a randomized controlled pilot study. Journal of clinical psychology. Jan. 2013;69(1):14-27. [pmid: 22930491].
93 Guardino CM, Dunkel Schetter C, Bower JE, Lu MC, Smalley SL. Randomised controlled pilot trial of mindfulness training for stress reduction during pregnancy. Psychol Health. 2014;29(3):334-349. [pmid: 24180264].
94 Garland SN, Carlson LE, Stephens AJ, Antle MC, Samuels C, Campbell TS. Mindfulness-based stress reduction compared with cognitive behavioral therapy for the treatment of insomnia comorbid with cancer: a randomized, partially blinded, noninferiority trial. J Clin Oncol. Feb. 10. 2014;32(5):449-457. [pmid: 24395850].
95 Zernicke KA, Campbell TS, Blustein PK, et al. Mindfulness-based stress reduction for the treatment of irritable bowel syndrome symptoms: a randomized wait-list controlled trial. Int J Behav Med. Sep. 2013;20(3):385-396. [pmid: 22618308].
96 Whitebird RR, Kreitzer M, Crain AL, Lewis BA, Hanson LR, Enstad CJ. Mindfulness-based stress reduction for family caregivers: a randomized controlled trial. Gerontologist. Aug. 2013;53(4):676-686. [pmid: 23070934].
97 van Son J, Nyklicek I, Pop VJ, et al. The effects of a mindfulness-based intervention on emotional distress, quality of life, and HbA(1c) in outpatients with diabetes (DiaMind): a randomized controlled trial. Diabetes Care. Apr. 2013;36(4):823-830. [pmid: 23193218].
98 Tang YY, Tang R, Posner MI. Brief meditation training induces smoking reduction. Proc Natl Acad Sci U S A. Aug. 20. 2013;110(34):13971-13975. [pmid: 23918376].
99 Strub L, Tarquinio C. Mindfulness-Based Cognitive Therapy (MBCT) program with workers in an industrial setting: a pilot study. Sante Ment Que. Spring. 2013;38(1):207-225. [pmid: 24336997].
100 Rosenkranz MA, Davidson RJ, Maccoon DG, Sheridan JF, Kalin NH, Lutz A. A comparison of mindfulness-based stress reduction and an active control in modulation of neurogenic inflammation. Brain Behav Immun. Jan. 2013;27(1):174-184. [pmid: 23092711].
101 Perez-Blasco J, Viguer P, Rodrigo MF. Effects of a mindfulness-based intervention on psychological distress, well-being, and maternal self-efficacy in breast-feeding mothers: results of a pilot study. Archives of women's mental health. Jun. 2013;16(3):227-236.
102 Nyklicek I, van Beugen S, Denollet J. Effects of mindfulness-based stress reduction on distressed (type D) personality traits: a randomized controlled trial. J Behav Med. Aug. 2013;36(4):361-370. [pmid: 22585012].
103 Nyklicek I, Mommersteeg PM, Van Beugen S, Ramakers C, Van Boxtel GJ. Mindfulness-based stress reduction and physiological activity during acute stress: a randomized controlled trial. Health Psychol. Oct. 2013;32(10):1110-1113. [pmid: 23527521].
104 Netterstrom B, Friebel L, Ladegaard Y. Effects of a multidisciplinary stress treatment programme on patient return to work rate and symptom reduction: results from a randomised, wait-list controlled trial. Psychother Psychosom. 2013;82(3):177-186. [pmid: 23548852].
105 Moody K, Kramer D, Santizo RO, et al. Helping the helpers: mindfulness training for burnout in pediatric oncology--a pilot program. J Pediatr Oncol Nurs. Sep-Oct. 2013;30(5):275-284. [pmid: 24101747].
106 Monti DA, Kash KM, Kunkel EJ, et al. Psychosocial benefits of a novel mindfulness intervention versus standard support in distressed women with breast cancer. Psycho-oncology. Nov. 2013;22(11):2565-2575. [pmid: 23873790].
107 Malarkey WB, Jarjoura D, Klatt M. Workplace based mindfulness practice and inflammation: a randomized trial. Brain Behav Immun. Jan. 2013;27(1):145-154. [pmid: 23078984].
108 Lo HH, Ng SM, Chan CL, Lam KF, Lau BH. The Chinese medicine construct “stagnation” in mind-body connection mediates the effects of mindfulness training on depression and anxiety. Complementary therapies in medicine. Aug. 2013;21(4):348-357. [pmid: 23876566].
109 Liu X, Wang S, Chang S, Chen W, Si M. Effect of brief mindfulness intervention on tolerance and distress of pain induced by cold-pressor task. Stress Health. Aug. 2013;29(3):199-204. [pmid: 22961992].
110 Lengacher CA, Kip KE, Post-White J, et al. Lymphocyte recovery after breast cancer treatment and mindfulness-based stress reduction (MBSR) therapy. Biol Res Nurs. Jan. 2013;15(1):37-47. [pmid: 22084404].
111 Jacobs TL, Shaver PR, Epel ES, et al. Self-reported mindfulness and cortisol during a Shamatha meditation retreat. Health Psychol. Oct. 2013;32(10):1104-1109. [pmid: 23527522].
112 Hughes JW, Fresco DM, Myerscough R, van Dulmen MH, Carlson LE, Josephson R. Randomized controlled trial of mindfulness-based stress reduction for prehypertension. Psychosomatic medicine. Oct. 2013;75(8):721-728. [pmid: 24127622].
113 Hoge EA, Bui E, Marques L, et al. Randomized controlled trial of mindfulness meditation for generalized anxiety disorder: effects on anxiety and stress reactivity. The Journal of clinical psychiatry. Aug. 2013;74(8):786-792. [pmid: 23541163].
114 Henderson VP, Massion AO, Clemow L, Hurley TG, Druker S, Hebert JR. A randomized controlled trial of mindfulness-based stress reduction for women with early-stage breast cancer receiving radiotherapy. Integrative cancer therapies. Sep. 2013;12(5):404-413. [pmid: 23362338].
115 Grant C, Hobkirk A, Persons E, Hwang V, Danoff-Burg S. Cardiovascular reactivity to and recovery from stressful tasks following a mindfulness analog in college students with a family history of hypertension. Journal of alternative and complementary medicine (New York, N.Y.). Apr. 2013;19(4):341-346.
116 Goldin P, Ziv M, Jazaieri H, Hahn K, Gross JJ. MBSR vs aerobic exercise in social anxiety: fMRI of emotion regulation of negative self-beliefs. Soc Cogn Affect Neurosci. Jan. 2013;8(1):65-72. [pmid: 22586252].
117 Garland EL, Howard MO. Mindfulness-oriented recovery enhancement reduces pain attentional bias in chronic pain patients. Psychother Psychosom. 2013;82(5):311-318. [pmid: 23942276].
118 Fjorback LO, Arendt M, Ornbol E, et al. Mindfulness therapy for somatization disorder and functional somatic syndromes: randomized trial with one-year follow-up. Journal of psychosomatic research. Jan. 2013;74(1):31-40. [pmid: 23272986].
119 Fegg MJ, Brandstatter M, Kogler M, et al. Existential behavioural therapy for informal caregivers of palliative patients: a randomised controlled trial. Psycho-oncology. Sep. 2013;22(9):2079-2086. [pmid: 23532835].
120 Drozd F, Raeder S, Kraft P, Bjorkli CA. Multilevel growth curve analyses of treatment effects of a Web-based intervention for stress reduction: randomized controlled trial. J Med Internet Res. 2013;15(4):e84. [pmid: 23607962].
121 Cavanagh K, Strauss C, Cicconi F, Griffiths N, Wyper A, Jones F. A randomised controlled trial of a brief online mindfulness-based intervention. Behav Res Ther. Sep. 2013;51(9):573-578. [pmid: 23872699].
122 Carlson LE, Doll R, Stephen J, et al. Randomized controlled trial of Mindfulness-based cancer recovery versus supportive expressive group therapy for distressed survivors of breast cancer. J Clin Oncol. Sep. 1. 2013;31(25):3119-3126. [pmid: 23918953].
123 Buhrman M, Skoglund A, Husell J, et al. Guided internet-delivered acceptance and commitment therapy for chronic pain patients: a randomized controlled trial. Behav Res Ther. Jun. 2013;51(6):307-315. [pmid: 23548250].
124 Branstrom R, Kvillemo P, Akerstedt T. Effects of mindfulness training on levels of cortisol in cancer patients. Psychosomatics. Mar-Apr. 2013;54(2):158-164. [pmid: 23218058].
125 Arch JJ, Ayers CR, Baker A, Almklov E, Dean DJ, Craske MG. Randomized clinical trial of adapted mindfulness-based stress reduction versus group cognitive behavioral therapy for heterogeneous anxiety disorders. Behav Res Ther. May. 2013;51(4-5):185-196. [pmid: 23419887].
126 Davis MC, Zautra AJ. An online mindfulness intervention targeting socioemotional regulation in fibromyalgia: results of a randomized controlled trial. Ann Behav Med. Dec. 2013;46(3):273-284. [pmid: 23670111].
127 West CP, Dyrbye LN, Rabatin JT, et al. Intervention to promote physician well-being, job satisfaction, and professionalism: a randomized clinical trial. JAMA internal medicine. Apr. 2014;174(4):527-533. [pmid: 24515493].
128 Arch JJ, Ayers CR. Which treatment worked better for whom? Moderators of group cognitive behavioral therapy versus adapted mindfulness based stress reduction for anxiety disorders. Behav Res Ther. Aug. 2013;51(8):434-442. [pmid: 23747582].
129 Gallegos AM, Hoerger M, Talbot NL, Moynihan JA, Duberstein PR. Emotional benefits of mindfulness-based stress reduction in older adults: the moderating roles of age and depressive symptom severity. Aging Ment Health. 2013;17(7):823-829. [pmid: 23697871].
130 Kocovski NL, Fleming JE, Hawley LL, Huta V, Antony MM. Mindfulness and acceptance-based group therapy versus traditional cognitive behavioral group therapy for social anxiety disorder: a randomized controlled trial. Behav Res Ther. Dec. 2013;51(12):889-898. [pmid: 24220538].
131 Perich T, Manicavasagar V, Mitchell PB, Ball JR, Hadzi-Pavlovic D. A randomized controlled trial of mindfulness-based cognitive therapy for bipolar disorder. Acta psychiatrica Scandinavica. May. 2013;127(5):333-343. [pmid: 23216045].
132 Spahn G, Choi KE, Kennemann C, et al. Can a multimodal mind-body program enhance the treatment effects of physical activity in breast cancer survivors with chronic tumor-associated fatigue? A randomized controlled trial. Integrative cancer therapies. Jul. 2013;12(4):291-300. [pmid: 23766391].
133 Spek AA, van Ham NC, Nyklicek I. Mindfulness-based therapy in adults with an autism spectrum disorder: a randomized controlled trial. Research in developmental disabilities. Jan. 2013;34(1):246-253. [pmid: 22964266].
134 Van Dijk S, Jeffrey J, Katz MR. A randomized, controlled, pilot study of dialectical behavior therapy skills in a psychoeducational group for individuals with bipolar disorder. Journal of affective disorders. Mar. 5. 2013;145(3):386-393. [pmid: 22858264].
135 Wurtzen H, Dalton SO, Elsass P, et al. Mindfulness significantly reduces self-reported levels of anxiety and depression: results of a randomised controlled trial among 336 Danish women treated for stage I-III breast cancer. Eur J Cancer. Apr. 2013;49(6):1365-1373. [pmid: 23265707].
136 Allen M, Dietz M, Blair KS, et al. Cognitive-affective neural plasticity following active-controlled mindfulness intervention. J Neurosci. Oct. 31. 2012;32(44):15601-15610. [pmid: 23115195].
137 Barrett B, Hayney MS, Muller D, et al. Meditation or exercise for preventing acute respiratory infection: a randomized controlled trial. Ann Fam Med. Jul-Aug. 2012;10(4):337-346. [pmid: 22778122].
138 Creswell JD, Irwin MR, Burklund LJ, et al. Mindfulness-Based Stress Reduction training reduces loneliness and pro-inflammatory gene expression in older adults: a small randomized controlled trial. Brain Behav Immun. Oct. 2012;26(7):1095-1101. [pmid: 22820409].
139 Delgado LC, Guerra P, Perakakis P, Vera MN, Reyes del Paso G, Vila J. Treating chronic worry: Psychological and physiological effects of a training programme based on mindfulness. Behav Res Ther. Sep. 2010;48(9):873-882. [pmid: 20541180].
140 Dunn R, Callahan JL, Swift JK, Ivanovic M. Effects of pre-session centering for therapists on session presence and effectiveness. Psychother Res. 2013;23(1):78-85. [pmid: 23066649].
141 Erisman SM, Roemer L. A preliminary investigation of the effects of experimentally induced mindfulness on emotional responding to film clips. Emotion. Feb. 2010;10(1):72-82. [pmid: 20141304].
142 Feldman G, Greeson J, Senville J. Differential effects of mindful breathing, progressive muscle relaxation, and loving-kindness meditation on decentering and negative reactions to repetitive thoughts. Behav Res Ther. Oct. 2010;48(10):1002-1011. [pmid: 20633873].
143 Geng L, Zhang L, Zhang D. Improving spatial abilities through mindfulness: effects on the mental rotation task. Conscious Cogn. Sep. 2011;20(3):801-806. [pmid: 21377899].
144 Greenberg J, Reiner K, Meiran N. “Mind the trap”: mindfulness practice reduces cognitive rigidity. PloS one. 2012;7(5):e36206. [pmid: 22615758].
145 Hulsheger UR, Alberts HJ, Feinholdt A, Lang JW. Benefits of mindfulness at work: the role of mindfulness in emotion regulation, emotional exhaustion, and job satisfaction. J Appl Psychol. Mar. 2013;98(2):310-325. [pmid: 23276118].
146 Jacobs TL, Epel ES, Lin J, et al. Intensive meditation training, immune cell telomerase activity, and psychological mediators. Psychoneuroendocrinology. Jun. 2011;36(5):664-681. [pmid: 21035949].
147 MacCoon DG, Imel ZE, Rosenkranz MA, et al. The validation of an active control intervention for Mindfulness Based Stress Reduction (MBSR). Behav Res Ther. Jan. 2012;50(1):3-12. [pmid: 22137364].
148 Sharpe L, Nicholson Perry K, Rogers P, Dear BF, Nicholas MK, Refshauge K. A comparison of the effect of attention training and relaxation on responses to pain. Pain. Sep. 2010;150(3):469-476. [pmid: 20619540].
149 Sharpe L, Nicholson Perry K, Rogers P, Refshauge K, Nicholas MK. A comparison of the effect of mindfulness and relaxation on responses to acute experimental pain. Eur J Pain. May. 2013;17(5):742-752. [pmid: 23169690].
150 Jensen CG, Vangkilde S, Frokjaer V, Hasselbalch SG. Mindfulness training affects attention--or is it attentional effort?. J Exp Psychol Gen. Feb. 2012;141(1):106-123. [pmid: 21910559].
151 Mrazek MD, Franklin MS, Phillips DT, Baird B, Schooler JW. Mindfulness training improves working memory capacity and GRE performance while reducing mind wandering. Psychol Sci. May. 2013;24(5):776-781. [pmid: 23538911].
152 Kee YH, Chatzisarantis N, Kong PW, Chow JY, Chen LH. Mindfulness, movement control, and attentional focus strategies: effects of mindfulness on a postural balance task. J Sport Exerc Psychol. Oct. 2012;34(5):561-579. [pmid: 23027228].
153 Keng SL, Robins CJ, Smoski MJ, Dagenbach J, Leary MR. Reappraisal and mindfulness: a comparison of subjective effects and cognitive costs. Behav Res Ther. Dec. 2013;51(12):899-904. [pmid: 24225174].
154 Kilpatrick LA, Suyenobu BY, Smith SR, et al. Impact of Mindfulness-Based Stress Reduction training on intrinsic brain connectivity. Neuroimage. May. 1. 2011;56(1):290-298. [pmid: 21334442].
155 Luethcke CA, McDaniel L, Becker CB. A comparison of mindfulness, nonjudgmental, and cognitive dissonance-based approaches to mirror exposure. Body Image. Jun. 2011;8(3):251-258. [pmid: 21561817].
156 Mantzios M, Wilson JC. Making concrete construals mindful: a novel approach for developing mindfulness and self-compassion to assist weight loss. Psychol Health. 2014;29(4):422-441. [pmid: 24215123].
157 McHugh L, Procter J, Herzog M, Schock AK, Reed P. The effect of mindfulness on extinction and behavioral resurgence. Learn Behav. Dec. 2012;40(4):405-415. [pmid: 22227833].
158 McHugh L, Simpson A, Reed P. Mindfulness as a potential intervention for stimulus over-selectivity in older adults. Research in developmental disabilities. Jan-Feb. 2010;31(1):178-184. [pmid: 19815376].
159 Neff KD, Germer CK. A pilot study and randomized controlled trial of the mindful self-compassion program. Journal of clinical psychology. Jan. 2013;69(1):28-44. [pmid: 23070875].
160 Oken BS, Fonareva I, Haas M, et al. Pilot controlled trial of mindfulness meditation and education for dementia caregivers. Journal of alternative and complementary medicine (New York, N.Y.). Oct. 2010;16(10):1031-1038.
161 Palta P, Page G, Piferi RL, et al. Evaluation of a mindfulness-based intervention program to decrease blood pressure in low-income African-American older adults. J Urban Health. Apr. 2012;89(2):308-316. [pmid: 22302233].
162 Robins CJ, Keng SL, Ekblad AG, Brantley JG. Effects of mindfulness-based stress reduction on emotional experience and expression: a randomized controlled trial. Journal of clinical psychology. Jan. 2012;68(1):117-131. [pmid: 22144347].
163 Shapiro SL, Brown KW, Thoresen C, Plante TG. The moderation of Mindfulness-based stress reduction effects by trait mindfulness: results from a randomized controlled trial. Journal of clinical psychology. Mar. 2011;67(3):267-277. [pmid: 21254055].
164 Wolever RQ, Bobinet KJ, McCabe K, et al. Effective and viable mind-body stress reduction in the workplace: a randomized controlled trial. J Occup Health Psychol. Apr. 2012;17(2):246-258. [pmid: 22352291].
165 Warnecke E, Quinn S, Ogden K, Towle N, Nelson MR. A randomised controlled trial of the effects of mindfulness practice on medical student stress levels. Med Educ. Apr. 2011;45(4):381-388. [pmid: 21401686].
166 Werner A, Uldbjerg N, Zachariae R, Rosen G, Nohr EA. Self-hypnosis for coping with labour pain: a randomised controlled trial. BJOG. Feb. 2013;120(3):346-353. [pmid: 23190251].
167 Churchill R, Moore TH, Davies P, et al. Mindfulness-based ‘third wave’ cognitive and behavioural therapies versus treatment as usual for depression. The Cochrane database of systematic reviews. Sep. 8. 2010;(9).