# METHODS

This evidence map provides a visual overview of the existing evidence on mindfulness intervention research. Given the breadth of the research field and diversity of interventions, we used systematic reviews to estimate the research volume and research focus. Systematic reviews follow a standardized and resource-intense approach that aims to identify all pertinent studies to answer a particular research or policy question. Systematic reviews search multiple sources to identify studies, screen potentially relevant studies in detail against specified inclusion and exclusion criteria, and summarize results across individual studies. Studies may be synthesized in a meta-analysis, a statistical technique to pool data across published studies. Meta-analysis is instrumental in detecting treatment effects across individual, often small and statistically underpowered, studies. To give a very broad indication of the clinical effectiveness, we used the results reported across randomized controlled trials (RCTs). RCTs represent a rigorous research design which can provide strong evidence for the effectiveness of mindfulness interventions.

## DATA SOURCES AND SEARCHES

We searched the electronic databases PubMed (using the systematic review clinical query), the Database of Abstracts of Reviews of Effects (DARE, a database dedicated to cataloguing systematic reviews in healthcare), the Cochrane Library of Systematic Reviews (which keeps a record of all ongoing and completed Cochrane reviews), the Campbell Collaboration database (covering reviews on social interventions in crime and justice, education, international development, and social welfare), AMED (the Allied and Complementary Medicine database), CINAHL (which indexes the nursing and allied health literature), and PsycInfo (which is directed at psychological research) to identify English-language systematic reviews published without date restriction focusing on mindfulness interventions to February 2014. In addition, we screened published reviews of reviews and consulted with topic experts.

## STUDY SELECTION

To be included in the evidence map, publications had to meet the following criteria:

- Design: Systematic reviews focusing on mindfulness interventions and summarizing primary research studies were eligible for inclusion in the evidence map. We defined systematic reviews as reviews that either self-identified as a “systematic review” or reviews that reported the search sources and accounted for identified studies.
- Participants: Systematic reviews including adults participating in a mindfulness intervention for any health-related indication were eligible for inclusion. Systematic reviews of adults or unspecified age groups were included; systematic reviews exclusively focusing on children and adolescents were excluded. Systematic reviews were not limited to “patients” and may have targeted staff or non-clinical participants, but the intervention had to be associated with a health-related indication.
- Intervention: Systematic reviews of the effects of mindfulness interventions for any clinical indication were eligible for inclusion. Systematic reviews addressing mindfulness and other approaches were eligible if the term “mindfulness” was part of the search strategy. Systematic reviews with search strategies that did not specify any intervention (eg, focused on an outcome) and that identified mindfulness studies were also included. Systematic reviews that included mindfulness intervention studies but did not systematically search for these (eg, by reviewing “meditation” interventions where only those mindfulness studies were found that used the descriptive term “meditation”), and broad reviews on complementary and alternative medicine approaches without a systematic strategy to identify mindfulness interventions were excluded. We accepted the authors' definition of “mindfulness intervention,” which may include a number of interventions, but publications had to refer to “mindfulness” to be considered.
- Outcome: Patient outcomes were eligible for inclusion. Publications of prevalence, use, costs, study design features, intervention features, or mechanistic outcomes (eg, neurobiological changes, EEG reaction) and not reporting patient health outcomes were excluded.
- Timing: Any intervention duration and any followup point were eligible for inclusion.
- Setting: The setting was not limited to healthcare-related settings, but interventions had to be associated with a health-related indication to be eligible for inclusion.
- Other limiters: Systematic reviews regardless of the publication date were eligible for inclusion. English-language systematic reviews, regardless of the language of the included studies, were eligible.

Two independent literature reviewers screened the systematic review search results. Citations deemed potentially relevant or unclear by at least one reviewer were obtained as full text. The full text publications were screened against the specified inclusion criteria by 2 independent reviewers; disagreements were resolved through discussion. The literature flow was documented in an electronic database and reasons for exclusion of full text publications were recorded.

## DATA ABSTRACTION AND QUALITY ASSESSMENT

We identified systematic reviews meeting the inclusion criteria and removing data duplicates from the database so that each systematic review entered the dataset only once (this entailed consolidating online-only and final publication of articles, Cochrane reviews published in the Cochrane database and in a journal article, multiple updates of Cochrane reviews, and references to systematic reviews differently indexed in general and specialist databases). Where originals and updates of systematic reviews by the same author group were available, only the most recent version was considered.

From each included systematic review, we extracted the specific clinical indication (eg, cancer care) and the main patient outcomes summarized across studies. We extracted the number of included mindfulness RCTs; when randomization information was not available, studies included in the review were retrieved to check their status individually. We extracted whether the review reported statistically significant benefits of mindfulness interventions across included RCTs, the size of the treatment effect for the main patient outcomes together with the comparator, and the number of studies the result was based on. In addition, we abstracted whether the review addressed adverse events.

To address the validity of effects, we documented which particular format of mindfulness intervention (eg, MBSR) the review had searched for and which formats the pooled result was primarily based on. To address the validity of the systematic review, we extracted whether the review was published by an organization known for their expertise and high-quality systematic reviews (eg, Cochrane review). Data were extracted by a content expert and checked by an experienced systematic reviewer in an online database designed for systematic reviews using a pilot-tested, standardized form.

## DATA SYNTHESIS AND ANALYSIS

The evidence base was distilled into a visual overview using a bubble plot format and results were synthesized narratively in an executive summary.

### Bubble plots

The bubble plot uses 5 dimensions to display information: the x-axis; y-axis; the number, size, and color of the bubble.

Clinical indications (number of bubbles): We used the topics of the individual systematic reviews as reported by the review authors to categorize the reviews. Reviews focused on outcomes or clinical indications. All identified systematic reviews were allocated to a single content area and did not enter the bubble plot multiple times. Where reviews provided data for multiple content areas, results were described in the narrative synthesis.

Literature size (x-axis): The bubble plots provide an overview of the research volume for the clinical indications. For this estimate we used the number of included RCTs per review, selecting the systematic review with the most included mindfulness RCTs for the topic as the research volume estimate. Reviews vary in their inclusion criteria for study designs (eg, whether or not they include observational studies). A well-established research design, such as RCTs, that is likely to be included in all reviews, provides a broad estimate of the research volume.

Effect (y-axis): The bubble plot provides a very broad indication of the clinical effectiveness of mindfulness interventions according to patient health outcomes reported in RCTs. For each clinical topic, all available systematic reviews were reviewed. Most emphasis was given to the largest review (which should provide the most complete literature synthesis), Cochrane reviews (given their methodological quality), or reports from agencies specializing in unbiased systematic reviews such as Agency for Healthcare Research and Quality (AHRQ) reports. For effect size estimates, meta-analytic results were sought to provide a summary effect across individual and often small and underpowered studies. In order to provide information on intervention-specific effects, the effect determination focused on the effectiveness of the mindfulness intervention compared to a control group. Preference was given to passive control groups (ie, no intervention, base treatment given to both treatment arms, waitlist group, not further specified usual care, or provider-independent interventions). Comparative effectiveness results and equivalence / non-inferiority demonstrations of mindfulness compared to other active interventions were described in the narrative synthesis.

Reviews (bubble size): We used the size of the bubble to document the number of identified systematic reviews on the topic.

Intervention (color): “Mindfulness” covers a wide range of intervention approaches that are distinctly different, such as MBSR and mindfulness based cognitive therapy (MBCT). In the figure, red indicates the result is primarily based on interventions where mindfulness was only a component of the overall intervention. Pink indicates the result is based on MBSR studies, purple indicates MBCT studies, and yellow indicates the result is based on another selected mindfulness intervention. Blue indicates the result is based on MBSR and MBCT studies, while green indicates the result is based on many different mindfulness-based approaches.

### Executive Summary

While the bubble plot can only display very limited information, the narrative synthesis provides more information on the size of the treatment effect, the individual included clinical indications, the assessed outcomes, characteristics of the identified reviews, the comparator against which the treatment effect was estimated, and other pertinent information on the included studies.

## VA PRIORITY AREAS

The primary clients and technical expert panel (TEP) determined the outcomes and clinical indications post-traumatic stress disorder (PTSD), stress, depression, and wellness to be VA priority areas. We provided more detail on existing research in these a priori identified priority areas, including information on the intervention components, course format, and adverse events of the intervention, where reported.

The published literature continues to grow and new RCTs may challenge existing summaries of the literature. Hence, we have identified recently published RCTs not yet included in published systematic reviews in a scoping review for the identified priority areas. Studies had to be explicitly described as a mindfulness intervention and had to refer to the outcome of interest in the title or the abstract of the citation to be considered. We used the Randomized Controlled Trial filter in PubMed to identify new RCTs. No language restriction was applied.

## FUTURE RESEARCH

We identified evidence gaps by documenting topic areas for which systematic reviews exist, but despite a systematic search, the reviews did not identify relevant RCTs (ie, high evidence level research studies). In addition, we documented clinical indications for which there is conflicting evidence across identified reviews or where reviews concluded that the existing evidence base is insufficient to come to firm conclusions.

The international review registry PROSPERO and the Cochrane library of Systematic Reviews were screened for ongoing reviews. We documented these registered reviews that will become available to summarize a topic area in the near future.

## TECHNICAL EXPERT PANEL

The TEP included Dr. Stephen Ezeji-Okoye, VHA Central Office Field Advisory Committee on Complementary and Alternative Medicine; Laura Krejci, Associate Director Office of Patient Centered Care and Cultural Transformation; Jill Bormann, Associate Nurse Executive/Research and Clinical Nurse Specialist in Adult Psychiatric-Mental Health Nursing with the Veterans Affairs San Diego Healthcare System, San Diego, California; David Kearney, University of Missouri Kansas City Medical School VA Puget Sound Health Care System - Seattle Division; and John (Greg) Serpa, PhD, California School of Professional Psychology VA Greater Los Angeles Healthcare System.

## PEER REVIEW

A draft version of the deliverables was reviewed by technical experts, as well as clinical leadership. Reviewer comments were addressed in the final product and are documented in the appendix.