# PEER REVIEW COMMENTS/AUTHOR RESPONSES

Comment | Response
Line 38 reads “patient sands” instead of “patients and” | Corrected
The use of MBSR and meditation more broadly is of great interest in the management of PTSD. While the map is unclear of the benefit, some of the conditions associated with PTSD such as depression and pain did show potential benefit. Is there any evidence to suggest that symptom improvement in conditions associated with PTSD amongst PTSD patients may be improved? | We have checked the patient population in studies included in the evidence map reviews: 5 RCTs in included reviews were in cancer survivors, one in hurricane survivors, but only one was described in the context of PTSD; that one is included in the identified PTSD review11
Highlighting the fact that in most cases there was not much difference with other active treatments would be helpful as this would help both in showing that multiple approaches that can be used to deal with these conditions as well as highlighting that these may be adjunctive rather than replacement interventions. | To address this point we have added more detail to the results of the 5 comparative effectiveness results, see in particular the VA priority area depression section. Effects varied by comparator and the statistical power to show a difference between groups was often unclear
This project is very well defined and described. | Appreciated
It is clearly stated that this is a review of other reviews and systematic reviews of RCT's. It would seem equally beneficial to differentiate which of those reviews focused on “passive” controls versus “active” control groups. Such information, in my opinion, strengthens the evidence. Having a “wait-list” control where one group receives the mindfulness intervention and the other group receives nothing, seems less compelling than having an active control group. However, given the state of the science on mindfulness research, there is likely to be more RCT's without active control groups. | Passive comparators were the most common comparators but we have expanded the description of comparisons to control groups matched in time and attention and comparative effectiveness results as outlined above
Could the final discussion on results separate those studies or systematic reviews that focused only on passive controls, and then compare findings with systematic reviews using active controls? | We have added more detail to individual sections as outlined above; however, there are too few comparisons and no consistent effect to warrant a separate evidence statement; we have added this point to the future research section
After thoroughly reviewing the article twice, I do not have any edits to suggest. This is a very well written report. | Appreciated
I am not sure that Transcendental Meditation (TM) or relaxation response (RR) fits in this review, although both require concentration, which I view as a form of mindfulness. Although there has been some controversy regarding the history and rigor of TM research, I am aware of some studies now being conducted in active military and veterans groups using both TM and RR. | We acknowledge that there is not a universal agreement on what interventions should be considered “mindfulness.” With input from our partners and TEP, we have included only reviews (and RCTs for priority areas) that specifically refer to “mindfulness” and mantra-based interventions without reference to mindfulness were not eligible for inclusion
The definition of mindfulness using only 2 references and citing Jon Kabat-Zinn (1990) as the source for the Sanskrit definition seems biased to me (as noted on page 1, lines 21-22: “Mindfulness, often translated from Sanskrit to mean “awareness,” is an ancient Buddhist concept whose practice entails the “…non-judgmental awareness of the present moment experience.”1 | We have revised the paragraph accordingly
“For the VA priority areas, recent RCTs using a mindfulness intervention, reporting patient outcomes, and not yet included in existing reviews were also reviewed.” There were studies missing that had “mindfulness” as keyword, even though the term had not been used in the title. | We have restructured the method section and state more clearly now that interventions had to explicitly refer to “mindfulness” in the title to be included. We acknowledge that there is limited agreement on the definition of “mindfulness interventions” and we have added this as a limitation
Before implementation, there needs to be validation of expert facilitators. | We have added a sentence on implementation steps to the limitation section
DBT included in some of the studies which is conceptually problematic. Inclusion of ACT and DBT have been largely accepted in review papers as mindfulness based interventions but I argue the mindfulness component of these interventions, particularly DBT, is secondary and is a potential confound. In DBT, for example, mindfulness is just one quarter of the skills building portion of the intervention which is in turn just a part of the treatment. This is admittedly a minority view. | To address this comment, we have revised the intervention overview and individual sections to avoid confusion and conflation of results; while several reviews included a variety of interventions, only a small number did not differentiate Acceptance and Commitment Therapy and Dialectical Behavior Therapy results from other mindfulness intervention results
Suicidal ideation is not addressed. This is due of course to the typical approach of excluding patients with SI from study participation. While not an RCT, a recent project at the VA (Serpa, Taylor & Tillisch, in press) took all comers and one quarter of MBSR participants reported SI. Class appears to be effective at reducing SI, a particular concern for VA care. | We did not identify a summary estimate on the outcome suicidal ideation. One review6 addressed suicidality but results were based on an individual case study, not the included RCTs; we have added a description to the VA priority section on depression
ln 43 “medication” is meditation | Corrected
This report does not address the specific training requirements for the delivery of mindfulness-based interventions. This is clearly outside the scope of an evidence map yet particularly relevant given the specific skills needed to teach an effective mindfulness course. Many of the studies cited include a description of the interventionist's skill such as “class was provided by a psychologist certified to teach MBSR with experience teaching more than 10 cohorts.” Skill sufficient to teach MBSR is a 2-3 year development process and a life-long learning approach, not a weekend training course. Yet this is an implementation rather than an evidence-based issue. This is a highly effective and easily used evidence map. It is very well executed. | To address this comment we have added information on the intervention, including the training of the interventionist, to the VA priority areas. However, the available information is very limited and we have added this point as a limitation
The review's scope and objectives are clear and well thought out. The method, consisting of using systematic reviews to identify evidentiary data, is problematic despite the attempt to identify differences in approach (ie, MBSR, MBCT, other mindfulness approaches?), since it's unclear (it may be unavoidable given the nature of the reviews) across studies what the key feature of the “mindfulness” training being investigated was. It would have been helpful to have a bit more description of key components of mindfulness including the intensity/length of training, attentional focus, insight, moment-to moment awareness, the degree of home practice, resources provided to intervention subjects. | To the extent possible we have added more information on the mindfulness intervention of successful programs in the VA priority areas. However, we acknowledge that this broad overview does not address pertinent intervention details specific to individual research studies
In terms of stress/distress, it was reported that there was low evidence of improved stress/distress in mindfulness meditation programs but from the studies cited, it was difficult to conclude on the true effectiveness or lack thereof of mindfulness since there was no clear information on stress-specific behavioral or psycho-physiologic responses which might alter as a result of specific mindfulness interventions. | We have revised the AHRQ report summary to avoid confusion (“low” refers to the strength of evidence)
Provide more specifics on the nature of the interventions reviewed, populations studied, more clarity on outcome measures. | See comment above. We have also added more study-level detail on populations and outcome measures, where reported in included reviews; but the information is limited
Toneatto, T. & Nguyen, L. Does mindfulness meditation improve anxiety and mood symptoms? A review of the controlled research. Canadian Journal of Psychiatry; 2007; 52:260-266. | We have added this review (it was not indexed as a systematic review for multiple reasons) but met inclusion criteria
Hofmann SG, Sawyer AT, Witt AA, Oh D. The effect of mindfulness-based therapy on anxiety and depression: a meta-analytic review. J Consult Clin Psychol 2010;78:169–183. | The review is included in the evidence map (ref 42)
Orme-Johnson DW & Barnes VA. Effects of the transcendental meditation technique on trait-anxiety: a meta-analysis of randomized controlled trials. J Alt & Comp Med 2014;(20)5: 330-341. | See above. Meditation approaches without reference to mindfulness were not eligible for inclusion
Bormann JE, Thorp S, Wetherell JL, Golshan S, & Lang AJ. Meditation-based mantram intervention for veterans with posttraumatic stress disorder: a randomized trial. Psychological Trauma: Theory, Research, Practice, and Policy; 2013;(5)3:259-267. | The study was part of the review on mind-body practices for PTSD;11 we have added more detail to the VA priority area section on PTSD
Bormann JE, Thorp S, Wetherell JL, Golshan, S. A spiritually based group intervention for combat veterans with PTSD: Feasibility study. Journal of Holistic Nursing, 2008:26(2), 109-116. | See above. We had to restrict this review to studies explicitly referring to mindfulness, hence this was outside the scope of the overview
There are several published studies on Mindfulness and ADHD in adults and children which were omitted. See chapter by Zylowska, L, Smalley, S. and Schwartz, J. in Handbook for Mindfulness, e. Fabrizio Didona, New York,: Springer-Verlag, 2008. | We did not identify systematic reviews on mindfulness and ADHD. A RCT in adults with ADHD reporting on the outcome depression133 is included (see priority section) but studies in children were outside the scope of the review
Baijal, S. &Gupta, R.,” Meditation Based Training: A Possible Intervention for Attention Deficit Hyperactivity Disorder .: Psychiatry 5, no. 4 (April, 2008): 48-55. | The review was assessed but did not meet inclusion criteria for a systematic review
Our current study addresses the use MBCT in suicidal veterans. | The study will be of great interest to the VA; however, this evidence map displays the published literature
There is a study by Williams, J. M.G.& Swales, M. The Use of Mindfulness-Based Approaches for Suicidal Patients. Archives of Suicide Research, 8:315-329, 2004 in this emerging area. | We assessed the review but it did not meet inclusion criteria for a systematic review

Note: we omitted comments specific to the dissemination within the VA