# Evidence Brief: Use of Performance Measures as Criteria for Selecting Community Cardiac and Orthopedic Surgical Providers for the Veterans Choice Program

## PREFACE

The VA Evidence-based Synthesis Program (ESP) was established in 2007 to provide timely and accurate syntheses of targeted healthcare topics of particular importance to clinicians, managers, and policymakers as they work to improve the health and healthcare of Veterans. QUERI provides funding for four ESP Centers, and each Center has an active University affiliation. Center Directors are recognized leaders in the field of evidence synthesis with close ties to the AHRQ Evidence-based Practice Centers. The ESP is governed by a Steering Committee comprised of participants from VHA Policy, Program, and Operations Offices, VISN leadership, field-based investigators, and others as designated appropriate by QUERI/HSR&D.

The ESP Centers generate evidence syntheses on important clinical practice topics. These reports help:

- Develop clinical policies informed by evidence;
- Implement effective services to improve patient outcomes and to support VA clinical practice guidelines and performance measures; and
- Set the direction for future research to address gaps in clinical knowledge.

The ESP disseminates these reports throughout VA and in the published literature; some evidence syntheses have informed the clinical guidelines of large professional organizations.

The ESP Coordinating Center (ESP CC), located in Portland, Oregon, was created in 2009 to expand the capacity of QUERI/HSR&D and is charged with oversight of national ESP program operations, program development and evaluation, and dissemination efforts. The ESP CC establishes standard operating procedures for the production of evidence synthesis reports; facilitates a national topic nomination, prioritization, and selection process; manages the research portfolio of each Center; facilitates editorial review processes; ensures methodological consistency and quality of products; produces “rapid response evidence briefs” at the request of VHA senior leadership; collaborates with HSR&D Center for Information Dissemination and Education Resources (CIDER) to develop a national dissemination strategy for all ESP products; and interfaces with stakeholders to effectively engage the program.

Comments on this evidence report are welcome and can be sent to Nicole Floyd, ESP CC Program Manager, at Nicole.Floyd@va.gov.

## EXECUTIVE SUMMARY

After a reported access crisis in the VHA involving long wait times, the 2014 Veterans Access, Choice, and Accountability Act (VACCA) was passed. It established the Veterans Choice Program or “Choice” to expand Veterans' access to community providers when VHA medical facilities have long wait times or when geographic accessibility is excessively burdensome. Choice provider network inadequacy is one challenge that stemmed from implementing a complex program under an aggressive timeline. Accordingly, the VHA is planning to replace and expand existing community care networks.

Quality, efficiency, and costs of surgeries still vary greatly among community providers. The Institute of Medicine (IOM) defines quality of care as “the degree to which health services for individuals increase the likelihood of desired health outcomes and are consistent with current professional knowledge.” Performance measurement is the regular collection of data on health care processes, experiences, and/or patient outcomes for use in characterizing variation in quality and efficiency across providers and facilities. The Office of Community Care is considering adopting performance measures to identify eligible community orthopedic and cardiac surgery providers that meet certain minimum requirements.

A significant barrier to the Office of Community Care in selecting performance measures for determing community provider eligibility is that there are a large number of measures meant as indirect indicators of health outcomes (eg, readmissions, process measures, etc) but uncertainty about their actual association with health outcomes (eg, mortality, quality of life, or function). The purpose of our review was to determine whether such performance measures are associated with health outcomes and compare their measurement burden and unintended consequences.

#### Background

The ESP Coordinating Center (ESP CC) is responding to a request from the Office of Community Care for an evidence brief on the use of performance measures for selective contracting with community cardiac and orthopedic surgical providers. Findings from this evidence brief will be used to inform the development of value-based community care purchasing pilots.

#### Methods

To identify studies, we searched MEDLINE®, CINAHL, CCRT, CDSR, NHS Economic Evaluation, and other sources through April 2017. We used prespecified criteria for study selection, data abstraction, and rating internal validity and strength of the evidence.

### Summary of Findings

All-cause 30-day readmission is a moderate-strength indicator of 30-day mortality for coronary artery bypass grafting (CABG). Thirty-day readmission is a weaker indicator of early mortality for hip replacement. The correlations with early mortality are modest (eg, R range, 0.32 to 0.38; OR 1.14), but consistent. Thirty-day readmission would likely be feasible to collect as all community Medicare providers are already mandated to collect this information, but several potential limitations must be considered, such as lack of consensus on case-mix adjustment methods, whether to include socioeconomic status (SES), and difficulties capturing readmissions to non-index hospitals. Although the use of 30-day mortality as a measure of quality has recently been questioned, a recent VHA study reinforced its usefulness as a surrogate for long-term outcomes and disputed its susceptibility to gaming.

Adherence to standardized CABG wait time protocols, a set of cardiac surgery process measures, and a specific cardiac surgery antibiotic prophylaxis guideline-based protocol, but not other studied individual process measures, has decreased the likelihood of mortality and complications in cardiac surgery but not orthopedic surgery. We did not find any studies of performance measures collected in the inpatient setting that directly assessed the quality of postoperative bundles of care.

### Implications for Policy and Implementation

Possible minimum requirements for Choice providers include acceptable performance on national rankings, compatible operational infrastructure, and ability to comply with an agreed-upon wait time threshold. In addition to these minimum requirements, the Office of Community Care could consider the added value of the performance measures that this review has identified as being indicators of desirable health outcomes. These include the single measures of 30-day mortality, a direct health outcome measure, and/or 30-day readmission, the indirect measure with the strongest association with mortality – both of which are commonly measured by surgery programs. Another option is to use a composite performance measure that includes mortality, readmission, and other process measures – such as the Society of Thoracic Surgeons' (STS) composite CABG measure. Also, we recommend use of public reporting program participation and measures of efficiency as additional considerations for Choice community provider minimum standards.

However, an unintended effect of stricter performance measure-based criteria for selective contracting with Choice providers may be an undersupply of providers, which could diminish Choice's effect on reducing Veterans' wait times.

Executive Summary Table 1 Summary of Findings

Population: Evidence base | Summary of findings on validity as indicators of quality
Early all-cause mortality
CABG: 1 fair-quality retrospective cohort study^1^ | No correlation between all-cause risk-adjusted in-hospital mortality with preventable mortality (r = -0.42, P = 0.26) ★★
Cardiac and orthopedic surgery: 1 good-quality retrospective cohort study^2^ | 30-day mortality is a valid surrogate of 365-day survival in the VHA; 365-day survival in highest 30-day mortality risk decile vs others for cardiac (81% vs 91-98%) and orthopedic (77% vs 96-99%)^‡^ ★★
Readmission
CABG: 6 fair- to good-quality retrospective cohort studies^3-8^ | Consistent significant association with 30-day mortality across 3 of most rigorous studies (r range, 0.32 to 0.38; OR 1.14^†^), but not with process measures.^4^ ★★★
Hip replacement: 1 fair-quality retrospective cohort^7^ | Higher risk of readmission in highest vs lowest mortality quartile (11.7% vs 10.2%-10.9%; P < 0.001), but no association with process measures★★
Any orthopedic surgery: 1 good-quality retrospective cohort^9^ | Significant association with 2 aggregate process compliance measures (r range, -0.05 to -0.06) ★★
Surgical standard adherence
CABG: 5 fair- to good-quality retrospective studies.^10-14^ | Low ‘total care quality’ scores^*^, but not single process measures associated with increased risk of 30-day mortality and complications (OR range, 1.51 to 1.91)^12^ ★★ Antibiotic protocol violation associated with increased mortality and complications (OR range, 7.03 to 10.16)^14^★★
Hip or knee replacement: 2 fair-quality retrospective cohort study^15,16^ | Nonsignificant trend toward higher rate of 30-day mortality for hospitals at bottom 50% of performance on a composite of process measures (r = 0.116, P = 0.088) ★★ No association of adherence to multiple individual SCIP measures and post-operative infection rates or hospital-level SSI rates, with the exception of increased infection rates with higher adherence to VTE prophylaxis (OR range, 1.50 to 1.91) ★★
Wait times
CABG: 1 fair-quality prospective^17^ and 1 fair-quality retrospective^18^ cohort study. | Adherence to a short delay wait time protocol significantly reduced risk of in-hospital mortality (OR 0.32, 95% CI 0.20 to 0.51) ★★ Use of a wait-time triage system to assign standard wait times of 0 days for emergent cases, 7 days for in-hospital urgent, 21 days for out-of-hospital semi-urgent A, and 56 days for semi-urgent B resulted in equitable composite mortality and morbidity score across waiting groups. Emergent: (OR 2.5, 95% CI 0.95 to 6.5) In-hospital urgent: (OR 0.9, 95% CI 0.4 to 1.9) Out-of-hospital semi-urgent A: (OR 0.7, 95% 0.3 to 1.6) ★★

* The “total care quality” score ranges from 0 to 5-6, where 0 means no process measures were met and 5-6 is the total number of process measures used

† ESP calculated OR using online calculator available at https://www.medcalc.org/calc/odds_ratio.php

‡ ESP calculated percentages using an online tool available at http://arohatgi.info/WebPlotDigitizer/app/

Abbreviations: CABG=coronary artery bypass grafting; SCIP=Surigical Care Improvement Project; VTE=Venous Thromboembolism

Strength of evidence: ★=Insufficient, ★★=low, ★★★=moderate, ★★★★=high

## EVIDENCE BRIEF

INTRODUCTION

### PURPOSE

The ESP Coordinating Center (ESP CC) is responding to a request from the Office of Community Care for an evidence brief on the use of performance measures for selecting community cardiac and orthopedic surgical providers for the Veterans Choice Program. Findings from this evidence brief will be used to inform development of value-based community care purchasing pilots.

### BACKGROUND

In 2014, after reports of long waiting times for VA clinical services,^19^ Congress passed the Veterans Access, Choice, and Accountability Act (VACCA), which expanded the criteria through which Veterans can access civilian providers.^20^ VACCA mandated the VHA to implement a new national program within 90 days that allowed Veterans to pursue care from a third-party administrator’s (TPA) network provider in their community when VHA medical facilities have long wait times or when geographic accessibility is excessively burdensome (Veterans Choice Program or “Choice”). Important aspects of VACCA are that community providers must (1) “maintain the same or similar credentials and licenses as VA providers”, and (2) enter agreements with VA to furnish care rather than an open market or ‘voucher-based’ system.

Implementation of a new national program is a complex process, and Choice’s aggressive implementation timeline created challenges. Community provider network inadequacy was among a number of specific challenges identified by the VA Office of Inspector General review of the first 11 months of Choice implementation (November 1, 2014 through September 30, 2015).^21^ The VHA is planning to replace and expand existing community care networks to improve the quality of care for some services, such as general and vascular surgeries^22^ and Percutaneous Coronary Intervention (PCI).^23^ Possible minimum requirements for Choice providers might include acceptable performance on national rankings, compatible operational infrastructure (eg, billing systems that can process bundled payments), and ability to comply with an agreed-upon wait time threshold. In addition to such requirements, the Office of Community Care is considering using performance measures to select and monitor community providers.^24^ Initial pilots are targeting orthopedic and cardiac surgery because they are frequently performed and relatively standardized.

#### Health Care Quality and Purpose of Performance Measurement

A challenge in performance measurement is the variation in how quality is defined.^25^ The Institute of Medicine (IOM) defines quality of care as “the degree to which health services for individuals increase the likelihood of desired health outcomes and are consistent with current professional knowledge.”^26^ Health care quality is a complex concept that encompasses clinical processes and health outcomes^27^ which are susceptible to influence by provider, system, social, socioeconomic, and patient risk factors and adherence to care.^28^ Performance measurement, a critical tool for quality improvement, is “the regular collection of data to assess whether the correct processes are being performed and desired results are being achieved.”^29^ As part of a quality improvement system, performance measures are used to characterize variation in quality across providers and facilities, identify substandard care, and monitor improvements in the context of quality improvement efforts.^15^ To better align quality with patients’ values, arguments have been made to focus performance assessment on survival beyond 30 days^30^ and/or the subset of preventable deaths that could have been avoided if optimal care had been delivered.^1,31^

#### Proliferation of Performance Measures and Variation in Their Use

There is no gold standard for performance measurement,^32^ and development of performance measures has proliferated over the past 2 decades. Different organizations use different sets of measures (supplemental materials Appendix A). National Quality Forum (NQF), Surgical Care Improvement Project (SCIP), American College of Surgeons’ National Surgical Quality Improvement Program (ACS NSQIP), and the VA Surgical Quality Improvement Program (VASQIP) have developed and maintain various measure sets. The number of measures ranges from 15 in SCIP^33^ to 135 in NSQIP.^34^ Most measures sets are developed by expert consensus, although the VASQIP was developed by the National VA Surgical Risk Study (NVASRS) from 1991-1993.^35^ Performance measure sets most often include both process and outcome measures. Common individual process measures include receipt and timing of prophylactic antibiotic, and common outcome measures include 30-day mortality and 30-day readmissions. Composite performance measures have also been created to broadly encapsulate the overall quality of care by combining information from multiple individual outcome and process performance measures into a single, comprehensive, multidimensional measure.^36^

To evaluate the quality of surgery services within VA, the National Surgery Office evaluates all-cause 30-day unadjusted mortality and risk-adjusted observed-to-expected (O/E) ratios for 30-day mortality and morbidity for VASQIP-assessed procedures. Expected figures are calculated using VASQIP models that consider the patient populations’ associated risk factors. Surgical care delivery is evaluated by case review and site visit for any program whose outcomes deviate with statistical significance from national program O/E ratios.^2^ Other organizations base their evaluation of surgical quality on other measures. For example, the Society of Thoracic Surgeons (STS)^37-39^ evaluates quality of cardiac surgery using risk-adjusted mortality, risk-adjusted morbidity, optimal surgical techniques, and NQF recommended medications.^40^ Consumer Reports publishes rankings based on these STS measures. Hospital Compare, from the Centers for Medicare & Medicaid (CMS), reports results from the American College of Surgeons’ National Surgery Quality Improvement Program (ACS-NSQIP), which, like VASQIP, relies on review of medical records rather than on insurance claims.^41^ US News & World Report rankings, which are developed by RTI International, uses the 3M Health Information Systems Medicare Severity Grouper, reputational surveys, and hospital indicators such as staffing ratios and surgical volume to rate surgery centers.^42^

#### Use of Performance Measures for Competency Assessment

Performance measures were originally designed for various internal uses, such as to monitor and improve quality and efficiency. In this context, it is sufficient to subjectively view performance measures as relevant indicators of health care quality. Performance measures have been adapted for use in external competency assessment and to reduce payment and contracting opportunities for poor performers.^43,44^ For example, CMS’s Hospital Readmissions Reduction Program (HRRP) uses Excess Readmission Ratios (ERRs) to determine hospitals’ reimbursement levels for Coronary Artery Bypass Graft (CABG) and elective primary Total Hip and/or Total Knee Arthroplasty (THA/TKA).^45^ A 2014 RAND Corporation research report found that value-based purchasing programs (eg, pay-for-performance, accountable care organizations, bundled payments) typically determine reimbursement based on measures of clinical process and intermediate outcomes, patient safety measures, utilization, patient experience, and, to a more limited degree, outcomes and structural elements.^46^ Because the use of performance measures in these ways has potential financial consequences for providers, it is important that the measures that are used can be applied consistently, reliably, and equitably; are feasible to collect in community practice settings; and are valid quality indicators – that is, have been shown to be predictive of or associated with health outcomes.

#### How to Choose Performance Measures for Selective Contracting

With the proliferation of performance measures, it is important to have a framework for deciding (1) which measures to use to select and monitor community providers, and (2) how to use them. One clear principle is to use a small set of measures that focuses on the highest-priority clinical goals.^47^ After a period of time in which the number of new performance measures adopted by the VA and non-VA organizations grew, we have begun to reduce the number and focus on the most important measures.^48^ Secondly, use valid measures – measures that directly measure or have been proven to be strong indicators of health outcomes. Applying these principles may reduce feelings of measurement overload and measurement irrelevance. A third principle is to apply measures judiciously, rather than formulaically. This means adjusting for factors outside the hospital’s control, such as social and economic conditions.^43,49,50^ More detailed criteria for equitable performance measurement have been proposed. Equitable performance measures should: (1) have established standards for satisfactory performance, (2) be collected in a standardized and reliable way, (3) be applicable to a group of patients of sufficient size to provide reliable estimates for individual physicians, (4) be adjusted for confounding patient factors, (5) be attributable to individual physicians, (6) be feasible to collect, (7) be representative of the activities of the specialty, and (8) have minimal unintended consequences.^15,25,44,51^

However, several information gaps make it difficult to adapt performance measurement to the purposes of selecting and monitoring community providers. Although there are a large number of measures meant as indirect indicators of health outcomes (eg, readmissions, process measures, etc), there is uncertainty about their actual association with health outcomes (eg, mortality, quality of life, or function). For example, although a 1997 review by Ashton et al found 31-day readmission to be a valid indicator of quality of care based on its association with process of care measures, it did not evaluate association with patient-centered outcomes.^52^ Also, although there is general agreement that in order to fairly compare hospital performance based on health outcomes, measures must be risk-adjusted based on patient-level factors to account for differences in case mix, further development may be needed to improve their ability to not discriminate against high-risk patients and to answer questions about whether and how to adjust for broader social and environmental factors.^27,53-56^ Finally, although performance measurement has been key in increasing utilization of evidence-based practices, concern has been expressed that it has created an array of unintended consequences including overtreatment, diminished attention to patient needs and preferences, providers’ feelings of loss of autonomy, and gaming. However, recent systematic reviews have found that few studies have evaluated unintended effects at least in the context of value-based payment implementations.^46,57^

The goal of this rapid evidence brief is to determine whether certain performance measures meant as indirect indicators of health outcomes are associated with actual health outcomes and evaluate their measurement burden, and their potential unintended consequences.

### SCOPE/ANALYTIC FRAMEWORK

The underlying logic that guided our review is that the impact of using performance measures as criteria for selecting providers depends on whether the measures are indicative of lower complication and readmission rates, improved long-term survival and quality of life, and have acceptable measurement burden and unintended effects. The analytic framework (Figure 1) visually depicts this logic. The Key Questions and Inclusion Criteria define our specific focus within this framework.

Figure 1 Analytic Framework

Key Question 1: When used as criteria for selecting providers, are certain performance measures valid indicators of surgical quality?

a. Is satisfactory performance on certain process standards associated with improved complications, lower readmissions, early survival, and long-term outcomes?
b. Are reduced readmission rates associated with improved early survival and long-term outcomes?
c. Is improved early survival associated with improved long-term outcomes?

Key Question 2: What is the comparative measurement burden of different performance measures?

Key Question 3: What are the unintended effects of using performance measures for selective contracting of community providers?

### ELIGIBILITY CRITERIA

The ESP included studies that met the following criteria:

- Surgical services: Orthopedic and cardiac surgery services. We prioritized non-emergent total hip replacement, total knee replacement, and coronary artery bypass surgeries (CABG) as those are the most common VASQIP-assessed procedures.
- Health outcome performance measures: Early readmission rates, mortality rates
- Process performance measures: Post-operative plan of continuing care (eg, rehabilitation plan), wait times, adherence to surgical standards (eg, guideline compliance, infection-related outcome sets (eg, SCIP))
- Measurement burden: IT environment characteristics (eg, automated methods for collecting and auditing data, certification, interoperability), public reporting, audit and feedback, and electronic decision-support tools, chart review
- Unintended effects: Gaming, risk-based patient selection, appropriateness of care, changes in disparities, spillover effects, et cetera
- Timing: Any study follow-up durations
- Setting: Any
- Study design: Any, but may prioritize to accommodate timeline using a best-evidence approach

## METHODS

To identify articles relevant to the key questions, our research librarian searched MEDLINE®, CINAHL, CCRT, CDSR, and NHS Economic Evaluation up to 06/19/2017 using terms for quality indicators, cardiac or orthopedic surgery, and specific measures of interest (see Appendix B in the supplemental materials for complete search strategies). Additional citations were identified from hand-searching reference lists and consultation with content experts. We limited the search to published and indexed articles involving human subjects available in the English language. Study selection was based on the eligibility criteria described above. Titles, abstracts, and full texts were reviewed by one investigator and checked by another. All disagreements were resolved by consensus.

We used predefined criteria to rate the internal validity of all controlled cohort studies.^58^ We abstracted data on setting, population, measurement methods, and results from all controlled cohort studies using a standardized form. All data abstraction and internal validity ratings were first completed by one reviewer and then checked by another. All disagreements were resolved by consensus.

We informally graded the strength of the evidence based on the AHRQ Methods Guide for Comparative Effectiveness Reviews, by considering risk of bias (includes study design and aggregate quality), consistency, directness, and precision of the evidence.^59^ Ratings typically range from high to insufficient, reflecting our confidence that the evidence reflects the true effect. For this review, we applied the following general algorithm: evidence comprised primarily of uncontrolled case series or retrospective cohort studies with high risk of bias received ratings of ‘insufficient’; evidence consisting of a single retrospective good-quality study received a rating of ‘low strength’; and evidence consisting of multiple retrospective and/or prospective, consistent, precise, fair-to-good quality studies received a rating of ‘moderate strength’. We found no ‘high-strength’ evidence, but this generally would have been comprised of multiple, prospective, good-quality, precise cohort studies. We synthesized the evidence qualitatively, as meta-analysis was not suitable due to limited data or heterogeneity.

A draft version of this report was reviewed by technical experts selected to represent relevant specialties including surgery, value-based purchasing, and systematic review methodology. Their comments and our responses are available in Appendix E in the supplemental materials.

## RESULTS

### LITERATURE FLOW

The literature flow diagram (Figure 2) summarizes the results of the search and study selection processes.

Figure 2 Literature Flowchart

Searches resulted in 3,519 unique potentially relevant articles. Overall, we included 38 studies: 6 systematic reviews^60-65^ one randomized controlled trial,^66^ and 31 observational studies.^1-12,14-18,67-80^ Only 4 of the observational studies were prospective cohorts,^8,14,17,66^ with the rest being retrospective. Eleven studies addressed adherence to a surgical standard,^10-12,14-16,68,71,72,74,76^ 7 addressed readmission,^3-9^ 18 addressed wait times,^17,18,60-67,69,70,73,75,77,79-81^ and 2 addressed mortality.^1,2^ Detailed reasons for study exclusion are provided in Appendix C in the supplemental materials. More than half of the studies were multicenter (66%) and within the US (53%), but only 44% used data collected in the last decade. Median sample size was 2,218 (range 47 to 2,121,215). Of the studies we formally quality assessed, most were good^2-4,7-12,72^ or fair quality.^1,5,6,14-18^ We rated 4 studies as poor quality for lack of adjustment for potential confounders, lack of information on missing data, and/or potential risk of selection bias.^68,71,74,76^ Sixteen studies had high levels of adjustment for patient-, procedure-, and provider-level factors,^2-5,7-12,14,16,18,66,72,81^ while 7 studies adjusted for patient-level factors only,^1,6,15,17,67,74,76^ and 2 studies did not adjust for any confounding factors.^68,71^ We did not formally assess the quality of the systematic reviews or 7 studies in orthopedic fracture populations,^69,70,73,75,77,79,80^ as these emergency populations were of less direct relevance to this review (full details of data abstraction and quality assessment in Appendix D in the supplemental materials).

### KEY QUESTION 1A Is satisfactory performance on certain process standards associated with improved complications, lower readmissions, early survival, and long-term outcomes?

#### Wait Time

Adherence to standardized CABG wait time protocols shows a decrease in the likelihood of mortality.^17,18^ We found no studies on wait times for total knee replacements or total hip replacements. For emergent hip fracture repair in the elderly, delays beyond 24-48 hours are associated with increased mortality and complications, but this evidence likely has limited applicability to the non-emergent, elective surgery populations of greatest interest in this review.

##### Cardiac Surgery

Delays exceeding British Columbia provincial wait list guidelines (6 weeks for semiurgent and 12 weeks for nonurgent) were associated with increased probability of in-hospital death based on findings from a large, nationally representative retrospective cohort studiy in a cardiac surgery population awaiting CABG (Table 1).^18^ This study evaluated the association of adherence to 2 separate established wait time guidelines – British Columbia provincial and the stricter Canadian Cardiac Society (CCS) (2 weeks for semiurgent and 6 weeks for nonurgent) – and in-hospital mortality by comparing outcomes across 3 categories of delays: short (within CCS timeframes), prolonged (longer than CCS but within provincial targets), and excessive (longer than both guidelines). Adherence to at least the provincial guidelines could potentially decrease risk of in-hospital mortality, as the short CCS timeframes had a protective effect compared with nonadherence with both guidelines, but not compared to the provincial guideline adherence. The validity of adherence to a strict wait time protocol as an indicator of quality of care is also supported by the finding that use of a wait-time triage system to assign standard wait times of 0 days for emergent cases, 7 days for in-hospital urgent, 21 days for out-of-hospital semi-urgent A, and 56 days for semi-urgent B resulted in equitable mortality and morbidity across waiting groups.^17^ Although the supporting study likely had limited statistical power and applicability because it focused on a small sample of patients with left main coronary artery disease from a single hospital in Halifax, its approach to evaluating the safety of using a standardized triage system for determining CABG wait times is an important mechanism for evaluating the validity of wait time protocols as quality indicators.^17^ No studies reported on readmission, complication or other outcomes of interest. Both studies^17,18^ adjusted for patient, clinical, and surgical factors (see appendix D), but were conducted outside the US, so their applicability to the US health care system is limited.

Table 1 Cardiovascular Surgery Wait Times and Patient Outcomes

Author, Year N | Setting | Population | Mortality
Légaré 2005^17^ N=561 | 1 hospital in Halifax, Nova Scotia 1999-2003 | CABG among patients with stenosis of the left main coronary artery | Composite measure^*^ including in-hospital mortality rate for: Wait longer than standard waiting time OR 0.7 (95% CI 0.4 to 1.2) Queue assignment compared to out-of-hospital semi-urgent B for composite score: Emergent OR 2.5 (95% CI 0.95 to 6.5) In-house urgent OR 0.9 (95% CI 0.4 to 1.9) Out-of-hospital semi-urgent A OR 0.7 (95% CI 0.3 to 1.6)
Sobolev 2012^18^ N=9,593 | 4 cardiac centers in British Columbia, population-based patient registry 1992-2006 | CABG | In-hospital mortality rate for: Excessive delay OR 1.00 (Reference) Prolonged delay OR 0.78 (95% CI 0.38 to 1.63) Short delay OR 0.32 (95% CI 0.20 to 0.51)

* Comprised in-hospital death from any cause, mechanical ventilation for more than 24 hours postoperatively, and postoperative length of hospital stay of more 9 days

Abbreviations: CABG=Coronary Artery Bypass Grafting; OR=Odds Ratio

##### Emergent Fracture Repair

Early surgery (usually within 24-48 hours) was associated with reduced mortality (OR 0.74, 95% CI 0.67 to 0.81) in elderly patients with hip fractures needing emergent repair according on the best evidence from a 2012 good-quality systematic review of 35 studies.^62^ However, it is important to note that adjusted and unadjusted data were combined, and the cut-off time for wait time and mortality varied by study. When stratified by cut-off time for surgical delay (<12, <24, <48, <96 hours), results showed a significant association between wait time and mortality for wait times within 24-48 hours, but no association betweeen other cut-off times. Among systematic reviews that looked at complications in this population,^61,64,65^ the most recent good-quality systematic review^65^ found early surgery (within 24-48 hours) to be associated with decreased rates of pneumonia (RR 0.59; 95% CI 0.37 to 0.93; 2 studies; N=2793) and pressure sores (RR 0.48; 95% CI 0.34 to 0.69; 3 studies; N=3023), but not deep vein thrombosis (RR 0.97; 95% CI 0.56 to 1.68; 2 studies; N=4679) or pulmonary embolism (RR 0.66; 95% CI 0.17 to 2.58; 2 studies; N=2822). The study authors caution that their confidence in the finding is limited because the included primary studies did not adjust for potential confounding factors.^65^

Findings from subsequently published primary literature neither confirm nor refute these findings due to their serious methodological limitations or use of a prolonged follow-up period.^67,75,81^ Wait times exceeding 24 hours were not associated with 1-year mortality in a sample of 567 people admitted to a single orthogeriatric unit in Oslo.^67^ This study was underpowered to find a difference; post-hoc power for the study was 42.2% and revealed that a future study to would require 1,249 patients to reach adequate power.^82^ In a sample of 828 patients in Italy, wait times exceeding 48 hours were not associated with 2-year mortality.^75^ A strength of this study was its adjustment for comorbidities. But it is unclear how comparable findings from a 2-year follow-up period are to the most recent systematic review^62^ in which the mean follow-up period was unspecified, but most likely shorter. Finally, the most recent study^81^ found no association between wait time and mortality in the elderly hip fracture population. However, we have limted confidence in its findings due to the lack of adjustment for any potential confounders and small sample size.

In hip fracture repair populations not restricted to the elderly, one good-quality systematic review found that the majority of studies (14/24) that adequately controlled for confounding did not find a correlation between wait time and mortality, but found that delays increased risk of complications.^60^ Results were consistent regardless of variation in adjustment, cut-off time for wait time, and cut-off time for mortality. Among 4 subsequently published primary studies,^66,70,73,77^ results from the single study^77^ that adequately controlled for potential confounding (adjusted for age, gender, race, comorbidity burden, insurance status, day of admission, hospital size, teaching status, and region) were consistent with and strengthen the findings of the systematic review (Table 2).

Table 2 Wait Time and Patient Outcomes in Orthopedic Surgery (Studies not captured in systematic reviews)

Author, Year N | Population/Setting | Mortality | Complications/Readmissions
Hip fracture (elderly)
Holvik 2010^67^ N=567 | Oslo, Norway 2007-2008 | 1-year all-cause mortality rate for ≤24 hours vs >24 hours RR= 0.48 (95% CI 0.21 to 1.10) | NR
Karademir 2015^81^ N=115 | Istanbul, Turkey Timeframe NR | 1-year all-cause mortality rate for ≤5 days vs >5 days P=0.5 | NR
Meessen, 2014^75^ N=828 | Varese, Italy 2009 | 2y all-cause mortality rate for ≤48h vs >48h^*^: (data not reported) P>0.05 | NR
Hip fracture (non-elderly)
Clague, 2002^69^ N=462 | 1 UK hospital, 1996-1999 | In-hospital mortality rate for ≤24h vs >24h (data not reported) P>0.05 90d mortality rate for ≤24h vs >24h (data not reported) P>0.05 | NR
Griffiths, 2013^70^ N=60 | 1 UK hospital | 30d mortality rate for ≤72h vs >72h (data not reported) P=0.2 | 30d complication rate for ≤72h vs >72h (Data not reported) P=0.008
Lund, 2014^73^ N=6,143 | Danish National Registry of Patients | 1-year all-cause mortality rate 0-12h: HR 1.00 (reference) 12-24h: HR 0.89 (95% CI 0.78 to 1.01) 24-48h: HR 1.03 (95% CI 0.91 to 1.17) 48-72h: HR 1.02 (95% CI 0.84 to 1.24) 72-96h: HR 1.10 (95% CI 0.83 to 1.44) >96h: HR 1.05 (95% CI 0.81 to 1.36) | NR
Lurati-Buse 2014^66^ N=60 | 2 hospitals in Canada and 1 in India 2011-2012 | 30-day mortality rate for accelerated care (shorter wait time) and standard care (longer wait time) OR 0.22 (95% CI 0.02 to 2.14)^**^ | NR
Ryan, 2015^77^ N=2,121,215 | US National inpatient sample 2000-2009 | In-hospital mortality rate^*^ 0-day: OR 1 (reference) 1-day: OR 1.02 (95% CI 0.96-1.09) 2-day: OR 1.14 (95% CI 1.06-1.23) ≥3-days: OR 1.34 (95% CI 1.23-1.46) | In-hospital complication rate^*^ 0-day: OR 1 (reference) 1-day: OR 1.09 (95% CI 1.06-1.12) 2-day: OR 1.33 (95% CI 1.29-1.39) ≥3-days: OR 2.08 (95% CI 2.00-2.16)

Abbreviations: OR odds ratio; HR=hazard ratio; RR=relative risk; h=hours; y=year; NR=not reported

* =adjusted for confounding variables;

** ESP-calculated

In patients undergoing emergent ankle fracture repair, delayed surgery (>24 hours, up to 14 days) significantly increased risk of wound complications in 6 of 11 studies.^63,79^ Although we did not formally rate the quality of these studies in this lower-priority population, the strength of evidence is likely very low because they were small – sample sizes < 100 – and did not control for potential confounding.^63,79^

In patients with multiple fractures, one retrospective cohort of 1005 patients at a single Level 1 trauma center provides low-strength evidence that performing fixation of unstable axial fractures within 24 hours of the trauma significantly reduced risk of complications.^80^ The applicability of this evidence to the non-emergent surgeries of interest is likely low.

#### Surgical Standards

Low ‘total care quality’ scores moderately increased risk of 30-day mortality and complications following CABG (OR range, 1.51 to 1.91; low strength of evidence; 2 studies).^10,12^ The ‘total care quality’ score ranges from 0 to 5-6, where 0 means no process measures were met and 5-6 is the total number of process measures used. Adherence to individual cardiac surgery process measures was generally not associated with reduced mortality and complications, except that violation of an antibiotic prophylaxis guideline-based protocol increased risk of mortality and surgical site infections (OR range 7.03 to 10.16; low strength of evidence; one study).^14^ For orthopedic surgery, among 4 studies the best studies provided low-strength evidence that a composite quality score of CMS NQF measures, and adherence to individual SCIP measures were not valid indicators of either mortality or complications.^15,16^

##### Cardiac Surgery

In cardiac surgery populations, composite scores of ‘total care quality’ (ie, total number of individual process measures missed) may better predict patient health outcomes than adherence to an individual process measure (Table 3). Two good-quality studies examined adherence to surgical quality measures in cardiac surgery using a composite quality score based on the total number of recommended NQF or SCIP measures achieved.^10,12^ One study of 81,289 CABG patients found increased 30-day mortality with increasing proportion of patients who failed to receive recommended Surgical Care Improvement Project (SCIP) measures.^10^ This study found no association between the number of missed measures and readmission.^10^ Another study of 2,218 CABG patients found higher odds of several complications for patients with a low quality score based on the number of National Quality Forum (NQF) process measures achieved (range 0 to 5, 5 = high quality care, all other scores = low quality care).^12^

Table 3 Adherence to Surgical Standards and Patient Outcomes in Cardiac Surgery

Author, Year N | Setting | Measure Details | Findings
Composite Measure
Auerbach, 2009^10^ N=81,289 | 164 US hospitals in Perspective database, 2003-2005 | Proportion of patients who failed to receive recommended SCIP measures (# of missed measures). | Mortality: 3 missed measures vs none missed OR 1.54 (95 % CI 1.20 to 1.98), 4 or more missed measures vs none missed OR 1.63 (95% CI 1.24 to 2.15) Readmissions: 4 or more missed vs none OR 1.02 (95% CI 0.93 to 1.13)
Kurlansky, 2012^12^ N=2,218 | 5 cardiac surgery programs associated with Columbia University, 2007-2009 | Total quality score (0 to 5) based on number of NQF process measures achieved. 5=high-quality care, all other scores=low-quality care | Complications: Low vs high quality score: stroke OR 1.51 (95% CI 1.18 to 1.93), reoperation OR 1.65 (95% CI 1.25 to 2.16), prolonged ventilation OR 1.54 (95% CI 1.21 to 1.96), and renal failure OR 1.91 (95% CI 1.09 to 3.35). No association with sternal infection.
Individual Measure
Brinkman, 2014^11^ N=506,110 | 1,107 centers in STS database, 2008-2012 | Adherence to use of preoperative beta-blocker within 24 hours preceding surgery (NQF). | Mortality: Beta-blocker use vs no use: OR 0.96 (95% CI 0.88 to 1.04) Complications: Beta-blocker use vs no use: atrial fibrillation OR 1.09 (95 % CI 1.06 to 1.12). No association with other complications (stroke, prolonged ventilation, reoperation, renal failure).
Cotogoni, 2017^14^ | 1 hospital in Turin, Italy, Timeframe NR | Adherence to prophylactic vancomycin administration timing protocol | Mortality: Association of increased mortality with protocol violation: OR 10.16 (95% CI 2.48 to 41.58) Complications: Association of increased SSI with protocol violation: OR 7.03 (95% CI 3.41 to 14.52)
LaPar, 2014^72^ N=1,703 | University of Virginia Hospital, 2010-2012 | Adherence to SCIP measure of maintenance of 6am blood glucose levels on post-operative days 1 and 2 | Mortality: SCIP measure failure: OR 1.49 (95% CI 0.54 to 4.09) Complications: SCIP measure failure: major morbidity OR 1.51 (95% CI 0.86 to 2.67), major sternal complications OR 1.58 (95% CI 0.18 to 13.7).
McDonnell, 2013^74^ N=832 | Boston University Medical Center, 2008-2011 | Adherence to SCIP measure of maintenance of 6am blood glucose levels on post-operative days 1 and 2 | Mortality: SCIP measure failure 1.8% vs SCIP compliant 1.7%, P=0.55 Complications: No association with complications for MI, stroke, deep sternal infection, multisystem failure, or atrial fibrillation

Abbreviations: STS=Society of Thoracic Surgeons; SCIP=Surgical Care Improvement Project; NQF=National Quality Forum; MI=myocardial infarction; OR=odds ratio; SSI=Surgical Site Infection

Among individual cardiac surgery process measures studied (Table 3),^11,13,14,74^ only adherence to an antibiotic prophylaxis guideline-based protocol improved outcomes.^14^ Initiating the first skin incision for elective cardiac surgery before the end of vancomycin infusion was associated with large increased risk of surgical site infection rates and mortality in-hospital or within 30 days in a prospective study of 741 adults from a single center in a 1200-bed tertiary care university hospital in Italy.^14^ Three other studies investigated adherence or lack of adherence to a single measure, pre-operative beta-blocker use^11^ and blood glucose maintenance.^13,74^ These studies found no association between adherence to surgical standards and 30-day mortality or complications.^11,13,74^ An additional pre-post study found decreased infection rates after implementation of an enhanced targeted infection control program, including education, improved hygeiene, MRSA screening, care pathways, and antimicrobial surgical prophlaxis. However, this study was limited by no control for potential confounders and did not specifically assess adherence to the antimicrobial surgical prophylaxis.^68^ These results indicate that composite measures or ‘all or none’ measures of surgical standard adherence may better measure overall quality of care, as they evaluate the overall system of care for several processes. In contrast, adherence to single surgical standards may be influenced by the practices of single team members.^83^

These studies were generally of good quality, using rigorous methods to adjust for potential confounding, and 3 out of the 7 studies were multicenter.^10-12^ The exceptions were 2 studies that inadequately addressed potential confounding factors, either only controlling for a single factor or not controlling for any potential confounders.^68,74^ As most of these studies were in CABG patients – which is a well-developed and frequently performed surgery – these results might not be applicable to other types of cardiac surgery.^12^

##### Orthopedic Surgery

Adherence to orthopedic surgical standards was consistently not associated with health outcomes in all of 4 included studies.^15,16,71,76^ One study examined hospital quality in hip or knee replacement surgery in 4 performance tiers based on a composite quality score of CMS NQF measures.^15^ This composite score included process measures (adherence to antibiotic prophylaxis standards, etc), as well as outcome measures (readmission avoidance, etc), but the differences in the top 20% of hospitals based on performance and the remaining hospitals were driven by the process measures. There was no significant difference in mortality across hospital tiers, but a trend toward a higher rate of mortality in tier 4 hospitals, classified as the bottom 50% of performance (r = 0.116, P = 0.088). Additionally, complication rates did not differ significantly by hospital tier, and readmission avoidance did not differ significantly between the top 20% of hospitals and all other hospitals.^15^ Another study examined level of compliance to SCIP measures (eg, ‘highly compliant’ indicated greater than median level of compliance) and complications among hip arthroplasties at 128 New York state hospitals.^16^ This study found no association of adherence to the individual SCIP measures and post-operative infection rates or hospital-level SSI rates, with the exception of increased infection rates with higher adherence to the SCIP “VTE-2” prevention measure, which measures the percentage of hospital patients who received appropriate venous thromboembolism prophylaxis within 24 hours prior to surgery to 24 hours after surgery (post-operative infection: OR 1.50, 95% CI 1.07 to 2.12; hospital-level SSI: OR 1.91, 95% CI 1.31 to 2.79).

Two studies examined rates of complications (SSI) before and after implementation of surgical standards.^71,76^ One poor-quality study with no adjustment for potential confounders examined adherence to surgical antibiotic prophylaxis (SAP) among 6 hospitals in Korea before and after implementation of a national hospital evaluation program.^71^ Although adherence to SAP improved (P < 0.01), there were no significant changes in SSI rate for hip or knee arthroplasty or spine surgery. Another poor-quality study with minimal adjustment for confounders examined SSI rates before and after implementation of SCIP in a single institute in the US.^76^ After implementation, the SCIP rate adherence was more than 98%. Multivariate analysis (adjusting for surgery and SCIP factors) showed that SCIP adherence was associated with increased risk of superficial infection (estimate: -4.45, P < 0.001), and pulmonary embolism (estimate: 0.34, P < 0.001), but there were no significant associations with deep infection (P = 0.46) or deep vein thrombosis (P = 0.51). These findings suggest that adherence to surgical standards may not predict surgical complication rates. However, these studies are limited by lack of a concurrent control, minimal or no adjustment for potential confounding variables, and limited information on processes prior to implementation of the surgical standard programs.

#### Postoperative Plan of Care

In some cases, community providers will offer episode-of-care services (‘bundles of care’) that include outpatient preoperative care, inpatient care, and postoperative rehabilitation services. We did not find any studies of performance measures collected in the inpatient setting that directly assessed the quality of postoperative bundles of care.

We did not evaluate the effectiveness of strategies to reduce readmission rates through better coordination and planning of post-discharge care. Nevertheless, if an indicator such as readmission rate is used, it may be important to assess whether the provider applies strategies to prevent or detect post-discharge complications early.^84^ Some believe that scheduling a timely post-hospital visit while the patient is still in the hospital may be helpful because readmissions for complications often occur before the first follow-up visit.^85^ The clarity of discharge instructions, better communication at the time of discharge, follow-up nursing calls, and communication between inpatient and outpatient rehabilitation services are also considered potentially useful.^86^

We are aware of additional studies that investigate the use of “clinical or care pathways” on patient health outcomes.^87^ However, these studies are complex system-level implementation interventions designed to encourage use of evidence-based processes (eg, flowcharts, patient education materials, checklists, mapping out of sequences) that are used for quality improvement. Although these studies measure use of these support systems, they typically don't measure adherence to the actual bundles of postoperative care standards, and this makes it difficult to determine which factors influence outcomes. As our goal is to assess measures collected in the inpatient setting that directly assessed the quality of postoperative bundles of care, we did not evaluate this broader “clinical or care pathway” literature.

### KEY QUESTION 1B Are reduced readmission rates associated with improved early survival and long-term outcomes?

For CABG surgery, the 3 most rigorous studies^3,4,7^ found a modest but consistent significant association between 30-day readmissions and 30-day mortality (r range, 0.32 to 0.38; OR 1.14; moderate strength of evidence), but not with process measures. For hip replacement, there was a correlation between 30-day readmission and mortality (one study, low strength of evidence),^7^ but the association between readmission rates and process measures was inconsistent. Among 2 studies,^7,9^ readmission rates were only correlated with aggregate process compliance measures in the study with a broader orthopedic population that had wider variation in readmission rates.^9^

#### Coronary Artery Bypass Grafting (CABG)

##### 30-day Readmission Association with 30-day Mortality

Among 4 retrospective cohort studies, the 3 most rigorous studies^3,4,7^ found a modest but consistent significant association between 30-day readmissions and 30-day mortality (r range, 0.32 to 0.38; OR 1.14) (Table 4).^3-5,7^ The most broadly applicable data comes from the only study using a national data source.^7^ Others used data from the states of New York,^3,4^ or California.^5^ All used risk-adjusted readmission and mortality variables, but each used slightly different analytic approaches. For example, the national Medicare data study used a standardized readmission rate whereby they calculated the composite readmission rate for each hospital by averaging the observed-to-expected (O/E) readmission ratios for the 6 procedures for the hospital and weighting each ratio on the basis of the number of cases for that procedure. Then they compared the standardized risk-adjusted readmission rates between hospitals in the highest quartile for mortality to the lowest quartile.^7^ In contrast, the California study observed trends in discordance among hospitals that were O/E outliers (95% CI excluded 1.0) for mortality or readmission and not both (“discordant”).^5^ Regardless, 3 of the 4 studies found a significant association between 30-day readmission and 30-day mortality.^3,4,7^ We have lower confidence in the validity of the outlier study, however, due to their use of weaker statistical methods.^5^ Authors of the outlier study noted that most hospitals had concordant O/E readmission and mortality rates, which “points to the likely existence of some association between readmission and mortality rates.” But, they based their conclusions on the trends they observed among the outliers. Among outliers, 85% were “discordant” for readmission and mortality (for example, hospitals with high readmission and low mortality). This approach may exaggerate the significance of the outliers as it neglects the statistical effects among the data as a whole, which was predominantly comprised of concordant hospitals.

Table 4 30-day Readmission in Coronary Artery Bypass Grafting (CABG) Patients

Author, Year N | Setting | Measure Details | Findings
Hannan, 2011^4^ N=33,936 | NY State Cardiac Surgery Reporting System, 2005-2007 | Risk-adjusted hospital 30-day readmissions | Mortality: Association with risk-adjusted 30-day hospital mortality rates (r=0.32, P=0.047), and with hospital risk-adjusted mortality rate in highest tertile (r=0.38, P=0.03)
Hannan, 2003^3^ N=16,325 | NY State Cardiac Surgery Reporting System, 1999 | Risk-adjusted hospital 30-day readmissions | Mortality: No statistically significant association with overall hospital risk-adjusted mortality rate (r=0.09, P=0.64), but association with hospital RAMR in highest tertile, OR 1.14 (95% CI 1.03 to 1.25)
Parina, 2015^5^ N=296,063 | 299 hospitals in CA, 1995-2009 | Risk-adjusted 30-day readmission. Outliers based on 95% CIs of O/E ratio excluding 1; classified ‘discordant’ if readmission and mortality rates were not both high or both low. | Mortality: No association: among outliers 85% were discordant, CABG discordance rate: 78.3%
Tsai, 2013^7^ N=153,496 | National Medicare data, 2009-2010 | Hospital-level composite of procedure-specific risk-adjusted 30-day readmission rates | Mortality: Readmission rate in highest mortality quartile=18.1% vs in lowest to third quartile=17.3%-17.4%; P=0.013. Process Measures: HQA surgical score. No statistically significant difference in readmission with HQA surgical score quartile (P=0.751)

Abbreviations: OR=odds ratio; O/E=observed/expected; CABG=coronary artery bypass grafting; HQA=Hospital Quality Alliance

##### Readmission Associated with 100-day Mortality

One retrospective cohort study evaluated the association between longer-term readmission rates (within 100 days) and 30-day mortality among 14 hospitals in Israel in 1994.^8^ Although this study found that high mortality-ranked hospitals had higher rates of readmission (OR 1.34, P = 0.003), this finding likely has low relevance to contemporary care in the US.

##### Readmission Associated with Process Measures

Among 3 retrospective cohort studies that used diverse process measure assessment,^6,7,9^ none found a significant association with readmission. Process measure compliance assessment ranged widely and included (1) peer-reviewing charts based on a set of Health Care Financing Administration (HCFA)-specified generic quality screens to evaluate care provided as acceptable or problematic,^6^ (2) evaluating compliance with surgery-specific SCIP process measures (overall compliance with all 9 process measures, or number of compliant events divided by the number of opportunities to provide recommended care (ie, non-smoker not eligible for smoking sessation counseling),^9^ and (3) comparing hospitals in the highest and lowest decile of the Hospital Quality Alliance (HQA) surgical score (composite of 9 process measures).^7^ Some authors speculated that the lack of association may be because these process measures represent just a fraction of the entire spectrum of care, and do not capture other important features such as care coordination at the time of discharge.^9^

##### Readmission associated with composite process/outcome measures

Lower readmission rates were weakly correlated (Spearman rank correlation= –0.154) with higher composite scores (including mortality, major morbidity, internal mammary artery graft, and NQF-endorsed perioperative medications) in a secondary subgroup analysis of 827 CMS CABG providers from the 2010 STS database.^88^ However, we have insufficient information to determine the strength of this evidence as this finding was only very briefly noted in the discussion section of the main study, which was devoted to the development of the readmission measure. No other information about the methodology were provided in the publication or via author request.

#### Orthopedic

##### 30-day Readmission Association with 30-day Mortality

One Medicare study (described above)^7^ evaluated the association between 30-day readmission and 30-day mortality in an orthopedic population. Among 206,175 hip replacements from National Medicare data from 2009 to 2010, there were significantly higher readmissions among hospitals in the highest quartile for mortality compared to the lowest quartile (11.7% vs 10.2%; P < 0.001).

##### 30-day Readmission Association with Process Measures

An evaluation of a broad population of fee-for-service Medicare patients from the Hospital Inpatient Quality Reporting Program who underwent any orthopedic procedure in 2007 found significant correlations between process performance scores and risk-standardized all-cause 30-day readmission rates.^9^ Correlations were -0.06 (P = 0.003) for the OM and -0.05 (P = 0.03) for the ACM for orthopedic surgery overall. Median hospital performance was 92.9% (InterQuartile Range [IQR], 88.3% to 95.9%) for the OM and 71.1% (IQR, 55.8% to 82.6%) for the ACM and median risk-standardized readmission rates were 9.1% (6.9% to 12.7% across 10^th^ to 90% percentiles). The 2 aggregate compliance measures are described above. In a narrower population of hip replacements with less variability in readmission rates across hospitals, there was no significant difference in risk-adjusted 30-day readmission across quartiles of Hospital Quality Alliance (HQA) surgical score (lowest = 11.2%, 2^nd^ quartile = 11.0%, 3^rd^ quartile = 10.7%, and highest = 10.8%).^7^ Both studies were of similar size and methodological quality, with only few and minor limitations. Therefore, it is likely that the significant variation in their population and process measures led to their different findings.

### KEY QUESTION 1C Is improved early survival associated with improved long-term outcomes?

#### Correlation Between In-Hospital All-Cause Mortality and Preventable In-Hospital Mortality

No significant correlation was found between all-cause, risk-adjusted in-hospital mortality rates and preventable in-hospital deaths based on a retrospective analysis of 347 randomly selected deaths following CABG at 9 institutions in Ontario between 1998 and 2003 (Spearman coefficient, -0.42, P = 0.26).^1^ Preventability was rated by 2 experienced, blinded surgeons who used a standardized tool to identify preventable deaths from nurse-abstracted chart summaries. Despite that the deaths came from high-volume hospitals with a long-standing public reporting, 32% were judged preventable. Deviations in perioperative management standards were attributed as the reason for a majority of the preventable deaths. The preventability criteria, low level of inter-rater agreement (k range, 0.16 to 0.26), and reliance on retrospective chart review are major deficiencies that reduce our confidence in these findings, however. Preventability was scored using a subjective 7-point Likert scale, with ratings of “none”, “slight”, “modest”, “<50 to 50”, “<50 to 50 but close call”, “strong” and “certain”. Although an advantage of a Likert scale is that it can be quick and efficient, detection of preventability could have been strengthened by use of a more objective set of criteria representing specific standards of care.

#### Correlation Between 30-day Mortality and 1-year Survival

Deciles of 30-day mortality were associated with significantly different rates of survival at 365 days following VASQIP-assessed cardiac (N = 10,042) and orthopedic (N = 60,515) surgeries performed within the VHA from October 1, 2011 to September 30, 2013.^2^ For cardiac surgery overall, the highest 30-day mortality risk decile had a significantly lower risk of 365-day survival than other risk deciles (approximately, 81% vs 91%-98%). Findings were similar for orthopedic surgery overall, with a 365-day survival probability of 77% for the highest 30-day risk decile compared with 96% to 99% for the other risk deciles. Although the methodology of this study was strong, as this study was conducted within the VHA, it is unclear how applicable these findings are to community hospitals with varying levels of quality improvement programs in place.

### KEY QUESTION 2 MEASUREMENT BURDEN

Performance measures vary in their burden of data collection and reporting. Measurement burden is an important consideration, as successful implementation depends on realistic attainability.^89^ However, we found no studies that formally evaluated comparative measurement burden. In general, measures such as mortality and readmission are often more appealing because they are the most feasible to collect as they are already being regularly collected and reported for internal and public quality improvement initiatives. However, they have the potential disadvantages of insufficiently discriminating quality-sensitive, preventable events. However, determining preventability would require committee or chart audits and would likely be resource-prohibitive.^1^ Also, risk-adjustment is necessary, but administrative databases may not capture all relevant variables^6^ and there is little consensus on which methods to use.^32^ Surgical standard adherence, postoperative plan of care, and wait times are likely associated with greater measurement burden. This is because (1) there is more variability in whether any are measured and, if so, which ones; (2) if tracked electronically, sources may have low reliability;^10^ and (3) they may require additional staff to set up and implement,^74^ possibly through chart review.^85^ Additionally, wait times may present additional barriers to collection. Different wait time standards may be needed for different subgroups, as safe wait times may vary by patient subgroups and surgery types.^69^ There is a risk that clinically-justified longer wait times may be penalized if medical records and/or databases lack a mechanism for recording supporting documentation. For example, frailer patients may be more likely to be delayed due to need for stabilization prior to surgery.^60,62^

### KEY QUESTION 3 UNINTENDED EFFECTS

Concern has been expressed that focus on specific performance measures may result in unintended effects such as gaming, risk-based patient selection, appropriateness of care, changes in disparities, and spillover effects. For example, 30-day readmission may be gamed by delaying readmission to 31 days instead of 30 days.^90^ Or for 30-day mortality, intensive care management and end-of-life care may be modified against the patient's best interest to extend death beyond 30 days.^2^ Also, adherence to some surgical standards is debated for some patients (ie, beta-blockers for specific cases of off-pump revascularization) and adherence may harm those patients.^11^ For wait times, as demonstrated in the Phoenix VA Medical Center in 2014, use of a 2-week wait time performance measure – regardless of clinical need, facility capacity, and other accommodations such as secure messaging or telehealth – resulted in the manipulation of scheduling practices in order to meet performance goals.^48^ Finally, an unintended effect of using any of these performance measures for selective contracting with Choice providers is that it may result in an undersupply of providers, which could diminish Choice's intended effect on reducing Veterans' wait times.

Evaluation of such unintended consequences has largely been lacking. Recent systematic reviews of using various performance measures in value-based payment programs found very limited evidence assessing the extent of gaming, inconsistent evidence of effects on health disparities, and only some evidence of both positive and negative effects on unincentivized measures.^91^ The only additional evidence we found was from a recent VHA study that examined surgical mortality between postoperative days 25 and 35 and found no evidence of delayed mortality within the highest readmission decile.^2^

## SUMMARY AND DISCUSSION

Health care performance measurement is the regular collection of data on health care processes, efficiency, experiences, and/or patient outcomes to determine the degree to which providers and health systems are providing health services that “increase the likelihood of desired health outcomes and are consistent with current professional knowledge.”^26^ Development of performance measures has proliferated over the past 2 decades, resulting in a wide range of individual measures of both direct and indirect indications of health outcomes, as well as comprehensive, multidimensional composite measures meant to broadly encapsulate the overall quality of care by combining information from multiple individual outcome and process performance measures. No gold standard exists and different organizations use different sets for different purposes (eg, quality improvement, competency assessment, criteria for network selection, etc). One challenge in selecting performance measures for determining Choice community provider eligibility is that there are a large number of measures meant as indirect indicators of health outcomes (eg, readmissions, process measures, etc) but uncertainty about their actual association with health outcomes (eg, mortality, quality of life, or function). The purpose of our review was to determine whether certain performance measures that are indirect indicators of health outcomes are associated with health outcomes and compare their measurement burden and unintended consequences.

The key findings of this review are:

1. Although 30-day mortality is the most commonly reported direct measure of a health outcome, its singular use has been recently criticized as unintentionally failing to accommodate patients who refuse aggressive treatments, neglecting the impact of postoperative complications on longer-term survival, and promoting manipulation of patient care to achieve better statistics.^30^ However, it is encouraging that the usefulness of 30-day mortality as a surrogate for longer-term survival was reinforced in a recent VHA study, which also found no evidence of gaming to meet a 30-day metric. It may also be feasible to collect from hospitals who are already mandated reporters through their participation in the Hospital Inpatient Quality Reporting Program.
2. Thirty-day readmission meets several of the criteria for performance measures for selecting community providers. Thirty-day readmission rates would likely be feasible to collect as all community Medicare providers are already mandated to collect this information. For CABG, it is consistently (although modestly) associated with 30-day mortality (eg, R range, 0.32 to 0.38; OR 1.14). For hip replacement, evidence is weaker but also points towards 30-day readmission as being a valid indicator of 30-day mortality. However, 30-day readmission has several potential limitations that are discussed in detail below.
3. Adherence to standardized CABG wait time protocols, a set of cardiac surgery process measures, and a specific cardiac surgery antibiotic prophylaxis guideline-based protocol, but not other studied individual process measures, has decreased the likelihood of mortality and complications in cardiac surgery. For orthopedic surgery, a composite quality score of CMS NQF measures was not a valid indicator of either mortality or complications. We did not find any studies of performance measures collected in the inpatient setting that directly assessed the quality of postoperative bundles of care.
4. Public reporting is an implementation factor that may mediate or moderate the association of performance measures with health outcomes. Discussions with experienced pay-for-performance researchers^89^ indicated that public reporting itself may be a strong motivator for hospital administrators and individual providers alike to improve quality. Decision-makers may consider determining eligibility of Choice community providers based on their participation in a public reporting program that involves periodic auditing. This could have the added benefit of demonstrating that providers could produce reliable measures.

### Limitations of 30-day Readmission Rates

Although evidence suggests 30-day readmission is a moderately valid indicator of surgical quality and is likely reasonably feasible to assess, its limitations and potential consequences must be considered. A systematic overview of methodological aspects of readmission rates^32^ and several editorials have provided detailed evaluations of the limitations of 30-day readmissions.^28,31,43,44,92,93^ The most common criticism about all-cause readmission is that it is insensitive to true quality of care issues because only a minority are avoidable (∼27%),^94^ with some being planned, and the majority being outside of the hospitals' control and likely driven by factors such as mental illness, poor social support, and poor community outpatient resources.^28^ A proposed solution is to limit analyses to preventable/avoidable readmission.^32^ However, as doing so would require additional resources in the form of independent expert judgment, this is likely technically infeasible to implement. Also, our review identified evidence supporting all-cause readmission as a valid indicator of quality in the form of 30-day mortality. A second common criticism of readmission rates is that their validity is limited by variability in and lack of consensus on the methods used to adjust for case-mix. Although risk prediction models consistently adjust for some variety of patient-, surgical-, and hospital-level variables, current evidence provides limited guidance on which specific variables should be included because studies have been highly heterogenous in their methodology, patient groups, and considered variables, and have found different factors increased risk of readmission. One of the key controversies in the ongoing dialogue about risk adjustment methods is over whether to adjust for socioeconomic status (SES). CMS and NQF have argued not to include adjustment for SES in readmission risk adjustment, because factors such as SES, race, and gender may be associated with inequalities in care and these inequalities may be obscured if these factors are included in risk models. Others argue that differences in outcomes by SES may in fact be due to poorer living conditions, lack of support, and/or poorer nutrition, for which hospitals should not be accountable.^95^Although there is much debate around this issue, it is unclear if adding SES to risk adjustment models would change actual hospital rankings.^96^ Third, although not necessarily unique to readmissions, the lack of widely acceptable thresholds for minimum performance may be a barrier to widespread use.^44^ Although thresholds must be set, there is an inherent risk of misclassifying providers or otherwise unfairly excluding providers with lower performance for idiosyncratic reasons. Finally, concern has been expressed that focus on readmission may result in neglect of other important aspects of care quality and/or gaming to achieve lower rates at the expense of patient care (ie, admitted at 31 days instead of 30 days). Although evaluation of such unintended consequences is largely lacking, a recent VHA study that examined surgical mortality between postoperative days 25 and 35 by risk decile showed no evidence of delayed mortality within the highest readmission decile.^2^ Also, as participation in the Choice network would be voluntary and not universally imposed on the community at large, this may minimize potential unintended consequences of readmission. However, adding performance measures to Choice network participation eligibility requirements may be seen as an additional barrier for community providers and may perpetuate the current network inadequacy challenges.^21^

### General Limitations

The main general limitations of the evidence included understudied measures, methodological features, and applicability. With few exceptions,^1,2^ evidence on the validity of the surgical performance measures evaluated in this review has largely neglected evaluating their association with the most patient-centered outcomes of long-term health outcomes. Also, although care coordination and follow-up care interventions have been shown to impact readmissions and there has been a call for development of innovative care transitions and postoperative care plan measures, other than one study of time to follow-up appointment timing (before or after the recommended 3 weeks),^85^ evidence is lacking on potential postoperative plan of care measures such as presence of pre-discharge assessment and ensuring every patient is scheduled for a follow-up visit. Also, as mentioned above, although there is much concern about the unintended consequences of using performance measures for various purposes, little research has been done in this area. Methodologically, the main strengths of these studies are that the reliability of the data sources was generally high, in that they were from established and regularly audited quality improvement databases, adequacy of adjustment for potential confounding was at least moderate, in that most at least adjusted for patient-level factors, and they likely had adequate statistical power with a median sample size of 2,218 (range 47 to 2,121,215). The main methodological weaknesses were that all but 4 were retrospective, none was able to capture events that may have occurred at hospitals other than the index hospital, and most were based on administrative databases that did not include information not captured by billing codes, such as disease severity. Although a majority of studies were within the US and multicenter, applicability is still limited because most focused on CABG and over half involved samples more than a decade old.

The main limitations of our review methods include (1) our literature search, (2) our focused scope, and (3) our use of sequential instead of independent dual assessment. For our literature search, although we searched 5 databases and other sources and used a comprehensive search strategy, the inconsistent terminology used in literature on performance measures and quality of care may have increased our risk of missing relevant studies. Second, to meet our condensed timeframe we focused our scope to the highest-priority populations and measures of the Office of Community Care. However, this limits the applicability of our findings to other populations and measures of interest. Third, although sequential dual review is a widely used method, its comparison to independent dual review has not yet been empirically studied and may have increased the risk of error and bias.

### Future Research

To improve evidence about the validity of performance measures as indicators of surgical quality and increase its applicability to broader populations, high priorities for future research include (1) prospective evaluation of a broader array of modern surgical populations; (2) improving consensus on case-mix adjustment methods, which could be in the forms of an updated systematic review, as well as a new primary study that compares the use of various adjustment methods; (3) evaluation of associations with longer-term patient-important outcomes; (4) evaluation of unintended consequences including gaming and risk-based patient selection, evaluation of appropriateness of care, changes in disparities, and spillover effects;^97^ and (5) evaluation of postoperative plan of care measures such as presence of pre-discharge assessment and ensuring every patient is scheduled for a follow-up visit.

As the reason for this review was to identify performance measures that are valid indicators of quality, for implementation in selective contracting with Choice community providers to improve quality of care for Veterans, implementation should be accompanied by plans not only to extend the evidence on validity, but also to evaluate the effectiveness of the implementation, including how selective contracting is affecting community providers' experience. For the purposes of this review, although the primary interest in the validity of performance measures is in their use for selective contracting, likely they will continue to be used to monitor Choice patient outcomes as well for general quality improvement. Currently, data is routinely collected from community providers using a one-page form that is scanned into the Veterans' charts. However, this process does not permit systematic electronic querying for data analysis. To improve capabilities to monitor Veterans' outcomes in the community and compare to care within VHA, VA Secretary Shulkin and others have called for creation of data standards and standardized electronic data systems that would better permit aggregation of data across sites.^19,44^

### Implications for Policy and Implementation

Possible minimum requirements for Choice providers include acceptable performance on national rankings, compatible operational infrastructure, and ability to comply with an agreed-upon wait time threshold. In addition to these minimum requirements, the Office of Community Care could consider the added value of the performance measures that this review has identified as being indicators of desirable health outcomes. These include the single measures of 30-day mortality, a direct health outcome measure, and/or 30-day readmission, the indirect measure with the strongest association with mortality – both of which are commonly measured by surgery programs. Another option is to consider use of a composite performance measure that includes mortality, readmission, and other process measures – such as STS's composite CABG measure. We also recommend use of public reporting program participation and measures of efficiency as additional considerations for Choice community provider minimum standards. However, an unintended effect of stricter performance measure-based criteria for selective contracting with Choice providers may be an undersupply of providers, which could diminish Choice's effect on reducing Veterans' wait times.

An alternative to using individual performance measures that are direct or indirect indicators of health outcomes is to use a composite performance measure^36^ that includes mortality, readmission, and other process measures – such as STS's composite CABG measure. Composite performance measures are meant to broadly encapsulate the overall quality of care by combining information from multiple individual outcome and process performance measures into a single, comprehensive, multidimensional measure. An advantage of composite measures is that they can reduce data burden by translating information on a broad range of indicators that may not otherwise be possible to track. However, as with any composite performance measure, including intelligence quotients, there are a few challenges to consider. Use of a single composite measure may lose important detail on variation in performance across individual component measures. For example, an intermediate score on a composite measure may reflect excellent performance on some measures and below-average on others. Also, all users' unique interests, values, and preferences may not be reflected by the subjective relative weighting of different components in scoring composite measures. Ideally, choice of a composite performance measure should consider the strength of the association between its components and health outcomes, the transparency and comprehensibility of its inputs and rules, the regularity of updating to maintain clinical relevance as new information becomes available, and its reliability and validity. The Office of Community Care could consider use of a composite measure as a highly feasible and comprehensive approach to determine eligibility of community providers if they determined that the potential advantages of a composite measure outweighed its challenges and identified a rigorously developed and validated composite measure that is widely accepted and used.

We examined whether performance measures meant as indirect indicators of health outcomes are related to health outcomes and whether they are difficult (feasible) to measure, but not whether potential Choice community providers collect and report valid data. To apply performance measurement-based selective contracting, VA must be able to determine whether the providers' data are reliably measured. Accordingly, in addition to selecting providers based on meeting thresholds for acceptable 30-day readmission and 30-day mortality rates, decision-makers may also require Choice community providers to participate in a public reporting program that involves periodic auditing, including publically available claims databases such as CMS, commercial comprehensive clinical databases such as Vizient, Crimson, Premier, etcetera, or specialty registries such as STS, ACC, or NSQUIP. This would ensure the reliability of Choice community providers' performance measures, and the participation in public reporting itself may also be a strong motivator for quality improvement. Preferable characteristics of performance reporting programs include (1) use of defined populations, (2) longer time in operation, (3) transparency through providing data that identifies specific providers/surgical centers, and (4) evaluation across the continuum of care.

Also, although we did not evaluate measures such as length of stay and patient visits per physician per month, we suggest decision-makers consider the usefulness of such efficiency measures as a supplement to indicators of patient outcomes. For providers that meet minimum standards on direct or indirect health outcome measures, choosing more efficient providers could benefit national efforts to improve health care value.

### CONCLUSIONS

Among performance measures meant as indirect indicators of health outcomes, 30-day readmission is the strongest indicator of 30-day mortality for CABG and for hip replacement and is feasible to measure. Its use for selecting Choice providers is reasonable, but its potential limitations must be considered. Contrary to recent criticism, the 30-day mortality measure is likely a valid surrogate for long-term survival, with a lower than expected risk of gaming. Use of a robust and widely used composite measure of direct and indirect indicators of health outcomes may also be a highly feasible and comprehensive approach to determining eligibility of Choice providers. Also, we recommend use of public reporting program participation and measures of efficiency as additional considerations for Choice community provider minimum standards. An unintended effect of using performance measures as criteria for selecting providers in general is that it may result in an undersupply of Choice providers that could diminish Choice's intended effect of reducing Veterans' wait times.

## REFERENCES

1 Guru V, Tu JV, Etchells E, . Relationship between preventability of death after coronary artery bypass graft surgery and all-cause risk-adjusted mortality rates. Circulation. 2008;117(23):2969-2976.18541752
2 Smith T, Li X, Nylander W, Gunnar W. Thirty-day postoperative mortality risk estimates and 1-year survival in Veterans Health Administration surgery patients. JAMA Surgery. 2016;151(5):417-422.26747331
3 Hannan EL, Racz MJ, Walford G, . Predictors of readmission for complications of coronary artery bypass graft surgery. JAMA. 2003;290(6):773-780.12915430
4 Hannan EL, Zhong Y, Lahey SJ, et al. 30-day readmissions after coronary artery bypass graft surgery in New York State. Jacc: Cardiovascular Interventions. 2011;4(5):569-576.21596331
5 Parina RP, Chang DC, Rose JA, Talamini MA. Is a low readmission rate indicative of a good hospital? Journal of the American College of Surgeons. 2015;220(2):169-176.25529903
6 Thomas JW. Does risk-adjusted readmission rate provide valid information on hospital quality? Inquiry. Fall 1996;33(3):258-270.8883460
7 Tsai TC, Joynt KE, Orav EJ, Gawande AA, Jha AK. Variation in surgical-readmission rates and quality of hospital care. New England Journal of Medicine. 2013;369(12):1134-1142.24047062
8 Zitser-Gurevich Y, Simchen E, Galai N, Braun D. Prediction of readmissions after CABG using detailed follow-up data: the Israeli CABG Study (ISCAB). Medical Care. 1999;37(7):625-636.10424633
9 Stefan MS, Pekow PS, Nsa W, . Hospital performance measures and 30-day readmission rates. Journal of General Internal Medicine. 2013;28(3):377-385.23070655
10 Auerbach AD, Hilton JF, Maselli J, Pekow PS, Rothberg MB, Lindenauer PK. Follow the crowd or shop for the best? Volume, quality, and outcomes of coronary artery bypass surgery. Annals of Internal Medicine. 2009;150(10):696-704.19451576
11 Brinkman W, Herbert MA, O'Brien S, . Preoperative beta-blocker use in coronary artery bypass grafting surgery: national database analysis. JAMA Intern Med. 2014;174(8):1320-1327.24934977
12 Kurlansky PA, Argenziano M, Dunton R, . Quality, not volume, determines outcome of coronary artery bypass surgery in a university-based community hospital network. The Journal of Thoracic and Cardiovascular Surgery. 2012;143(2):287-293. e281.22104669
13 LaPar DJ, Speir AM, Crosby IK, . Postoperative atrial fibrillation significantly increases mortality, hospital readmission, and hospital costs. Annals of Thoracic Surgery. 2014;98(2):527-533; discussion 533.25087786
14 Cotogni P, Barbero C, Passera R, Fossati L, Olivero G, Rinaldi M. Violation of prophylactic vancomycin administration timing is a potential risk factor for rate of surgical site infections in cardiac surgery patients: a prospective cohort study. BMC Cardiovascular Disorders. 2017;17(1). doi: 10.1186/s12872-017-0506-5.
15 Bhattacharyya T, Freiberg AA, Mehta P, Katz JN, Ferris T. Measuring the report card: the validity of pay-for-performance metrics in orthopedic surgery. Health Aff (Millwood). 2009;28(2):526-532.19276012
16 Wang Z, Chen F, Ward M, Bhattacharyya T. Compliance with Surgical Care Improvement Project measures and hospital-associated infections following hip arthroplasty. Journal of Bone & Joint Surgery - American Volume. 2012;94(15):1359-1366.22740029
17 Légaré JF, MacLean A, Buth KJ, Sullivan JA. Assessing the risk of waiting for coronary artery bypass graft surgery among patients with stenosis of the left main coronary artery. CMAJ. 2005;173(4):371-375.16103509
18 Sobolev BG, Fradet G, Kuramoto L, Rogula B. An observational study to evaluate 2 target times for elective coronary bypass surgery. Medical Care. 2012;50(7):611-619.22525613
19 Shulkin D. Understanding Veteran Wait Times. Annals of Internal Medicine. 2017. doi: 10.7326/M17-0900.
20 Expanded Access to Non-VA Care Through the Veterans Choice Program. Final Rule. Federal Register.Oct 29 2015;80(209):66419-66429.26524769
21 VA Office of Inspector General. Veterans Health Administration: Review of the Implementation of the Veterans Choice Program. Washington, DC: Veterans Affairs; 2017.
22 O'Hanlon C, Huang C, Sloss E, . Comparing VA and non-VA quality of care: a systematic review. Journal of General Internal Medicine. 2017;32(1):105-121.27422615
23 Barnett P. Differences in Quality, Cost, and Access between VA and Fee Basis CABG and PCI (IIR 11-049). 2016; Abstract. Available at: https://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141702066. Accessed May 3, 2017.
24 VA Office of Public Affairs. Top VA Health Care Official Announces Initiatives and Progress Made to Improve Access to Care: New Initiatives Chart Roadmap to Access-to-Care Improvements. Washington DC: Veterans Affairs; 2016.
25 Donabedian A. The quality of medical care methods for assessing and monitoring the quality of care for research and for quality assurance programs. Science 1978;200:856-864.417400
26 Institute of Medicine Committee on Quality of Health Care in America. Crossing the quality chasm: a new health system for the 21st century. Washington, DC: National Academy Press; 2001.
27 Chee TT, Ryan AM, Wasfy JH, Borden WB. Current State of Value-Based Purchasing Programs. Circulation. 2016;133(22):2197-2205.27245648
28 Joynt KE, Jha AK. Thirty-day readmissions—truth and consequences. New England Journal of Medicine. 2012;366(15):1366-1369.22455752
29 Health Resources and Services Administration. Performance Management & Measurement. https://www.hrsa.gov/quality/toolbox/methodology/performancemanagement/. Accessed May 9, 2017.
30 Schwarze ML, Brasel KJ, Mosenthal AC. Beyond 30-day mortality: aligning surgical quality with outcomes that patients value. JAMA Surgery. 2014;149(7):631-632.24897945
31 Krumholz HM. Seeking better outcomes in coronary artery bypass grafting: lessons from past experience. Circulation. Jun 10 2008;117(23):2963-2965.18541750
32 Fischer C, Lingsma HF, Marang-van de Mheen PJ, Kringos DS, Klazinga NS, Steyerberg EW. Is the readmission rate a valid quality indicator? A review of the evidence. PLoS ONE [Electronic Resource]. 2014;9(11):e112282.
33 Fry DE. Surgical site infections and the surgical care improvement project (SCIP): evolution of national quality measures. Surgical Infections. 2008;9(6):579-584.19216670
34 Shiloach M, Frencher SK, Steeger JE, . Toward robust information: data quality and inter-rater reliability in the American College of Surgeons National Surgical Quality Improvement Program. Journal of the American College of Surgeons. 2010;210(1):6-16.20123325
35 Khuri SF, Daley J, Henderson W, . The Department of Veterans Affairs' NSQIP: the first national, validated, outcome-based, risk-adjusted, and peer-controlled program for the measurement and enhancement of the quality of surgical care. National VA Surgical Quality Improvement Program. Annals of Surgery. 1998;228(4):491.9790339
36 Peterson ED, DeLong ER, Masoudi FA, . ACCF/AHA 2010 Position Statement on Composite Measures for Healthcare Performance Assessment: a report of American College of Cardiology Foundation/American Heart Association Task Force on Performance Measures (Writing Committee to Develop a Position Statement on Composite Measures). J Am Coll Cardiol. 2010;55(16):1755-1766.20394884
37 D'Agostino RS, Jacobs JP, Badhwar V, . The Society of Thoracic Surgeons Adult Cardiac Surgery Database: 2017 Update on Outcomes and Quality. Ann Thorac Surg. 2017;103(1):18-24.27884412
38 Jacobs JP, Shahian DM, He X, . Penetration, Completeness, and Representativeness of The Society of Thoracic Surgeons Adult Cardiac Surgery Database. Ann Thorac Surg. Jan 2016;101(1):33-41; discussion 41.26542437
39 Shahian DM, Jacobs JP, Edwards FH, . The Society of Thoracic Surgeons National Database. Heart. 2013;99(20):1494-1501.23335498
40 The Society of Thoracic Surgeons. The Society of Thoracic Surgeons Quality Performance Measures 2017; https://www.sts.org/quality-research-patient-safety/quality/quality-performance-measures. Accessed June 28, 2017.
41 Centers for Medicare & Medicaid Services. Hospital Compare. https://www.cms.gov/medicare/quality-initiatives-patient-assessment-instruments/hospitalqualityinits/hospitalcompare.html. Accessed June 28, 2017.
42 Olmsted MG, Geisen E, Murphy J, . Methodology: US News & World Report 2016-17 Best Hospitals: Specialty Rankings. 2016.
43 Girotti ME, Shih T, Dimick JB. Health policy update: rethinking hospital readmission as a surgical quality measure. JAMA Surgery. 2014;149(8):757-758.24920399
44 Landon BE, Normand S-LT, Blumenthal D, Daley J. Physician clinical performance assessment: prospects and barriers. JAMA. 2003;290(9):1183-1189.12953001
45 Centers for Medicare & Medicaid Services. Hospital Readmissions Reduction Program: Fiscal Year (FY) 2017 Fact Sheet. 2016. http://www.qualitynet.org/dcs/ContentServer?cid=1228772412458&pagename=QnetPublic%2FPage%2FQnetTier4&c=Page. Accessed May 9, 2017.
46 Damberg CL, Sorbero ME, Lovejoy SL, Martsolf GR, Raaen L, Mandel D. Measuring success in health care value-based purchasing programs: Summary and Recommendations. Santa Monica, CA: 2014.
47 Berwick DM. Era 3 for medicine and health care. JAMA. 2016;315(13):1329-1330.26940610
48 Atkins D, Kilbourne AM, Shulkin D. Moving From Discovery to System-Wide Change: The Role of Research in a Learning Health Care System: Experience from Three Decades of Health Systems Research in the Veterans Health Administration. Annual Review of Public Health. 2017.
49 Dimick JB, Ghaferi AA. Hospital readmission as a quality measure in surgery. JAMA. 2015;313(5):512-513.25647207
50 Croft AM, Lynch P, Smellie JS, Dickinson CJ. Outpatient waiting times: indicators of hospital performance? J R Army Med Corps. 1998;144(3):131-137.9819719
51 Press MJ, Scanlon DP, Ryan AM, . Limits of readmission rates in measuring hospital quality suggest the need for added metrics. Health Aff (Millwood). 2013;32(6):1083-1091.23733983
52 Ashton CM, Del Junco DJ, Souchek J, Wray NP, Mansyur CL. The association between the quality of inpatient care and early readmission: a meta-analysis of the evidence. Medical Care. 1997;35(10):1044-1059.9338530
53 Kansagara D, Englander H, Salanitro A, . Risk prediction models for hospital readmission: a systematic review. JAMA. 2011;306(15):1688-1698.22009101
54 Shahian DM, Blackstone EH, Edwards FH, . Cardiac surgery risk models: a position article. Ann Thorac Surg. 2004;78(5):1868-1877.15511504
55 Shahian DM, O'Brien SM, Filardo G, . The Society of Thoracic Surgeons 2008 cardiac surgery risk models: part 3--valve plus coronary artery bypass grafting surgery. Ann Thorac Surg. 2009;88(1 Suppl):S43-62.19559824
56 Shahian DM, O'Brien SM, Filardo G, . The Society of Thoracic Surgeons 2008 cardiac surgery risk models: part 1--coronary artery bypass grafting surgery. Ann Thorac Surg. 2009;88(1 Suppl):S2-22.19559822
57 Kondo K, Damberg C, Mendelsen A, . Understanding the intervention and implementation factors associated with benefits and harms of pay for performance programs in healthcare. VA-ESP Project #05-225; 2015.
58 Sterne J, Higgins J, Reeves B. A Cochrane risk of bias assessment tool: For non-randomized studies of interventions (ACROBAT-NRSI). 2014.
59 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville MD: Agency for Healthcare Research and Quality; 2013.
60 Khan SK, Kalra S, Khanna A, Thiruvengada MM, Parker MJ Timing of surgery for hip fractures: a systematic review of 52 published studies involving 291,413 patients. Injury. 2009;40(7):692-697.19450802
61 Leung F, Lau TW, Kwan K, Chow SP, Kung AW Does timing of surgery matter in fragility hip fractures? Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA. 2010;21(Suppl 4):S529-534.
62 Moja L, Piatti A, Pecoraro V, . Timing matters in hip fracture surgery: patients operated within 48 hours have better outcomes. A meta-analysis and meta-regression of over 190,000 patients. PloS One. 2012;7(10):e46175.23056256
63 Schepers T, De Vries MR, Van Lieshout EM, Van der Elst M The timing of ankle fracture surgery and the effect on infectious complications; a case series and systematic review of the literature. International Orthopaedics. 2013;37(3):489-494.23288046
64 Shiga T, Wajima Z, Ohe Y Is operative delay associated with increased mortality of hip fracture patients? Systematic review, meta-analysis, and meta-regression. Canadian Journal of Anaesthesia. 2008;55(3):146-154.18310624
65 Simunovic N, Devereaux PJ, Sprague S, . Effect of early surgery after hip fracture on mortality and complications: systematic review and meta-analysis. CMAJ. 2010;182(15):1609-1616.20837683
66 Lurati Buse GA, Bhandari M, Devereaux P, Inverstigators T Accelerated care versus standard care among patients with hip fracture: the HIP ATTACK pilot trial. CMAJ. 2014;186(1):E52-60.24246589
67 Holvik K, Ranhoff AH, Martinsen MI, Solheim LF Predictors of mortality in older hip fracture inpatients admitted to an orthogeriatric unit in oslo, norway. J Aging Health. 2010;22(8):1114-1131.20881106
68 Schelenz S, Tucker D, Georgeu C, . Significant reduction of endemic MRSA acquisition and infection in cardiothoracic patients by means of an enhanced targeted infection control programme. Journal of Hospital Infection. 2005;60(2):104-110.15866007
69 Clague JE, Craddock E, Andrew G, Horan MA, Pendleton N Predictors of outcome following hip fracture. Admission time predicts length of stay and in-hospital mortality. Injury. 2002;33(1):1-6.11879824
70 Griffiths EJ, Cash DJ, Kalra S, Hopgood PJ Time to surgery and 30-day morbidity and mortality of periprosthetic hip fractures. Injury. 2013;44(12):1949-1952.23639824
71 Kim ES, Park SW, Lee CS, Gyung Kwak Y, Moon C, Kim BN Impact of a national hospital evaluation program using clinical performance indicators on the use of surgical antibiotic prophylaxis in Korea. Int J Infect Dis. 2012;16(3):e187-192.22245171
72 LaPar DJ, Isbell JM, Kern JA, Ailawadi G, Kron IL Surgical Care Improvement Project measure for postoperative glucose control should not be used as a measure of quality after cardiac surgery. Journal of Thoracic & Cardiovascular Surgery. 2014;147(3):1041-1048.24418668
73 Lund CA, Moller AM, Wetterslev J, Lundstrom LH Organizational factors and long-term mortality after hip fracture surgery. A cohort study of 6143 consecutive patients undergoing hip fracture surgery. PLoS ONE [Electronic Resource]. 2014;9(6):e99308.
74 McDonnell ME, Alexanian SM, Junqueira A, Cabral H, Lazar HL Relevance of the Surgical Care Improvement Project on glycemic control in patients undergoing cardiac surgery who receive continuous insulin infusions. Journal of Thoracic & Cardiovascular Surgery. 2013;145(2):590-594; discussion 595-597.23062416
75 Meessen JM, Pisani S, Gambino ML, . Assessment of mortality risk in elderly patients after proximal femoral fracture. Orthopedics. 2014;37(2):e194-200.24679208
76 Rasouli MR, Jaberi MM, Hozack WJ, Parvizi J, Rothman RH Surgical care improvement project (SCIP): has its mission succeeded? Journal of Arthroplasty. 2013;28(7):1072-1075.23602416
77 Ryan DJ, Yoshihara H, Yoneoka D, Egol KA, Zuckerman JD Delay in Hip Fracture Surgery: An Analysis of Patient-Specific and Hospital-Specific Risk Factors. Journal of Orthopaedic Trauma. 2015;29(8):343-348.25714442
78 Sari I, Acar Z, Nurkalem Z, . Preoperative clinical status but not waiting time predicts in-hospital outcomes of surgery in patients with left main coronary artery stenosis. Tohoku J Exp Med. 2007;213(2):173-180.17917411
79 Tennent TD, Calder PR, Salisbury RD, Allen PW, Eastwood DM The operative management of displaced intra-articular fractures of the calcaneum: a two-centre study using a defined protocol. Injury. 2001;32(6):491-496.11476816
80 Vallier HA, Super DM, Moore TA, Wilber JH Do patients with multiple system injury benefit from early fixation of unstable axial fractures? The effects of timing of surgery on initial hospital course. Journal of Orthopaedic Trauma. 2013;27(7):405-412.23287766
81 Karademir G, Bilgin Y, Ersen A, . Hip fractures in patients older than 75 years old: Retrospective analysis for prognostic factors. International Journal Of Surgery. 2015;24(Pt A):101-104.26563486
82 Kane S Post-hoc Power Calculator. Evaluate statistical power of an existing study. 2017; http://clincalc.com/stats/Power.aspx. Accessed 6/20/2017, 2017.
83 Nolan T, Berwick DM All-or-none measurement raises the bar on performance. JAMA. 2006;295(10):1168-1170.16522838
84 Merkow RP, Ju MH, Chung JW, . Underlying reasons associated with hospital readmission following surgery in the United States. JAMA. 2015;313(5):483-495.25647204
85 Maniar HS, Bell JM, Moon MR, . Prospective evaluation of patients readmitted after cardiac surgery: analysis of outcomes and identification of risk factors. Journal of Thoracic & Cardiovascular Surgery. 2014;147(3):1013-1018.24365269
86 Nomellini V, Tevis S, O'Leary M, . Utilizing Patient Perspectives to Help Reduce Postoperative Readmission Rates. International Journal of Surgery Research and Practice. 2015;2(3).
87 Neuman MD, Archan S, Karlawish JH, Schwartz JS, Fleisher LA The relationship between short-term mortality and quality of care for hip fracture: a meta-analysis of clinical pathways for hip fracture. Journal of the American Geriatrics Society. 2009;57(11):2046-2054.19793159
88 Shahian DM, He X, O'Brien SM, . Development of a clinical registry-based 30-day readmission measure for coronary artery bypass grafting surgery. Circulation. 2014;130(5):399-409.24916208
89 Kondo KK, Damberg CL, Mendelson A, . Implementation Processes and Pay for Performance in Healthcare: A Systematic Review. J Gen Intern Med. 2016;31 Suppl 1:61-69.26951276
90 Hannan EL, Sarrazin MS, Doran DR, Rosenthal GE Provider profiling and quality improvement efforts in coronary artery bypass graft surgery: the effect on short-term mortality among Medicare beneficiaries. Medical Care. 2003;41(10):1164-1172.14515112
91 Mendelson A, Kondo K, Damberg C, . The Effects of Pay-for-Performance Programs on Health, Health Care Use, and Processes of Care: A Systematic Review. Ann Intern Med. 07 2017;166(5):341-353.28114600
92 Axon RN, Williams MV Hospital readmission as an accountability measure. JAMA. 2011;305(5):504-505.21285430
93 Benbassat J, Taragin M Hospital readmissions as a measure of quality of health care: advantages and limitations. Archives of Internal Medicine. 2000;160(8):1074-1081.10789599
94 Jencks SF, Williams MV, Coleman EA Rehospitalizations among patients in the Medicare fee-for-service program. N Engl J Med. 2009;360(14):1418-1428.19339721
95 Atkinson G, Giovanis T Conceptual errors in the CMS refusal to make socioeconomic adjustments in readmission and other quality measures. J Ambulatory Care Manage. 2014;37(3):269-272.24887528
96 Blum K, Gottlieb SS The effect of a randomized trial of home telemonitoring on medical costs, 30-day readmissions, mortality, and health-related quality of life in a cohort of community-dwelling heart failure patients. J Card Fail. 2014;20(7):513-521.24769270
97 Portland Evidence-based Synthesis Program. Pay-for-Performance and Veteran Care: Effects, Implementation, and Unintended Consequences. ESP Reports in Progress. https://www.hsrd.research.va.gov/publications/esp/in_progress.cfm#pay-perf. Accessed May 9, 2017.

## Acknowledgements

We would like to thank Julia Haskin, MA for editorial support and Steve Meurer, PhD for providing technical expertise.

## Supplemental Materials

### APPENDIX A EXISTING PERFORMANCE MEASURE SETS

Organization | Clinical Area | Number of Measures | Measure Development Process
NQF^1-3^ | All Includes surgery specific measures – cardiac, orthopedic | NQF:; - 50 - Search of cardiac surgery, orthopedic surgery, hip/pelvic fracture surgery, thoracic surgery; CMS Core Measure Sets:; - CABG – 4; - Ortho - 9 | Expert consensus
VASQIP^4,5^ | Surgery - all | 97 | National VA Surgical Risk Study (NVASRS) 1991-1993. Prospective study on surgical measures and outcomes aimed at developing risk prediction models.
NSQIP^6-8^ | Surgery – all | 135 from Shiloach 2010 75 cardiac specific, reported in Dixon 2015; - 46 preoperative; - 4 intraoperative; - 25 postoperative | Model taken from VASQIP and now managed by ACS
SCIP^9^ | Surgery – all | 15 Infection – 7 Cardiac – 2 VTE – 4 Global – 2 | Expert consensus
STS^6^ | Cardiac | 27 counted on website; - 1 composite; - 18 outcome; - 7 process; - 1 structure; 121 reported from Dixon 2015; - 59 preoperative; - 45 intraoperative; - 17 postoperative | Endorsed or considered for endorsement by NQF

### APPENDIX B SEARCH STRATEGIES

1. Readmissions
A. Required sources: | Evidence:
Medline Date: 3/15/17 | Database: Ovid MEDLINE(R) <1946 to March Week 2 2017>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <March 15, 2017> Search Strategy: ------------------------------------------------------------------------------- 1 exp Patient Readmission/ (11478) 2 Readmission*.ti,ab,kw. (16316) 3 1 or 2 (21425) 4 exp Quality Indicators, Health Care/ (16977) 5 exp “Outcome and Process Assessment (Health Care)”/ (908342) 6 (Quality or ACS NSQIP).ti,ab. (739312) 7 4 or 5 or 6 (1577404) 8 exp Thoracic Surgery/ (11984) 9 Thorax/su [Surgery] (2527) 10 exp Cardiovascular Surgical Procedures/ (337795) 11 exp Thoracic Surgical Procedures/ (297945) 12 Orthopedics/su [Surgery] (152) 13 exp Orthopedic Procedures/ (251138) 14 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (1933243) 15 8 or 9 or 10 or 11 or 12 or 13 or 14 (2369834) 16 3 and 7 and 15 (2241) 17 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (7133227) 18 surg*.ti,ab. (1581744) 19 16 and 18 (1059) 20 17 and 19 (601) 21 (surg* and measure* and quality and readmission*).ti. (9) 22 20 or 21 (605) 23 limit 22 to english language (588) 24 remove duplicates from 23 (560) ***************************
Cochrane Database of Systematic Reviews & Methodology Register Date: 3/15/17 | Database: EBM Reviews - Cochrane Database of Systematic Reviews <2005 to March 15, 2017> Search Strategy: ------------------------------------------------------------------------------- 1 [exp Patient Readmission/] (0) 2 Readmission*.ti,ab,kw. (39) 3 1 or 2 (39) 4 [exp Quality Indicators, Health Care/] (0) 5 [exp “Outcome and Process Assessment (Health Care)”/] (0) 6 (Quality or ACS NSQIP).ti,ab. (5026) 7 4 or 5 or 6 (5026) 8 [exp Thoracic Surgery/] (0) 9 [Thorax/su [Surgery]] (0) 10 [exp Cardiovascular Surgical Procedures/] (0) 11 [exp Thoracic Surgical Procedures/] (0) 12 [Orthopedics/su [Surgery]] (0) 13 [exp Orthopedic Procedures/] (0) 14 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (1077) 15 8 or 9 or 10 or 11 or 12 or 13 or 14 (1077) 16 3 and 7 and 15 (4) 17 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (3124) 18 surg*.ti,ab. (1518) 19 16 and 18 (1) 20 17 and 19 (0) 21 (surg* and measure* and quality and readmission*).ti. (0) 22 20 or 21 (0) 23 limit 22 to english language [Limit not valid; records were retained] (0) 24 remove duplicates from 23 (0) ***************************
CCRCT Date: 3/15/17 | Database: EBM Reviews - Cochrane Central Register of Controlled Trials <February 2017> Search Strategy: ------------------------------------------------------------------------------- 1 exp Patient Readmission/ (727) 2 Readmission*.ti,ab,kw. (2312) 3 1 or 2 (2670) 4 exp Quality Indicators, Health Care/ (295) 5 exp “Outcome and Process Assessment (Health Care)”/ (113624) 6 (Quality or ACS NSQIP).ti,ab. (63313) 7 4 or 5 or 6 (164168) 8 exp Thoracic Surgery/ (151) 9 Thorax/su [Surgery] (2) 10 exp Cardiovascular Surgical Procedures/ (16505) 11 exp Thoracic Surgical Procedures/ (13683) 12 Orthopedics/su [Surgery] (0) 13 exp Orthopedic Procedures/ (9539) 14 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (118774) 15 8 or 9 or 10 or 11 or 12 or 13 or 14 (131844) 16 3 and 7 and 15 (295) 17 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (355878) 18 surg*.ti,ab. (103574) 19 16 and 18 (75) 20 17 and 19 (40) 21 (surg* and measure* and quality and readmission*).ti. (0) 22 20 or 21 (40) 23 limit 22 to english language (39) 24 remove duplicates from 23 (38) ***************************
NHS Economic Evaluation Date: 3/15/17 | Database: EBM Reviews - NHS Economic Evaluation Database <1st Quarter 2016> Search Strategy: ------------------------------------------------------------------------------- 1 exp Patient Readmission/ (161) 2 Readmission*.ti,ab,kw. (20) 3 1 or 2 (164) 4 exp Quality Indicators, Health Care/ (27) 5 exp “Outcome and Process Assessment (Health Care)”/ (4159) 6 (Quality or ACS NSQIP).ti,ab. (302) 7 4 or 5 or 6 (4372) 8 exp Thoracic Surgery/ (10) 9 Thorax/su [Surgery] (0) 10 exp Cardiovascular Surgical Procedures/ (710) 11 exp Thoracic Surgical Procedures/ (629) 12 Orthopedics/su [Surgery] (0) 13 exp Orthopedic Procedures/ (547) 14 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (1026) 15 8 or 9 or 10 or 11 or 12 or 13 or 14 (2004) 16 3 and 7 and 15 (22) 17 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (263) 18 surg*.ti,ab. (1088) 19 16 and 18 (10) 20 17 and 19 (0) 21 (surg* and measure* and quality and readmission*).ti. (0) 22 20 or 21 (0) 23 limit 22 to english language (0) 24 remove duplicates from 23 (0) ***************************
CINAHL Date: 3/15/17 | Database: EBSCOhost CINAHL Plus with Full Text Search Strategy: ------------------------------------------------------------------------------- S1 (MH “Readmission”) (7499) S2 TI Readmission$ OR AB Readmission$ OR MW Readmission$ (10419) S3 S1 OR S2 (10419) S4 (MH “Clinical Indicators”) (9413) S5 (MH “Outcome Assessment”) OR (MH “Process Assessment (Health Care)+”))”/ (34719) S6 TI ( Quality OR ACS NSQIP ) OR AB ( Quality OR ACS NSQIP ) (200910) S7 S4 OR S5 OR S6 (234270) S8 (MH “Thoracic Surgery+”) (44891) S9 (MH “Surgery, Cardiovascular+”) (46637) S10 (MH “Orthopedic Surgery+”) (74399) S11 (MH “Orthopedics”) (8756) S12 TI ( cardi$ OR ortho$ OR arthroplasty OR vascular OR aortic OR hip OR knee ) OR AB ( cardi$ OR ortho$ OR arthroplasty OR vascular OR aortic OR hip OR knee ) (125150) S13 S8 OR S9 OR S10 OR S11 OR S12 (231496) S14 S3 and S7 and S13 (279) S15 TI ( measure$ OR factor$ OR indicat$ OR marker$ OR metric$ ) OR AB ( measure$ OR factor$ OR indicat$ OR marker$ OR metric$ ) (503422) S16 TI surg* OR AB surg* (220124) S17 S14 AND S16 (191) S18 S15 AND S17 (117) S19 TI ( surg$ AND measure$ AND quality AND readmission$ ) OR AB ( surg$ AND measure$ AND quality AND readmission$ ) (0) S20 S18 AND S19 (117) S21 limit S20 to english language (115) ***************************

2. Mortality Rates
A. Required sources: | Evidence:
Medline Date: 3/22/17 Updated: 4/4/17 | Database: Ovid MEDLINE(R) <1946 to March Week 4 2017>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <April 03, 2017> Search Strategy: ------------------------------------------------------------------------------- 1 exp Quality Indicators, Health Care/ (17040) 2 exp “Outcome and Process Assessment (Health Care)”/ (911588) 3 (Quality or ACS NSQIP).ti,ab. (743554) 4 1 or 2 or 3 (1584625) 5 exp Thoracic Surgery/ (11990) 6 Thorax/su [Surgery] (2527) 7 exp Cardiovascular Surgical Procedures/ (338850) 8 exp Thoracic Surgical Procedures/ (298602) 9 Orthopedics/su [Surgery] (152) 10 exp Orthopedic Procedures/ (251714) 11 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (1939359) 12 5 or 6 or 7 or 8 or 9 or 10 or 11 (2376877) 13 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (7160734) 14 surg*.ti,ab. (1586814) 15 (surg* and measure* and quality and mortality).ti. (3) 16 (30 day mortality or 60 day mortality or 90 day mortality).ti,ab,kw. (11751) 17 Postoperative Mortality.mp. (6323) 18 16 or 17 (17701) 19 4 and 12 and 18 (4124) 20 13 and 19 (1858) 21 14 and 20 (1244) 22 15 or 21 (1247) 23 remove duplicates from 22 (1205) 24 limit 23 to english language (1137) ***************************
Cochrane Database of Systematic Reviews & Methodology Register Date: 3/24/17 | Database: EBM Reviews - Cochrane Database of Systematic Reviews <2005 to March 22, 2017> Search Strategy: ------------------------------------------------------------------------------- 1 (Quality or ACS NSQIP).ti,ab. (5034) 2 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (1077) 3 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (3135) 4 surg*.ti,ab. (1519) 5 (surg* and measure* and quality and mortality).ti. (0) 6 (30 day mortality or 60 day mortality or 90 day mortality).ti,ab,kw. (21) 7 Postoperative Mortality.mp. (73) 8 6 or 7 (89) 9 1 and 2 and 8 (17) 10 4 and 9 (16) 11 3 and 10 (7) ***************************
CCRCT Date: 4/4/17 | Database: EBM Reviews - Cochrane Central Register of Controlled Trials <February 2017> Search Strategy: ------------------------------------------------------------------------------- 1 exp Quality Indicators, Health Care/ (295) 2 exp “Outcome and Process Assessment (Health Care)”/ (113624) 3 (Quality or ACS NSQIP).ti,ab. (63313) 4 1 or 2 or 3 (164168) 5 exp Thoracic Surgery/ (151) 6 Thorax/su [Surgery] (2) 7 exp Cardiovascular Surgical Procedures/ (16505) 8 exp Thoracic Surgical Procedures/ (13683) 9 Orthopedics/su [Surgery] (0) 10 exp Orthopedic Procedures/ (9539) 11 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (118774) 12 5 or 6 or 7 or 8 or 9 or 10 or 11 (131844) 13 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (355878) 14 surg*.ti,ab. (103574) 15 (surg* and measure* and quality and mortality).ti. (0) 16 (30 day mortality or 60 day mortality or 90 day mortality).ti,ab,kw. (1289) 17 Postoperative Mortality.mp. (316) 18 16 or 17 (1586) 19 4 and 12 and 18 (267) 20 13 and 19 (123) 21 14 and 20 (70) 22 15 or 21 (70) 23 remove duplicates from 22 (68) 24 limit 23 to english language (67) ***************************
NHS Economic Evaluation Date: 4/4/17 | Database: EBM Reviews - NHS Economic Evaluation Database <1st Quarter 2016> Search Strategy: ------------------------------------------------------------------------------- 1 exp Quality Indicators, Health Care/ (27) 2 exp “Outcome and Process Assessment (Health Care)”/ (4159) 3 (Quality or ACS NSQIP).ti,ab. (302) 4 1 or 2 or 3 (4372) 5 exp Thoracic Surgery/ (10) 6 Thorax/su [Surgery] (0) 7 exp Cardiovascular Surgical Procedures/ (710) 8 exp Thoracic Surgical Procedures/ (629) 9 Orthopedics/su [Surgery] (0) 10 exp Orthopedic Procedures/ (547) 11 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (1026) 12 5 or 6 or 7 or 8 or 9 or 10 or 11 (2004) 13 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (263) 14 surg*.ti,ab. (1088) 15 (surg* and measure* and quality and mortality).ti. (0) 16 (30 day mortality or 60 day mortality or 90 day mortality).ti,ab,kw. (0) 17 Postoperative Mortality.mp. (5) 18 16 or 17 (5) 19 4 and 12 and 18 (0) 20 13 and 19 (0) 21 14 and 20 (0) 22 15 or 21 (0) 23 remove duplicates from 22 (0) 24 limit 23 to english language (0) ***************************
CINAHL Date: 4/4/17 | Database: EBSCOhost CINAHL Plus with Full Text Search Strategy: ------------------------------------------------------------------------------- S1 (MH “Clinical Indicators”) (9431) S2 (MH “Outcome Assessment”) OR (MH “Process Assessment (Health Care)+”))”/ (34859) S3 TI ( Quality OR ACS NSQIP ) OR AB ( Quality OR ACS NSQIP ) (201663) S4 S1 OR S2 OR S3 (235154) S5 (MH “Thoracic Surgery+”) (45131) S6 (MH “Surgery, Cardiovascular+”) (46846) S7 (MH “Orthopedic Surgery+”) (74809) S8 (MH “Orthopedics”) (8797) S9 TI ( cardi$ OR ortho$ OR arthroplasty OR vascular OR aortic OR hip OR knee ) OR AB ( cardi$ OR ortho$ OR arthroplasty OR vascular OR aortic OR hip OR knee ) (126064) S10 S5 OR S6 OR S7 OR S8 OR S9 (232937) S11 TI ( measure$ OR factor$ OR indicat$ OR marker$ OR metric$ ) OR AB ( measure$ OR factor$ OR indicat$ OR marker$ OR metric$ ) (505470) S12 TI surg* OR AB surg* (221304) S13 TI ( surg$ AND measure$ AND quality AND readmission$ ) OR AB ( surg$ AND measure$ AND quality AND mortality) (3) S14 TI ( (30 day mortality OR 60 day mortality OR 90 day mortality) ) OR AB ( (30 day mortality OR 60 day mortality OR 90 day mortality) ) (2466) S15 (MH “Mortality”) (19322) S16 Postoperative Mortality (512) S17 S14 OR S15 OR S16 (22018) S18 S4 AND S10 AND S17 (234) S19 S11 AND S18 (93) S20 S12 AND S19 (69) S21 S13 OR S20 (72) ***************************

3. Post-op Care Plan
A. Required sources: | Evidence:
Medline Date: 3/22/17 Updated: 4/4/17 | Database: Ovid MEDLINE(R) <1946 to March Week 4 2017>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <April 03, 2017> Search Strategy: ------------------------------------------------------------------------------- 1 exp Quality Indicators, Health Care/ (17040) 2 exp “Outcome and Process Assessment (Health Care)”/ (911588) 3 (Quality or ACS NSQIP).ti,ab. (743554) 4 1 or 2 or 3 (1584625) 5 exp Thoracic Surgery/ (11990) 6 Thorax/su [Surgery] (2527) 7 exp Cardiovascular Surgical Procedures/ (338850) 8 exp Thoracic Surgical Procedures/ (298602) 9 Orthopedics/su [Surgery] (152) 10 exp Orthopedic Procedures/ (251714) 11 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (1939359) 12 5 or 6 or 7 or 8 or 9 or 10 or 11 (2376877) 13 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (7160734) 14 surg*.ti,ab. (1586814) 15 (surg* and measure* and quality and mortality).ti. (3) 16 patient care planning.mp. or exp Patient Care Planning/ (59227) 17 (care pathway* or clinical pathway*).ti,ab,kw. (5171) 18 16 or 17 (62380) 19 (home care or nursing home or assisted living).ti,ab. (34207) 20 18 and 19 (1255) 21 4 and 12 and 20 (32) ***************************
Cochrane Database of Systematic Reviews & Methodology Register Date: 3/24/17 | Database: EBM Reviews - Cochrane Database of Systematic Reviews <2005 to March 22, 2017> Search Strategy: ------------------------------------------------------------------------------- 1 (Quality or ACS NSQIP).ti,ab. (5034) 2 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (1077) 3 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (3135) 4 surg*.ti,ab. (1519) 5 (surg* and measure* and quality and care).ti. (0) 6 patient care planning.mp. (33) 7 (care pathway* or clinical pathway*).ti,ab,kw. (14) 8 (home care or nursing home or assisted living).ti,ab. (26) 9 6 or 7 or 8 (70) 10 1 and 2 and 9 (5) 11 3 and 10 (4) 12 4 and 11 (0) ***************************
CCRCT Date: 4/4/17 | Database: EBM Reviews - Cochrane Central Register of Controlled Trials <February 2017> Search Strategy: ------------------------------------------------------------------------------- 1 exp Quality Indicators, Health Care/ (295) 2 exp “Outcome and Process Assessment (Health Care)”/ (113624) 3 (Quality or ACS NSQIP).ti,ab. (63313) 4 1 or 2 or 3 (164168) 5 exp Thoracic Surgery/ (151) 6 Thorax/su [Surgery] (2) 7 exp Cardiovascular Surgical Procedures/ (16505) 8 exp Thoracic Surgical Procedures/ (13683) 9 Orthopedics/su [Surgery] (0) 10 exp Orthopedic Procedures/ (9539) 11 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (118774) 12 5 or 6 or 7 or 8 or 9 or 10 or 11 (131844) 13 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (355878) 14 surg*.ti,ab. (103574) 15 (surg* and measure* and quality and mortality).ti. (0) 16 patient care planning.mp. or exp Patient Care Planning/ (1361) 17 (care pathway* or clinical pathway*).ti,ab,kw. (429) 18 16 or 17 (1697) 19 (home care or nursing home or assisted living).ti,ab. (2423) 20 18 and 19 (55) 21 4 and 12 and 20 (1) ***************************
NHS Economic Evaluation Date: 4/4/17 | Database: EBM Reviews - NHS Economic Evaluation Database <1st Quarter 2016> Search Strategy: ------------------------------------------------------------------------------- 1 exp Quality Indicators, Health Care/ (27) 2 exp “Outcome and Process Assessment (Health Care)”/ (4159) 3 (Quality or ACS NSQIP).ti,ab. (302) 4 1 or 2 or 3 (4372) 5 exp Thoracic Surgery/ (10) 6 Thorax/su [Surgery] (0) 7 exp Cardiovascular Surgical Procedures/ (710) 8 exp Thoracic Surgical Procedures/ (629) 9 Orthopedics/su [Surgery] (0) 10 exp Orthopedic Procedures/ (547) 11 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (1026) 12 5 or 6 or 7 or 8 or 9 or 10 or 11 (2004) 13 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (263) 14 surg*.ti,ab. (1088) 15 (surg* and measure* and quality and mortality).ti. (0) 16 patient care planning.mp. or exp Patient Care Planning/ (212) 17 (care pathway* or clinical pathway*).ti,ab,kw. (66) 18 16 or 17 (219) 19 (home care or nursing home or assisted living).ti,ab. (49) 20 18 and 19 (2) 21 4 and 12 and 20 (0) ***************************
CINAHL Date: 4/4/17 | Database: EBSCOhost CINAHL Plus with Full Text Search Strategy: ------------------------------------------------------------------------------- S1 (MH “Clinical Indicators”) (9431) S2 (MH “Outcome Assessment”) OR (MH “Process Assessment (Health Care)+”))”/ (34859) S3 TI ( Quality OR ACS NSQIP ) OR AB ( Quality OR ACS NSQIP ) (201663) S4 S1 OR S2 OR S3 (235154) S5 (MH “Thoracic Surgery+”) (45131) S6 (MH “Surgery, Cardiovascular+”) (46846) S7 (MH “Orthopedic Surgery+”) (74809) S8 (MH “Orthopedics”) (8797) S9 TI ( cardi$ OR ortho$ OR arthroplasty OR vascular OR aortic OR hip OR knee ) OR AB ( cardi$ OR ortho$ OR arthroplasty OR vascular OR aortic OR hip OR knee ) (126064) S10 S5 OR S6 OR S7 OR S8 OR S9 (232937) S11 TI ( measure$ OR factor$ OR indicat$ OR marker$ OR metric$ ) OR AB ( measure$ OR factor$ OR indicat$ OR marker$ OR metric$ ) (505470) S12 TI surg* OR AB surg* (221304) S13 TI ( surg$ AND measure$ AND quality AND readmission$ ) OR AB ( surg$ AND measure$ AND quality AND readmission$ ) (0) S14 (MH “Patient Care Plans+”) (8763) S15 patient care plan$ (4730) S16 TI ( care pathway$ OR clinical pathway$ ) OR AB ( care pathway$ OR clinical pathway$ ) (2546) S17 TI ( home care OR nursing home OR assisted living ) OR AB ( home care OR nursing home OR assisted living ) (26014) S18 S14 OR S15 OR S16 OR S17 (37049) S19 S4 AND S10 AND S18 (196) S20 S11 AND S19 (65) S21 S12 AND S20 (21) ***************************

4. Wait Times
A. Required sources: | Evidence:
Medline Date: 4/4/17 Updated: 6/13/17 | Database: Ovid MEDLINE(R) <1946 to June Week 1 2017>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <June 12, 2017> Search Strategy: ------------------------------------------------------------------------------- 1 exp Thoracic Surgery/ (12160) 2 Thorax/su [Surgery] (2531) 3 exp Cardiovascular Surgical Procedures/ (345848) 4 exp Thoracic Surgical Procedures/ (303795) 5 Orthopedics/su [Surgery] (153) 6 exp Orthopedic Procedures/ (256205) 7 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (1982456) 8 1 or 2 or 3 or 4 or 5 or 6 or 7 (2426823) 9 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (7306744) 10 surg*.ti,ab. (1617175) 11 (target time* or waiting time or Waiting List).mp. or exp Waiting Lists/ (19131) 12 8 and 9 and 10 and 11 (540) 13 limit 12 to english language (486) 14 remove duplicates from 13 (469) ***************************
Cochrane Database of Systematic Reviews & Methodology Register Date: 3/24/17 Updated: 6/13/17 | Database: EBM Reviews - Cochrane Database of Systematic Reviews <2005 to June 9, 2017> Search Strategy: ------------------------------------------------------------------------------- 1 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (1087) 2 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (3168) 3 surg*.ti,ab. (1535) 4 (target time* or waiting time or Waiting List).mp. or exp Waiting Lists/ (381) 5 1 and 4 (29) 6 2 and 4 (173) 7 5 or 6 (182) ***************************
CCRCT Date: 4/4/17 Updated: 6/13/17 | Database: EBM Reviews - Cochrane Central Register of Controlled Trials <April 2017> Search Strategy: ------------------------------------------------------------------------------- 1 exp Thoracic Surgery/ (151) 2 Thorax/su [Surgery] (2) 3 exp Cardiovascular Surgical Procedures/ (16674) 4 exp Thoracic Surgical Procedures/ (13799) 5 Orthopedics/su [Surgery] (0) 6 exp Orthopedic Procedures/ (9656) 7 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (122041) 8 1 or 2 or 3 or 4 or 5 or 6 or 7 (135244) 9 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (365411) 10 surg*.ti,ab. (106681) 11 (target time* or waiting time or Waiting List).mp. or exp Waiting Lists/ (2398) 12 8 and 9 and 10 and 11 (47) 13 limit 12 to english language (41) 14 remove duplicates from 13 (41) ***************************
NHS Economic Evaluation Date: 4/4/17 Updated: 6/13/17 | Database: EBM Reviews - NHS Economic Evaluation Database <1st Quarter 2016> Search Strategy: ------------------------------------------------------------------------------- 1 exp Thoracic Surgery/ (10) 2 Thorax/su [Surgery] (0) 3 exp Cardiovascular Surgical Procedures/ (710) 4 exp Thoracic Surgical Procedures/ (629) 5 Orthopedics/su [Surgery] (0) 6 exp Orthopedic Procedures/ (547) 7 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (1026) 8 1 or 2 or 3 or 4 or 5 or 6 or 7 (2004) 9 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (263) 10 surg*.ti,ab. (1088) 11 (target time* or waiting time or Waiting List).mp. or exp Waiting Lists/ (133) 12 8 and 11 (32) ***************************
CINAHL Date: 4/4/17 Updated: 6/13/17 | Database: EBSCOhost CINAHL Plus with Full Text Search Strategy: ------------------------------------------------------------------------------- S1 (MH “Thoracic Surgery+”) (45864) S2 (MH “Surgery, Cardiovascular+”) (47712) S3 (MH “Orthopedic Surgery+”) (76552) S4 (MH “Orthopedics”) (8891) S5 TI ( cardi$ OR ortho$ OR arthroplasty OR vascular OR aortic OR hip OR knee ) OR AB ( cardi$ OR ortho$ OR arthroplasty OR vascular OR aortic OR hip OR knee ) (137985) S6 S1 OR S2 OR S3 OR S4 OR S5 (244533) S7 TI ( measure$ OR factor$ OR indicat$ OR marker$ OR metric$ ) OR AB ( measure$ OR factor$ OR indicat$ OR marker$ OR metric$ ) (572399) S8 TI surg* OR AB surg* (245763) S9 (MH “Waiting Lists”) (4169) S10 TX wait$ list$ (2222) S11 TX target time$ (245) S12 S9 OR S10 OR S11 (6453) S13 S6 AND S7 AND S8 AND S12 (52) ***************************

5. Guideline Compliance
A. Required sources: | Evidence:
Medline Date: 3/22/17 Updated 6/19/17 | Database: Ovid MEDLINE(R) <1946 to June Week 2 2017>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <June 16, 2017> Search Strategy: ------------------------------------------------------------------------------- 1 exp Thoracic Surgery/ (12160) 2 Thorax/su [Surgery] (2531) 3 exp Cardiovascular Surgical Procedures/ (346098) 4 exp Thoracic Surgical Procedures/ (303967) 5 Orthopedics/su [Surgery] (153) 6 exp Orthopedic Procedures/ (256401) 7 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (1984057) 8 1 or 2 or 3 or 4 or 5 or 6 or 7 (2428677) 9 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (7313030) 10 surg*.ti,ab. (1618459) 11 exp Guideline Adherence/ (27274) 12 (guidleine Compliance or policy Compliance or protocol Compliance or institutional Compliance).ti,ab,kw. (380) 13 (guidleine Adherence or policy Adherence or protocol Adherence or institutional Adherence).ti,ab,kw. (352) 14 11 or 12 or 13 (27847) 15 ((guideline or policy or protocol or institutional) adj3 (compliance or adherence)).mp. (29858) 16 14 or 15 (29858) 17 8 and 9 and 10 and 16 (397) 18 limit 17 to english language (363) 19 remove duplicates from 18 (346) ***************************
Cochrane Database of Systematic Reviews & Methodology Register Date: 3/24/17 Updated 6/19/17 | Database: EBM Reviews - Cochrane Database of Systematic Reviews <2005 to June 14, 2017> Search Strategy: ------------------------------------------------------------------------------- 1 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (1089) 2 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (3172) 3 surg*.ti,ab. (1536) 4 [exp Guideline Adherence/] (0) 5 (guidleine Compliance or policy Compliance or protocol Compliance or institutional Compliance).ti,ab,kw. (1) 6 (guidleine Adherence or policy Adherence or protocol Adherence or institutional Adherence).ti,ab,kw. (1) 7 4 or 5 or 6 (2) 8 ((guideline or policy or protocol or institutional) adj3 (compliance or adherence)).mp. (289) 9 7 or 8 (289) 10 1 and 2 and 3 and 9 (1) ***************************
CCRCT Date: 4/4/17 Updated 6/19/17 | Database: EBM Reviews - Cochrane Central Register of Controlled Trials <May 2017> Search Strategy: ------------------------------------------------------------------------------- 1 exp Thoracic Surgery/ (151) 2 Thorax/su [Surgery] (2) 3 exp Cardiovascular Surgical Procedures/ (16764) 4 exp Thoracic Surgical Procedures/ (13835) 5 Orthopedics/su [Surgery] (0) 6 exp Orthopedic Procedures/ (9715) 7 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (123336) 8 1 or 2 or 3 or 4 or 5 or 6 or 7 (136599) 9 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (370114) 10 surg*.ti,ab. (108072) 11 exp Guideline Adherence/ (830) 12 (guidleine Compliance or policy Compliance or protocol Compliance or institutional Compliance).ti,ab,kw. (334) 13 (guidleine Adherence or policy Adherence or protocol Adherence or institutional Adherence).ti,ab,kw. (149) 14 11 or 12 or 13 (1252) 15 ((guideline or policy or protocol or institutional) adj3 (compliance or adherence)).mp. (2166) 16 14 or 15 (2166) 17 8 and 9 and 10 and 16 (31) 18 limit 17 to english language (24) 19 remove duplicates from 18 (24) ***************************
NHS Economic Evaluation Date: 4/4/17 Updated 6/19/17 | Database: EBM Reviews - NHS Economic Evaluation Database <1st Quarter 2016> Search Strategy: ------------------------------------------------------------------------------- 1 exp Thoracic Surgery/ (10) 2 Thorax/su [Surgery] (0) 3 exp Cardiovascular Surgical Procedures/ (710) 4 exp Thoracic Surgical Procedures/ (629) 5 Orthopedics/su [Surgery] (0) 6 exp Orthopedic Procedures/ (547) 7 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (1026) 8 1 or 2 or 3 or 4 or 5 or 6 or 7 (2004) 9 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (263) 10 surg*.ti,ab. (1088) 11 exp Guideline Adherence/ (75) 12 (guidleine Compliance or policy Compliance or protocol Compliance or institutional Compliance).ti,ab,kw. (0) 13 (guidleine Adherence or policy Adherence or protocol Adherence or institutional Adherence).ti,ab,kw. (0) 14 11 or 12 or 13 (75) 15 ((guideline or policy or protocol or institutional) adj3 (compliance or adherence)).mp. (94) 16 14 or 15 (94) 17 8 and 9 and 10 and 16 (1) 18 limit 17 to english language (1) 19 remove duplicates from 18 (1) ***************************
CINAHL Date: 4/4/17 Updated 6/19/17 | Database: EBSCOhost CINAHL Plus with Full Text Search Strategy: ------------------------------------------------------------------------------- S1 (MH “Thoracic Surgery+”) (45900) S2 (MH “Surgery, Cardiovascular+”) (47756) S3 (MH “Orthopedic Surgery+”) (76677) S4 (MH “Orthopedics”) (8896) S5 TI ( cardi$ OR ortho$ OR arthroplasty OR vascular OR aortic OR hip OR knee ) OR AB ( cardi$ OR ortho$ OR arthroplasty OR vascular OR aortic OR hip OR knee ) (138274) S16 S1 OR S2 OR S3 OR S4 OR S5 (232937) S7 TI ( measure$ OR factor$ OR indicat$ OR marker$ OR metric$ ) OR AB ( measure$ OR factor$ OR indicat$ OR marker$ OR metric$ ) (574043) S8 TI surg* OR AB surg* (246392) S9 (MH “Guideline Adherence”) (9724) S10 TI ( (guideline Adherence OR policy Adherence OR protocol Adherence OR institutional Adherence) ) OR AB ( (guideline Adherence OR policy Adherence OR protocol Adherence OR institutional Adherence) ) (662) S11 TI ( (guideline Compliance OR policy Compliance OR protocol Compliance OR institutional Compliance) ) OR AB ( (guideline Compliance OR policy Compliance OR protocol Compliance OR institutional Compliance) ) (293) S12 TI ((guideline or policy or protocol or institutional) N3 (compliance or adherence)) OR AB ((guideline or policy or protocol or institutional) N3 (compliance or adherence)) (4404) S13 S9 OR S10 OR S11 OR S12 (13179) S14 S6 AND S7 AND S8 AND S13 (52) ***************************

6. Infections
A. Required sources: | Evidence:
Medline Date: 3/22/17 Updated: 4/4/17 | Database: Ovid MEDLINE(R) <1946 to March Week 4 2017>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <April 03, 2017> Search Strategy: ------------------------------------------------------------------------------- 1 exp Quality Indicators, Health Care/ (17040) 2 exp “Outcome and Process Assessment (Health Care)”/ (911588) 3 (Quality or ACS NSQIP).ti,ab. (743554) 4 1 or 2 or 3 (1584625) 5 exp Thoracic Surgery/ (11990) 6 Thorax/su [Surgery] (2527) 7 exp Cardiovascular Surgical Procedures/ (338850) 8 exp Thoracic Surgical Procedures/ (298602) 9 Orthopedics/su [Surgery] (152) 10 exp Orthopedic Procedures/ (251714) 11 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (1939359) 12 5 or 6 or 7 or 8 or 9 or 10 or 11 (2376877) 13 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (7160734) 14 surg*.ti,ab. (1586814) 15 (surg* and measure* and quality and infection).ti. (6) 16 Surgical Wound Infection.mp. or exp Surgical Wound Infection/ (32402) 17 Prophyla* Antibiotic*.ti,ab. (5418) 18 16 or 17 (36555) 19 4 and 12 and 18 (2310) 20 13 and 19 (914) 21 14 and 20 (749) 22 15 or 21 (754) 23 remove duplicates from 22 (732) 24 limit 23 to english language (682) ***************************
Cochrane Database of Systematic Reviews & Methodology Register Date: 3/24/17 | Database: EBM Reviews - Cochrane Database of Systematic Reviews <2005 to March 22, 2017> Search Strategy: ------------------------------------------------------------------------------- 1 (Quality or ACS NSQIP).ti,ab. (5034) 2 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (1077) 3 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (3135) 4 surg*.ti,ab. (1519) 5 (surg* and measure* and quality and infection*).ti. (0) 6 (surgical site infection* or Surgical Wound Infection*).mp. (136) 7 Prophyla* Antibiotic*.ti,ab. (61) 8 6 or 7 (181) 9 1 and 2 and 8 (15) 10 4 and 9 (14) 11 3 and 10 (8) ***************************
CCRCT Date: 4/4/17 | Database: EBM Reviews - Cochrane Central Register of Controlled Trials <February 2017> Search Strategy: ------------------------------------------------------------------------------- 1 exp Quality Indicators, Health Care/ (295) 2 exp “Outcome and Process Assessment (Health Care)”/ (113624) 3 (Quality or ACS NSQIP).ti,ab. (63313) 4 1 or 2 or 3 (164168) 5 exp Thoracic Surgery/ (151) 6 Thorax/su [Surgery] (2) 7 exp Cardiovascular Surgical Procedures/ (16505) 8 exp Thoracic Surgical Procedures/ (13683) 9 Orthopedics/su [Surgery] (0) 10 exp Orthopedic Procedures/ (9539) 11 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (118774) 12 5 or 6 or 7 or 8 or 9 or 10 or 11 (131844) 13 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (355878) 14 surg*.ti,ab. (103574) 15 (surg* and measure* and quality and infection).ti. (0) 16 Surgical Wound Infection.mp. or exp Surgical Wound Infection/ (2784) 17 Prophyla* Antibiotic*.ti,ab. (1083) 18 16 or 17 (3585) 19 4 and 12 and 18 (173) 20 13 and 19 (68) 21 14 and 20 (54) 22 15 or 21 (54) 23 remove duplicates from 22 (54) 24 limit 23 to english language (51) ***************************
NHS Economic Evaluation Date: 4/4/17 | Database: EBM Reviews - NHS Economic Evaluation Database <1st Quarter 2016> Search Strategy: ------------------------------------------------------------------------------- 1 exp Quality Indicators, Health Care/ (27) 2 exp “Outcome and Process Assessment (Health Care)”/ (4159) 3 (Quality or ACS NSQIP).ti,ab. (302) 4 1 or 2 or 3 (4372) 5 exp Thoracic Surgery/ (10) 6 Thorax/su [Surgery] (0) 7 exp Cardiovascular Surgical Procedures/ (710) 8 exp Thoracic Surgical Procedures/ (629) 9 Orthopedics/su [Surgery] (0) 10 exp Orthopedic Procedures/ (547) 11 (cardi* or ortho* or arthroplasty or vascular or aortic or hip or knee).ti,ab. (1026) 12 5 or 6 or 7 or 8 or 9 or 10 or 11 (2004) 13 (measure* or factor* or indicat* or marker* or metric*).ti,ab. (263) 14 surg*.ti,ab. (1088) 15 (surg* and measure* and quality and infection).ti. (0) 16 Surgical Wound Infection.mp. or exp Surgical Wound Infection/ (121) 17 Prophyla* Antibiotic*.ti,ab. (14) 18 16 or 17 (128) 19 4 and 12 and 18 (9) 20 13 and 19 (0) 21 14 and 20 (0) 22 15 or 21 (0) 23 remove duplicates from 22 (0) 24 limit 23 to english language (0) ***************************
CINAHL Date: 4/4/17 | Database: EBSCOhost CINAHL Plus with Full Text Search Strategy: ------------------------------------------------------------------------------- S1 (MH “Clinical Indicators”) (9431) S2 (MH “Outcome Assessment”) OR (MH “Process Assessment (Health Care)+”))”/ (34859) S3 TI ( Quality OR ACS NSQIP ) OR AB ( Quality OR ACS NSQIP ) (201663) S4 S1 OR S2 OR S3 (235154) S5 (MH “Thoracic Surgery+”) (45131) S6 (MH “Surgery, Cardiovascular+”) (46846) S7 (MH “Orthopedic Surgery+”) (74809) S8 (MH “Orthopedics”) (8797) S9 TI ( cardi$ OR ortho$ OR arthroplasty OR vascular OR aortic OR hip OR knee ) OR AB ( cardi$ OR ortho$ OR arthroplasty OR vascular OR aortic OR hip OR knee ) (126064) S10 S5 OR S6 OR S7 OR S8 OR S9 (232937) S11 TI ( measure$ OR factor$ OR indicat$ OR marker$ OR metric$ ) OR AB ( measure$ OR factor$ OR indicat$ OR marker$ OR metric$ ) (505470) S12 TI surg* OR AB surg* (221304) S13 TI ( surg$ AND measure$ AND quality AND infection$ ) OR AB ( surg$ AND measure$ AND quality AND infection$) (0) S14 Surgical Wound Infection$ (7342) S15 TI Prophyla$ Antibiotic$ OR AB Prophyla$ Antibiotic$ (0) S16 (MH “Surgical Wound Infection”) (7282) S17 S14 OR S15 OR S16 (7342) S18 S4 AND S10 AND S17 (154) S19 S11 AND S18 (57) S20 S12 AND S19 (55) ***************************

7. Grey Literature
A. Required sources: | Evidence:
AHRQ: evidence reports, technology assessments, U.S Preventative Services Task Force Evidence Synthesis Date: 3/20/17 Updated: 3/28/17 | http://www.ahrq.gov/research/findings/evidence-based-reports/search.html Search: readmission; readmit; mortality; post-operative care; wait time; delay; guideline compliance; infection Relevant Results: None
CADTH Date: 3/20/17 Updated: 3/28/17 | https://www.cadth.ca Search: readmission; readmit; mortality; post-operative care; wait time; delay; guideline compliance; infection Relevant Results: Post-Operative Follow-Up for Elderly Hip Fracture Surgery Patients: Clinical Effectiveness and Guidelines (https://www.cadth.ca/post-operative-follow-elderly-hip-fracture-surgery-patients-clinical-effectiveness-and-guidelines); - Abstract-based rapid review product; specific to follow-up care; Post-operative Pain Management for Patients After Elective Knee or Hip Replacement Surgery: Guidelines (https://www.cadth.ca/post-operative-pain-management-patients-after-elective-knee-or-hip-replacement-surgery-guidelines-0); - Specific to pain management, not related to quality measure; Timing of Hip Fracture Surgery for Non-Elderly Adults: Clinical Effectiveness and Guidelines (https://www.cadth.ca/timing-hip-fracture-surgery-non-elderly-adults-clinical-effectiveness-and-guidelines); - Abstract-based rapid review product; potentially relevant; Cancelation of Hip and Knee Replacement Surgeries: Guidelines (https://www.cadth.ca/cancelation-hip-and-knee-replacement-surgeries-guidelines); - Specific to comorbidities associated with surgery cancellation; Preoperative Skin Antiseptic Preparations and Application Techniques for Preventing Surgical Site Infections: A Systematic Review of the Clinical Evidence and Guidelines (https://www.cadth.ca/preoperative-skin-antiseptic-preparations-and-application-techniques-preventing-surgical-site); - SSI prevention specific to antiseptic application—peripheral information in the review is possibly useful for background on SSI; appendix 11 provides data by surgery type
ECRI Institute Date: 3/20/17 Updated: 3/28/17 | https://www.ecri.org/Pages/default.aspx Search: readmission; readmit; mortality and surgery; post-operative care; wait time; delay; guideline compliance; infection Relevant Results: None
NHS Evidence Date: 3/20/17 | http://www.evidence.nhs.uk/default.aspx Search: readmission; readmit; mortality; post-operative care; wait time; delay; guideline compliance; infection Relevant Results: Thirty-day readmission rates in spine surgery: systematic review and meta-analysis (http://www.ncbi.nlm.nih.gov/pubmed/26424347); - KQ2 is relevant - What study factors impact the rate of 30-day readmissions? Includes time from enrollment as a factor; Effect of early surgery after hip fracture on mortality and complications: systematic review and meta-analysis (http://www.crd.york.ac.uk/crdweb/ShowRecord.asp?LinkFrom=OAI&ID=12010007859); - KQ1-Supports wait time as a valid quality metric – relevant; Meta-analysis of studies on mortality of early surgery vs delayed surgery for patients with femoral neck fractures (http://www.crd.york.ac.uk/crdweb/ShowRecord.asp?LinkFrom=OAI&ID=12011005042); - Chinese language only; Pre-operative indicators for mortality following hip fracture surgery: a systematic review and meta-analysis (http://www.crd.york.ac.uk/crdweb/ShowRecord.asp?LinkFrom=OAI&ID=12014036522); - Background- patient-level characteristics only – may be useful as citation for number of studies looking at patient level characteristics; Morbidity and mortality related to odontoid fracture surgery in the elderly population (http://www.crd.york.ac.uk/crdweb/ShowRecord.asp?LinkFrom=OAI&ID=12010004053); - Outcomes after fracture surgery. Study supports discussion on outcomes based on factors other than hospital/physician performance.; Timing matters in hip fracture surgery: patients operated within 48 hours have better outcomes - a meta-analysis and meta-regression of over 190,000 patients (http://www.crd.york.ac.uk/crdweb/ShowRecord.asp?LinkFrom=OAI&ID=12012047984); - Relevant KQ1-Supports wait times as valid quality metric.; Timing of surgery for hip fractures: a systematic review of 52 published studies involving 291,413 patients (http://www.crd.york.ac.uk/crdweb/ShowRecord.asp?LinkFrom=OAI&ID=12009106228); - Relevant KQ1-Supports wait times as valid quality metric.
NQF Date: 3/23/17 | http://www.qualityforum.org/ProjectListing.aspx Search: readmission; readmit; mortality and surgery; post-operative care; wait time; delay; guideline compliance; infection Relevant Results: Surgery These refer to ongoing projects, not complete data. See comments below for potentially relevant projects. All-Cause Admissions and Readmissions Project 2015-2017 (http://www.qualityforum.org/Project_Pages/All-Cause_Admissions_and_Readmissions_2015-2017.aspx); - Relevant measures: #1789, #2879, #2514, #2502, #2504; - Relevant for discussion of NQF activities; All-Cause Admissions & Readmissions Project 2017 (http://www.qualityforum.org/All-Cause_Admissions_and_Readmissions_2017.aspx); - Relevant measures: #2515; - Relevant for discussion of NQF activities – not sure how it differs from above; Care Coordination Endorsement Maintenance Project 2016-2017 (http://www.qualityforum.org/Care_Coordination_2016-2017.aspx); - Relevant measures: #0326, #0646, #0647, #0648, #0649; - Relevant for discussion of NQF activities; Surgery Project 2015-2017 (http://www.qualityforum.org/Surgery_2015-2017.aspx); - Relevant measures: #1550, #1551, #2998, #3030, #3031, #3032; - Relevant for discussion of NQF activities
VA Products - VATAP, PBM and HSR&D publications Date: 3/29/17 | A. http://www.hsrd.research.va.gov/research/default.cfm Search: readmission; readmit (https://scholar.google.com/Evidence); mortality and surgery; post-operative care; wait time; delay; guideline compliance; infection Relevant Results: Differences in Quality, Cost, and Access between VA and Fee Basis CABG and PCI (https://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141702066); - Background of potential effects of outsourced, non-VA care identified by annual volume of procedures and hospital performance reported to Medicare-- performance measured in 30-day risk-adjusted mortality following acute myocardial infarction in the Hospital Compare database; Improving Surgical Quality: Risks and Impact of Readmission (https://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141704064); - Background-On-going study-considers multiple patient-, procedure- and complication-based factors in 30-day readmission for the purposes of validating a risk prediction tool- specifically aimed at exposing data not currently reflected in VASQIP; B. http://www.research.va.gov/research_topics/ Relevant Results: Access and Quality Tool www.accesstocare.va.gov; - Background - provide Veterans with useful information related to such things as new and established patient wait times, satisfaction scores for access to primary and specialty care, and timeliness of urgent appointments.; C. https://www.hsrd.research.va.gov/publications/esp Relevant Results: Joint replacement disparities https://www.hsrd.research.va.gov/publications/esp/joint-replacement.cfm; - Focuses on racial disparities – VA and non-VA; Public reporting of quality and safety data https://www.hsrd.research.va.gov/publications/esp/transparency.cfm; - Background - Focuses on best way to present performance data to the public and if public reporting influences quality improvement programs or clinical measures. May be relevant context for discussion around KQ2.; Readmission risk prediction https://www.hsrd.research.va.gov/publications/esp/readmission.cfm; - Background-Useful to cite in discussion about existing models. The review finds risk prediction models for hospital readmission still not validated in the evidence.; VA vs non-VA quality https://www.hsrd.research.va.gov/publications/esp/quality.cfm; - Background – VA vs non-VA quality of care
CMS Policies Date: 3/29/17 | https://www.cms.gov/Medicare/Quality-Initiatives-Patient-Assessment-Instruments/QualityMeasures/CMS-Measures-Inventory.html Search: quality measures Relevant Results: Cardiovascular Measures (https://www.cms.gov/Medicare/Quality-Initiatives-Patient-Assessment-Instruments/QualityMeasures/Downloads/Cardiovascular-Measures.pdf); - Background - Useful for background discussion of CMS measures.; Orthopedic Measures (https://www.cms.gov/Medicare/Quality-Initiatives-Patient-Assessment-Instruments/QualityMeasures/Downloads/Orthopedic-Measures.pdf); - Background - Useful for background discussion of CMS measures.; Statistical Issues In Assessing Hospital Performance (https://www.cms.gov/Medicare/Quality-Initiatives-Patient-Assessment-Instruments/HospitalQualityInits/Downloads/Statistical-Issues-in-Assessing-Hospital-Performance.pdf); - Background- CMS statistical guidance
Google scholar Date: 3/29/17 | http://scholar.google.com/ Search: readmission; readmit; mortality and surgery; post-operative care; wait time; delay; guideline compliance; infection Relevant Results: Lucas, Donald J., and Timothy M. Pawlik. “Readmission after surgery (https://www.ncbi.nlm.nih.gov/pubmed/25293615).” Advances in surgery 48 (2013): 185-199.; - Background Focuses on problems with the 30-day standard. Data on rates of readmission after surgery by surgery type; Karhade, Aditya V., et al. “Thirty-day readmission and reoperation after surgery for spinal tumors: a National Surgical Quality Improvement Program analysis. (https://www.ncbi.nlm.nih.gov/pubmed/?term=Thirty-day+readmission+and+reoperation+after+surgery+for+spinal+tumors%3A+a+National+Surgical+Quality+Improvement+Program+analysis.)” Neurosurgical Focus 41.2 (2016): E5.; - Rate of and reasons for readmission after surgery, focus on determining incidence for readmittance post-spinal tumor surgery, mortality and predictors of complications; Li, Zhongmin, et al. “Hospital variation in readmission after coronary artery bypass surgery in California (https://www.ncbi.nlm.nih.gov/pubmed/22949489).” Circulation: Cardiovascular Quality and Outcomes (2012): CIRCOUTCOMES-112.; - Background- Focuses on disparity between hospital readmission rates, evidence for patient characteristics and hospital practices as key indicators of readmission risk (top 2 reasons for readmission failure or infection)

8. Search for systematic reviews currently under development (includes forthcoming reviews & protocols) Date Searched:
A. Required sources: | Evidence:
PROSPERO (SR registry) Date: 3/29/17 | http://www.crd.york.ac.uk/PROSPERO/ Search: readmission; readmit; mortality; post-operative care; wait time; delay; guideline compliance; infection Relevant Results: Stein Ove Danielsen, Irene Lie, Philip Moons, Iren Sandven. Incidence and causes of thirty-day readmission after surgical aortic valve replacement and transcatheter aortic valve implantation: a systematic review and meta-analysis. PROSPERO 2016:CRD42016032670 Available from http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=CRD42016032670 (http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=); - Discussion – review in progress - Rate of and reasons for readmission after surgery, focus on determining incidence for readmittance, mortality and predictors of complications, unclear if patient level factors only; James Bernatz. Thirty-day readmission rates in orthopedic and neurosurgical spinal surgeries: a systematic review and meta-analysis. PROSPERO 2014:CRD42014015319 Available from http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=CRD42014015319 (http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=); - KQ1 -identifies patient level causes for and rate of 30-day readmission for spinal surgery (focused on cost-reduction).; James Bernatz, Paul Anderson. Thirty-day readmission rates in orthopedics: a systematic review. PROSPERO 2014:CRD42014010293 Available from http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=CRD42014010293 (http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=); - KQ1-identifies rate of and 22 risk factors for 30-day readmission; focused on reducing rate of 30-day readmission. Patient level only; Maria Peer, Andrea Bailey, Peter Gallacher, Fiona Coutts, Nigel Gleeson. The effect of waiting time on physical function in patients undergoing total knee arthroplasty surgery: a systematic review of the literature. PROSPERO 2016:CRD42016037093 Available from http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=CRD42016037093 (http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=); - NA-focused on functionality during wait time before knee surgery; Christoph Röder, Thomas Klestil, Birgit Winkler, Christoph Stotter, Martin Lutz, Stefan Nehrer, Gerald Gartlehner, Barbara Nussbaumer-Streit, Gernot Wagner, Irma Klerings. Immediate versus delayed surgery for hip fractures in the geriatric population. PROSPERO 2017:CRD42017058216 Available from http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=CRD42017058216 (http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=); - Completion 28 February 2018- focused on geriatric hip surgery and wait times; James Masters. A systematic review of the epidemiology of surgical site infection in hip fracture surgery. PROSPERO 2017:CRD42017050685 Available from http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=CRD42017050685 (http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=); - Completion 30 September 2017- focused on SSI in hip fracture surgery
DoPHER (SR Protocols) Date: 3/29/17 | http://eppi.ioe.ac.uk/webdatabases4/Intro.aspx?ID=9 (http://eppi.ioe.ac.uk/webdatabases4/Intro.aspx?ID=) Search: readmission; readmit; mortality and surgery; post-operative care; wait time; delay; guideline compliance; infection Relevant Results: None
Cochrane Database of Systematic Reviews: Protocols Date: 3/29/17 | Database: EBM Reviews - Cochrane Methodology Register <3rd Quarter 2012> Search Strategy: ------------------------------------------------------------------------------- 1 quality measure*.mp. [mp=title, abstract, subject heading word] (22) 2 performance measure*.mp. [mp=title, abstract, subject heading word] (13) 3 outcome measure*.mp. [mp=title, abstract, subject heading word] (766) 4 quality indicator*.mp. [mp=title, abstract, subject heading word] (25) 5 performance indicator*.mp. [mp=title, abstract, subject heading word] (6) 6 outcome indicator*.mp. [mp=title, abstract, subject heading word] (2) 7 1 or 2 or 3 or 4 or 5 or 6 (825) 8 surg*.mp. [mp=title, abstract, subject heading word] (805) 9 7 and 8 (65) *************************** Relevant Results: None

### APPENDIX C LIST OF EXCLUDED STUDIES

Exclude reasons: B=Relevant for background information only, 1=Ineligible population, 2=Ineligible intervention, 3=Ineligible comparator, 4=Ineligible outcome, 5=Ineligible timing, 6=Ineligible study design, 7=Ineligible publication type 8=Outdated or ineligible systematic review, 9=Non-English language

# | Citation | Exclude reason
1 | Agabiti N, Cesaroni G, Picciotto S, et al. The association of socioeconomic disadvantage with postoperative complications after major elective cardiovascular surgery. J Epidemiol Community Health. Oct 2008;62(10):882-889. | B
2 | Agha R. Towards national surgical surveillance in the UK--a pilot study. PLoS ONE [Electronic Resource]. 2012;7(12):e47969. | 1
3 | Albright JM, Panzer RJ, Black ER, Mays RA, Lush-Ehmann CM. Reporting tools for clinical quality improvement. Clinical Performance & Quality Health Care. 1993;1(4):227-232. | 4
4 | Al-Khatib SM, Hellkamp A, Curtis J, et al. Non-evidence-based ICD implantations in the United States. JAMA. Jan 05 2011;305(1):43-49. | 4
5 | Al-Momany NH, Al-Bakri AG, Makahleh ZM, Wazaify MM. Adherence to international antimicrobial prophylaxis guidelines in cardiac surgery: a Jordanian study demonstrates need for quality improvement. J Manage Care Pharm. Apr 2009;15(3):262-271. | 4
6 | Alverson BK, O'Callaghan J. Hospital readmission: quality indicator or statistical inevitability? Pediatrics. Sep 2013;132(3):569-570. | 1
7 | Amato L, Colais P, Davoli M, et al. [Volume and health outcomes: evidence from systematic reviews and from evaluation of Italian hospital data]. Epidemiologia e Prevenzione. 2013;37(2-3 Suppl 2):1-100. | 9
8 | Anderson DJ, Chen LF, Sexton DJ, Kaye KS. Complex surgical site infections and the devilish details of risk adjustment: important implications for public reporting. Infection Control & Hospital Epidemiology. Oct 2008;29(10):941-946. | 4
9 | Andreasen JJ, Korsager B, Alstrup P, Jepsen OB. Postoperative wound infection: indicator of clinical quality? Dan Med Bull. Aug 2002;49(3):242-244. | 4
10 | Andruszkow H, Scharff B, Zapf A, et al. [Influence of comorbidities and delay in surgical treatment on mortality following femoral neck fracture]. Z Orthop Unfall. Aug 2013;151(4):338-342. | 9
11 | Angus DC. Grappling with intensive care unit quality--does the readmission rate tell us anything? Critical Care Medicine. Nov 1998;26(11):1779-1780. | 1
12 | Anonymous. Rewarding quality--the highest- and lowest-scored hospitals. Combined penalty/reward based on FY 2016 readmissions penalty, value-based purchasing reward/penalty and hospital-acquired conditions (HAC) score. Mod Healthc. Dec 21-28 2015;45(51):34. | 7
13 | Ashby E, Haddad FS, O'Donnell E, Wilson AP. How will surgical site infection be measured to ensure “high quality care for all”? Journal of Bone & Joint Surgery - British Volume. Sep 2010;92(9):1294-1299. | B
14 | Ashton CM, Del Junco DJ, Souchek J, Wray NP, Mansyur CL. The association between the quality of inpatient care and early readmission: a meta-analysis of the evidence. Medical Care. Oct 1997;35(10):1044-1059. | B
15 | Ashton CM, Wray NP. A conceptual framework for the study of early readmission as an indicator of quality of care. Soc Sci Med. Dec 1996;43(11):1533-1541. | B
16 | Ashton HA, Buxton MJ, Day NE, et al. The Multicentre Aneurysm Screening Study (MASS) into the effect of abdominal aortic aneurysm screening on mortality in men: a randomised controlled trial. Lancet. Nov 16 2002;360(9345):1531-1539. | B
17 | Atkinson G, Giovanis T. Conceptual errors in the CMS refusal to make socioeconomic adjustments in readmission and other quality measures. J Ambulatory Care Manage. Jul-Sep 2014;37(3):269-272. | 7
18 | Awad N, Caputo FJ, Carpenter JP, Alexander JB, Trani JL, Lombardi JV. Relative value unit-based compensation incentivization in an academic vascular practice improves productivity with no early adverse impact on quality. Journal of Vascular Surgery. 2017;65(2):579-582. | 2
19 | Axon RN, Cole L, Moonan A, et al. Evolution and Initial Experience of a Statewide Care Transitions Quality Improvement Collaborative: Preventing Avoidable Readmissions Together. Popul Health Manag. Feb 2016;19(1):4-10. | 1
20 | Babaev A, Frederick PD, Pasta DJ, et al. Trends in management and outcomes of patients with acute myocardial infarction complicated by cardiogenic shock. JAMA: Journal of the American Medical Association. 2005;294(4):448-454. | 2
21 | Balla U, Malnick S, Schattner A. Early readmissions to the department of medicine as a screening tool for monitoring quality of care problems. Medicine (Baltimore). Sep 2008;87(5):294-300. | 1
22 | Basta MN, Bauder AR, Kovach SJ, Fischer JP. Assessing the predictive accuracy of the American College of Surgeons National Surgical Quality Improvement Project Surgical Risk Calculator in open ventral hernia repair. American Journal of Surgery. Aug 2016;212(2):272-281. | 1
23 | Bates OL, O'Connor N, Dunn D, Hasenau SM. Applying STAAR interventions in incremental bundles: improving post-CABG surgical patient care. Worldviews on Evidence-Based Nursing. 2014;11(2):89-97. | B
24 | Bautista M, Llinas A, Bonilla G, et al. Thromboprophylaxis after major orthopedic surgery: Improving compliance with clinical practice guidelines. Thromb Res. Jan 2016;137:113-118. | 4
25 | Benbassat J, Taragin M. Hospital readmissions as a measure of quality of health care: advantages and limitations. Archives of Internal Medicine. Apr 24 2000;160(8):1074-1081. | B
26 | Bernatz JT, Anderson PA. Thirty-day readmission rates in spine surgery: systematic review and meta-analysis. Neurosurg Focus. Oct 2015;39(4):E7. | 4
27 | Bernatz JT, Tueting JL, Hetzel S, Anderson PA. What Are the 30-day Readmission Rates Across Orthopaedic Subspecialties? Clinical Orthopaedics & Related Research. 2016;474(3):838-847. | B
28 | Bernheim SM. Measuring quality and enacting policy: readmission rates and socioeconomic factors. Circulation. Cardiovascular Quality & Outcomes. May 2014;7(3):350-352. | 7
29 | Bernstein SJ, Rigter H, Brorsson B, et al. Waiting for coronary revascularization: a comparison between New York State, The Netherlands and Sweden. Health Policy. Oct 1997;42(1):15-27. | 4
30 | Bertholf L. Clinical pathways from conception to outcome. Top Health Inf Manage. Nov 1998;19(2):30-34. | 4
31 | Borgi J, Rubinfeld I, Ritz J, Jordan J, Velanovich V. The differential effects of intermediate complications with postoperative mortality. American Surgeon. Mar 2013;79(3):261-266. | B
32 | Bottorff MB, Nutescu EA, Spinler S. Antiplatelet therapy in patients with unstable angina and non-ST-segment-elevation myocardial infarction: findings from the CRUSADE national quality improvement initiative. Pharmacotherapy. Aug 2007;27(8):1145-1162. | B
33 | Bougioukakis P, Kluegl SJ, Babin-Ebell J, et al. Presentation of a quality management program in off-pump coronary bypass surgery. Innovations. Jul-Aug 2014;9(4):317-321. | 4
34 | Bradley EH, Sipsma H, Curry L, Mehrotra D, Horwitz LI, Krumholz H. Quality collaboratives and campaigns to reduce readmissions: what strategies are hospitals using? J Hosp Med. Nov 2013;8(11):601-608. | 1
35 | Braybrooke J, Ahn H, Gallant A, et al. The impact of surgical wait time on patient-based outcomes in posterior lumbar spinal surgery. European Spine Journal. Nov 2007;16(11):1832-1839. | 4
36 | Brekke A, Elfenbein DM, Madkhali T, et al. When patients call their surgeon's office: an opportunity to improve the quality of surgical care and prevent readmissions. American Journal of Surgery. Mar 2016;211(3):599-604. | 1
37 | Brown EG, Burgess D, Li CS, Canter RJ, Bold RJ. Hospital readmissions: necessary evil or preventable target for quality improvement. Annals of Surgery. Oct 2014;260(4):583-589; discussion 589-591. | 1
38 | Brown SE, Ratcliffe SJ, Halpern SD. Assessing the utility of ICU readmissions as a quality metric: an analysis of changes mediated by residency work-hour reforms. Chest. Mar 2015;147(3):626-636. | 1
39 | Bruce J, Russell EM, Mollison J, Krukowski ZH. The quality of measurement of surgical wound infection as the basis for monitoring: a systematic review. Journal of Hospital Infection. 2001;49(2):99-108. | 4
40 | Burgess JF, Hockenberry JM. Can all cause readmission policy improve quality or lower expenditures? A historical perspective on current initiatives. Health Econ Policy Law. Apr 2014;9(2):193-213. | B
41 | Calderwood MS, Kleinman K, Bratzler DW, et al. Medicare Claims Can Be Used to Identify US Hospitals With Higher Rates of Surgical Site Infection Following Vascular Surgery. Medical Care. 2014;52(10):918-925. | 1
42 | Carrier M, Pineault R, Tremblay N, Pelletier LC. Outcome of rationing access to open-heart surgery: effect of the wait for elective surgery on patient outcome. CMAJ Canadian Medical Association Journal. Oct 15 1993;149(8):1117-1122. | 3
43 | Cebul RD, Snow RJ, Pine R, Hertzer NR, Norris DG. Indications, outcomes, and provider volumes for carotid endarterectomy. JAMA. 1998;279(16):1282-1287. | 4
44 | Cesena FH, Favarato D, Cesar LA, de Oliveira SA, da Luz PL. Cardiac complications during waiting for elective coronary artery bypass graft surgery: incidence, temporal distribution and predictive factors. European Journal of Cardio-Thoracic Surgery. Feb 2004;25(2):196-202. | 3
45 | Chambers M, Clarke A. Measuring readmission rates. BMJ. 1990;301(6761):1134-1136. | 1
46 | Chen J, Radford MJ, Wang Y, Marciniak TA, Krumholz HM. Do “America's Best Hospitals” perform better for acute myocardial infarction? New England Journal of Medicine. Jan 28 1999;340(4):286-292. | 1
47 | Chen JY, Ma Q, Chen H, Yermilov I. New bundled world: quality of care and readmission in diabetes patients. J Diabetes Sci Technol. May 01 2012;6(3):563-571. | 1
48 | Chen LM, Jha AK, Guterman S, Ridgway AB, Orav EJ, Epstein AM. Hospital cost of care, quality of care, and readmission rates: penny wise and pound foolish? Archives of Internal Medicine. Feb 22 2010;170(4):340-346. | 1
49 | Chen Q, Mull HJ, Rosen AK, Borzecki AM, Pilver C, Itani KM. Measuring readmissions after surgery: do different methods tell the same story? American Journal of Surgery. 2016;212(1):24-33. | B
50 | Chen Q, Tsai TC, Mull HJ, Rosen AK, Itani KM. Using a composite readmission measure to assess surgical quality in the Veterans Health Administration: how well does it correlate with established surgical measures? JAMA Surgery. Nov 2014;149(11):1206-1207. | 4
51 | Chiasson PM, Roy PD, Mitchell MJ, Chiasson AM, Alexander DI. Hip fracture surgery in Nova Scotia: a comparison of treatment provided by “generalist” general surgeons and orthopedic surgeons. Canadian Journal of Surgery. 1997;40(5):383-389. | 4
52 | Clancy CM. Commentary: reducing hospital readmissions: aligning financial and quality incentives. American Journal of Medical Quality. Sep-Oct 2012;27(5):441-443. | 7
53 | Clancy CM. New hospital readmission policy links financial and quality incentives. J Nurs Care Qual. Jan-Mar 2013;28(1):1-4. | 7
54 | Clarke A. Readmission to hospital: a measure of quality or outcome? Quality & Safety in Health Care. Feb 2004;13(1):10-11. | 7
55 | Cohn A. Readmission rates are a poor marker of quality. BMJ. Jan 29 2014;348:g1148. | 7
56 | Copeland LA, Graham LA, Richman JS, et al. A study to reduce readmissions after surgery in the Veterans Health Administration: design and methodology. BMC Health Services Research. 2017;17(1):198. | 7
57 | Croft AM, Lynch P, Smellie JS, Dickinson CJ. Outpatient waiting times: indicators of hospital performance? J R Army Med Corps. Oct 1998;144(3):131-137. | B
58 | Curran T, Zhang JQ, Lo RC, et al. Risk factors and indications for readmission after lower extremity amputation in the American College of Surgeons National Surgical Quality Improvement Program. Journal of Vascular Surgery. Nov 2014;60(5):1315-1324. | 4
59 | Dardick KR, Stein JA. Hospital readmissions and measures of quality. JAMA. Jan 25 2012;307(4):361; author reply 361-362. | 7
60 | Davenport DL, Zwischenberger BA, Xenos ES. Analysis of 30-day readmission after aortoiliac and infrainguinal revascularization using the American College of Surgeons National Surgical Quality Improvement Program data set. Journal of Vascular Surgery. Nov 2014;60(5):1266-1274. | 4
61 | Davies SM, Saynina O, McDonald KM, Baker LC. Limitations of using same-hospital readmission metrics. International Journal for Quality in Health Care. 2013;25(6):633-639. | B
62 | D'Errigo P, Tosti ME, Fusco D, Perucci CA, Seccareccia F, Research group ICOS. Use of hierarchical models to evaluate performance of cardiac surgery centres in the Italian CABG outcome study. BMC Med Res Methodol. Jul 03 2007;7:29. | B
63 | DesHarnais SI, Forthman MT, Homa-Lowry JM, Wooster LD. Risk-adjusted clinical quality indicators: indices for measuring and monitoring rates of mortality, complications, and readmissions.[Erratum appears in Qual Manag Health Care. 2001 Winter;9(2):ix]. Qual Manag Health Care. Fall 2000;9(1):14-22. | 7
64 | DesHarnais SI, Forthman MT, Homa-Lowry JM, Wooster LD. Risk-adjusted quality outcome measures: indexes for benchmarking rates of mortality, complications, and readmissions. Qual Manag Health Care. Winter 1997;5(2):80-87. | B
65 | Dimick JB, Ghaferi AA. Hospital readmission as a quality measure in surgery. JAMA. Feb 03 2015;313(5):512-513. | B
66 | Dixon JL, Papaconstantinou HT, Hodges B, et al. Redundancy and variability in quality and outcome reporting for cardiac and thoracic surgery. Baylor University Medical Center Proceedings. 2015;28(1):14-17. | B
67 | Dua A, Desai SS, Seabrook GR, et al. The effect of Surgical Care Improvement Project measures on national trends on surgical site infections in open vascular procedures. Journal of Vascular Surgery. Dec 2014;60(6):1635-1639. | B
68 | Dummit LA, Kahvecioglu D, Marrufo G, et al. Association Between Hospital Participation in a Medicare Bundled Payment Initiative and Payments and Quality Outcomes for Lower Extremity Joint Replacement Episodes. JAMA. 2016;316(12):1267-1278. | 4
69 | Edelstein AI, Lovecchio FC, Saha S, Hsu WK, Kim JY. Impact of Resident Involvement on Orthopaedic Surgery Outcomes: An Analysis of 30,628 Patients from the American College of Surgeons National Surgical Quality Improvement Program Database. Journal of Bone & Joint Surgery -American Volume. 2014;96(15):e131. | 4
70 | Edmiston CE, Spencer M, Lewis BD, et al. Reducing the risk of surgical site infections: did we really think SCIP was going to lead us to the promised land? Surg Infect (Larchmt). Jun 2011;12(3):169-177. | B
71 | Every NR, Fihn SD, Sales AE, Keane A, Ritchie JR. Quality Enhancement Research Initiative in ischemic heart disease: a quality initiative from the Department of Veterans Affairs. QUERI IHD Executive Committee. Medical Care. Jun 2000;38(6 Suppl 1):I49-59. | B
72 | Falcone RA, Nass C, Jermyn R, et al. The value of preoperative pharmacologic stress testing before vascular surgery using ACC/AHA guidelines: a prospective, randomized trial. Journal of Cardiothoracic & Vascular Anesthesia. Dec 2003;17(6):694-698. | 1
73 | Fielden JM, Cumming JM, Horne JG, Devane PA, Slack A, Gallagher LM. Waiting for hip arthroplasty: economic costs and health outcomes. Journal of Arthroplasty. Dec 2005;20(8):990-997. | 4
74 | Fink AS, Campbell DA, Jr., Mentzer RM, Jr., et al. The National Surgical Quality Improvement Program in non-veterans administration hospitals: initial demonstration of feasibility. Annals of Surgery. Sep 2002;236(3):344-353; discussion 353-344. | B
75 | Fischer C, Anema HA, Klazinga NS. The validity of indicators for assessing quality of care: a review of the European literature on hospital readmission rate. Eur J Public Health. Aug 2012;22(4):484-491. | 1
76 | Fischer C, Lingsma HF, Marang-van de Mheen PJ, Kringos DS, Klazinga NS, Steyerberg EW. Is the readmission rate a valid quality indicator? A review of the evidence. PLoS ONE [Electronic Resource]. 2014;9(11):e112282. | B
77 | Fischer C, Steyerberg EW, Fonarow GC, Ganiats TG, Lingsma HF. A systematic review and meta-analysis on the association between quality of hospital care and readmission rates in patients with heart failure. American Heart Journal. Nov 2015;170(5):1005-1017.e1002. | 1
78 | Folbert E, Smit R, van der Velde D, Regtuijt M, Klaren H, Hegeman JH. [Multidisciplinary integrated care pathway for elderly patients with hip fractures: implementation results from Centre for Geriatric Traumatology, Almelo, The Netherlands]. Ned Tijdschr Geneeskd. 2011;155(26):A3197. | 9
79 | Fortuna GR, Jr., Perlick A, DuBose JJ, et al. Injury grade is a predictor of aortic-related death among patients with blunt thoracic aortic injury. Journal of Vascular Surgery. May 2016;63(5):1225-1231. | 2
80 | Franzo A, Francescutti C, Simon G. Risk factors correlated with postoperative mortality for hip fracture surgery in the elderly: a population-based approach. Eur J Epidemiol. 2005;20(12):985-991. | 10
81 | Fry DE. Surgical site infections and the surgical care improvement project (SCIP): evolution of national quality measures. Surgical Infections. Dec 2008;9(6):579-584. | B
82 | Gani F, Lucas DJ, Kim Y, Schneider EB, Pawlik TM. Understanding Variation in 30-Day Surgical Readmission in the Era of Accountable Care: Effect of the Patient, Surgeon, and Surgical Subspecialties. JAMA Surgery. 2015;150(11):1042-1049. | 4
83 | Gao Y, Long A, Xie Z, et al. The compliance of thromboprophylaxis affects the risk of venous thromboembolism in patients undergoing hip fracture surgery. Springerplus. 2016;5(1):1362. | 3
84 | Garbuz DS, Xu M, Duncan CP, Masri BA, Sobolev B. Delays worsen quality of life outcome of primary total hip arthroplasty. Clinical Orthopaedics & Related Research. Jun 2006;447:79-84. | 4
85 | Gharacholou SM, Alexander KP, Chen AY, et al. Implications and reasons for the lack of use of reperfusion therapy in patients with ST-segment elevation myocardial infarction: findings from the CRUSADE initiative. American Heart Journal. May 2010;159(5):757-763. | 1
86 | Gholson JJ, Pugely AJ, Bedard NA, Duchman KR, Anthony CA, Callaghan JJ. Can We Predict Discharge Status After Total Joint Arthroplasty? A Calculator to Predict Home Discharge. Journal of Arthroplasty. 2016;31(12):2705-2709. | 4
87 | Gholve PA, Kosygan KP, Sturdee SW, Faraj AA. Multidisciplinary integrated care pathway for fractured neck of femur. A prospective trial with improved outcome. Injury. Jan 2005;36(1):93-98; discussion 99. | 4
88 | Gibbons C, Bruce J, Carpenter J, et al. Identification of risk factors by systematic review and development of risk-adjusted models for surgical site infection. Health Technology Assessment (Winchester, England). 2011;15(30):1-156, iii-iv. | 4
89 | Gibson A, Tevis S, Kennedy G. Readmission after delayed diagnosis of surgical site infection: a focus on prevention using the American College of Surgeons National Surgical Quality Improvement Program. American Journal of Surgery. Jun 2014;207(6):832-839. | 1
90 | Gibson PH, Croal BL, Cuthbertson BH, et al. Socio-economic status and early outcome from coronary artery bypass grafting. Heart. May 2009;95(10):793-798. | 4
91 | Girotti ME, Shih T, Dimick JB. Health policy update: rethinking hospital readmission as a surgical quality measure. JAMA Surgery. Aug 2014;149(8):757-758. | B
92 | Gjertsson P, Caidahl K, Oden A, Bech-Hanssen O. Diagnostic and referral delay in patients with aortic stenosis is common and negatively affects outcome. Scandinavian Cardiovascular Journal. Jan 2007;41(1):12-18. | 3
93 | Glebova NO, Bronsert M, Hammermeister KE, et al. Drivers of readmissions in vascular surgery patients. Journal of Vascular Surgery. 2016;64(1):185-194.e183. | 4
94 | Glebova NO, Bronsert M, Hicks CW, et al. Contributions of planned readmissions and patient comorbidities to high readmission rates in vascular surgery patients. Journal of Vascular Surgery. 2016;63(3):746-755.e742. | 4
95 | Gonzalez AA, Girotti ME, Shih T, Wakefield TW, Dimick JB. Reliability of hospital readmission rates in vascular surgery. Journal of Vascular Surgery. 2014;59(6):1638-1643. | B
96 | Grover FL. The Society of Thoracic Surgeons National Database: current status and future directions. Annals of Thoracic Surgery. Aug 1999;68(2):367-373; discussion 374-366. | B
97 | Grumbach K, Anderson GM, Luft HS, Roos LL, Brook R. Regionalization of cardiac surgery in the United States and Canada. Geographic access, choice, and outcomes. JAMA. Oct 25 1995;274(16):1282-1288. | 4
98 | Gupta PK, Fernandes-Taylor S, Ramanan B, Engelbert TL, Kent KC. Unplanned readmissions after vascular surgery. Journal of Vascular Surgery. 2014;59(2):473-482. | 4
99 | Guru V, Anderson GM, Fremes SE, et al. The identification and development of Canadian coronary artery bypass graft surgery quality indicators. Journal of Thoracic & Cardiovascular Surgery. 2005;130(5):1257. | B
100 | Hajat S, Fitzpatrick R, Morris R, et al. Does waiting for total hip replacement matter? Prospective cohort study. Journal of Health Services & Research Policy. Jan 2002;7(1):19-25. | 4
101 | Halfon P, Eggli Y, Pretre-Rohrbach I, Meylan D, Marazzi A, Burnand B. Validation of the potentially avoidable hospital readmission rate as a routine indicator of the quality of hospital care. Medical Care. Nov 2006;44(11):972-981. | B
102 | Han S, Smith TS, Gunnar W. Descriptive analysis of 30-day readmission after inpatient surgery discharge in the Veterans Health Administration. JAMA Surgery. 2014;149(11):1162-1168. | B
103 | Hannan EL, Kilburn H, Jr., Racz M, et al. Improving the outcomes of coronary artery bypass surgery in New York State. JAMA: Journal of the American Medical Association. 1994;271(10):761-766. | B
104 | Hannan EL, Sarrazin MS, Doran DR, Rosenthal GE. Provider profiling and quality improvement efforts in coronary artery bypass graft surgery: the effect on short-term mortality among Medicare beneficiaries. Medical Care. Oct 2003;41(10):1164-1172. | B
105 | Hansen LS, Hjortdal VE, Andreasen JJ, Mortensen PE, Jakobsen CJ. 30-day mortality after coronary artery bypass grafting and valve surgery has greatly improved over the last decade, but the 1-year mortality remains constant. Annals of Cardiac Anaesthesia. Apr-Jun 2015;18(2):138-142. | B
106 | Harpole DH, Jr., DeCamp MM, Jr., Daley J, et al. Prognostic models of thirty-day mortality and morbidity after major pulmonary resection. Journal of Thoracic & Cardiovascular Surgery. May 1999;117(5):969-979. | 1
107 | Hawn MT, Vick CC, Richman J, et al. Surgical site infection prevention: time to move beyond the surgical care improvement program. Annals of Surgery. Sep 2011;254(3):494-499; discussion 499-501. | 4
108 | Head SJ, da Costa BR, Beumer B, et al. Adverse events while awaiting myocardial revascularization: a systematic review and meta-analysis. Eur J Cardiothorac Surg. May 02 2017. | 3
109 | Hollenbeak CS, Bowman AR, Harbaugh RE, Casale PN, Han D. The impact of surgical specialty on outcomes for carotid endarterectomy. Journal of Surgical Research. 2010;159(1):595-602. | 4
110 | Holt PJ, Poloniecki JD, Hofman D, Hinchliffe RJ, Loftus IM, Thompson MM. Re-interventions, readmissions and discharge destination: modern metrics for the assessment of the quality of care. Eur J Vasc Endovasc Surg. Jan 2010;39(1):49-54. | 4
111 | Horwitz LI, Lin Z, Herrin J, et al. Association of hospital volume with readmission rates: a retrospective cross-sectional study.[Erratum appears in BMJ. 2015;350:h895 Note: Hines, Harold J Jr [added]; PMID: 25689984]. BMJ. 2015;350:h447. | 1
112 | Horwitz LI, Partovian C, Lin Z, et al. Development and use of an administrative claims measure for profiling hospital-wide performance on 30-day unplanned readmission. Annals of Internal Medicine. 2014;161(10 Suppl):S66-75. | B
113 | Hsu RB, Lin CH. Surgical proficiency and quality indicators in off-pump coronary artery bypass. Annals of Thoracic Surgery. Dec 2013;96(6):2069-2074. | 4
114 | Huesch MD. Provider-hospital “fit” and patient outcomes: evidence from Massachusetts cardiac surgeons, 2002-2004.[Erratum appears in Health Serv Res. 2011 Apr;46(2):690]. Health Services Research. 2011;46(1 Pt 1):1-26. | 4
115 | Hughes JS, Eisenhandler J, Goldfield N, Weinberg PG, Averill R. Postadmission sepsis as a screen for quality problems: a case-control study. American Journal of Medical Quality. Nov-Dec 2014;29(6):499-507. | 1
116 | Husni ME, Losina E, Fossel AH, Solomon DH, Mahomed NN, Katz JN. Decreasing medical complications for total knee arthroplasty: effect of critical pathways on outcomes. BMC Musculoskeletal Disorders. Jul 14 2010;11:160. | 4
117 | Hyder JA, Roy N, Wakeam E, et al. Performance measurement in surgery through the National Quality Forum. Journal of the American College of Surgeons. 2014;219(5):1037-1046. | B
118 | Iddriss A. Surgical-readmission rates and quality of care. New England Journal of Medicine. Dec 19 2013;369(25):2460. | B
119 | Improta G, Balato G, Romano M, et al. Lean Six Sigma: a new approach to the management of patients undergoing prosthetic hip replacement surgery. Journal of Evaluation in Clinical Practice. 2015;21(4):662-672. | 4
120 | Ingraham AM, Cohen ME, Bilimoria KY, et al. Association of surgical care improvement project infection-related process measure compliance with risk-adjusted outcomes: implications for quality measurement. Journal of the American College of Surgeons. Dec 2010;211(6):705-714. | B
121 | Jackson NW, Doogue MP, Elliott JM. Priority points and cardiac events while waiting for coronary bypass surgery. Heart. Apr 1999;81(4):367-373. | 3
122 | Johnson ML, Gordon HS, Petersen NJ, et al. Effect of definition of mortality on hospital profiles. Medical Care. Jan 2002;40(1):7-16. | B
123 | Johnston LE, Robinson WP, Tracci MC, et al. Vascular Quality Initiative and National Surgical Quality Improvement Program registries capture different populations and outcomes in open infrainguinal bypass. Journal of Vascular Surgery. Sep 2016;64(3):629-637. | 1
124 | Judge A, Chard J, Learmonth I, Dieppe P. The effects of surgical volumes and training centre status on outcomes following total joint replacement: analysis of the Hospital Episode Statistics for England. Journal of Public Health. 2006;28(2):116-124. | 4
125 | Kangovi S, Grande D. Hospital readmissions--not just a measure of quality. JAMA. Oct 26 2011;306(16):1796-1797. | 7
126 | Kao LS, Lew DF, Doyle PD, et al. A tale of 2 hospitals: a staggered cohort study of targeted interventions to improve compliance with antibiotic prophylaxis guidelines. Surgery. Aug 2010;148(2):255-262. | 1
127 | Kelly-Pettersson P, Samuelsson B, Muren O, et al. Waiting time to surgery is correlated with an increased risk of serious adverse events during hospital stay in patients with hip-fracture: A cohort study. Int J Nurs Stud. Apr 2017;69:91-97. | 3
128 | Keswani A, Tasi MC, Fields A, Lovy AJ, Moucha CS, Bozic KJ. Discharge Destination After Total Joint Arthroplasty: An Analysis of Postdischarge Outcomes, Placement Risk Factors, and Recent Trends. Journal of Arthroplasty. 2016;31(6):1155-1162. | 4
129 | Keswani A, Weiser MC, Shin J, Lovy AJ, Moucha CS. Discharge Destination After Revision Total Joint Arthroplasty: An Analysis of Postdischarge Outcomes and Placement Risk Factors. Journal of Arthroplasty. 2016;31(9):1866-1872.e1861. | 4
130 | Khanna R, McDevitt JL, McClendon J, Jr., Smith ZA, Dahdaleh NS, Fessler RG. Utility of Readmission Rates as a Quality of Care Measure and Predictors of Readmission Within 30 Days After Spinal Surgery: a Single-Center, Multivariate Analysis. Spine. Nov 2015;40(22):1769-1774. | B
131 | Khuri SF, Daley J, Henderson WG. The comparative assessment and improvement of quality of surgical care in the Department of Veterans Affairs. Archives of Surgery. Jan 2002;137(1):20-27. | B
132 | Khuri SF, Henderson WG, Daley J, et al. Successful implementation of the Department of Veterans Affairs' National Surgical Quality Improvement Program in the private sector: the Patient Safety in Surgery study. Annals of Surgery. Aug 2008;248(2):329-336. | B
133 | Khuri SF, Henderson WG, Daley J, et al. The patient safety in surgery study: background, study design, and patient populations. Journal of the American College of Surgeons. Jun 2007;204(6):1089-1102. | B
134 | Kisloff B. Surgical-readmission rates and quality of care. New England Journal of Medicine. Dec 19 2013;369(25):2460. | B
135 | Knudtson ML, Beanlands R, Brophy JM, et al. Treating the right patient at the right time: access to specialist consultation and non-invasive testing. Canadian Journal of Cardiology. Aug 2006;22(10):819-824. | 1
136 | Kocher RP, Adashi EY. Hospital readmissions and the Affordable Care Act: paying for coordinated quality care. JAMA. Oct 26 2011;306(16):1794-1795. | 7
137 | Konstantinidis A, Fogel S, Jones J, Gilliam B, Kundzins J, Baker C. Use of the national surgical quality improvement program to reduce surgical mortality: implementation of intensive preoperative screening and intervention. American Surgeon. Sep 2014;80(9):896-900. | 1
138 | Kristensen PK, Thillemann TM, Soballe K, Johnsen SP. Can improved quality of care explain the success of orthogeriatric units? A population-based cohort study. Age & Ageing. Jan 2016;45(1):66-71. | 4
139 | Kumar G. Protocol-guided hip fracture management reduces length of hospital stay. Br J Hosp Med (Lond). Nov 2012;73(11):645-648 | 2
140 | Kurki TS. Prediction of outcome in cardiac surgery. Mt Sinai J Med. Jan-Mar 2002;69(1-2):68-72. | 4
141 | Kurtz SM, Lau EC, Ong KL, Adler EM, Kolisek FR, Manley MT. Which Clinical and Patient Factors Influence the National Economic Burden of Hospital Readmissions After Total Joint Arthroplasty? Clinical orthopaedics and related research. 2017. | 4
142 | Lancey R, Kurlansky P, Argenziano M, et al. Uniform standards do not apply to readmission following coronary artery bypass surgery: a multi-institutional study. Journal of Thoracic & Cardiovascular Surgery. 2015;149(3):850-857.e851; discussion 857. | 4
143 | Lau RL, Perruccio AV, Gandhi R, Mahomed NN. The role of surgeon volume on patient outcome in total knee arthroplasty: a systematic review of the literature. BMC Musculoskeletal Disorders. 2012;13:250. | 4
144 | Lavernia CJ, Villa JM, Iacobelli DA. Readmission rates in the state of Florida: a reflection of quality? Clinical Orthopaedics & Related Research. Dec 2013;471(12):3856-3862. | 4
145 | Lawson EH, Hall BL, Louie R, et al. Association between occurrence of a postoperative complication and readmission: implications for quality improvement and cost savings. Annals of Surgery. Jul 2013;258(1):10-18. | 4
146 | Lee JD, Bonaros N, Hong PT, et al. Factors influencing hospital length of stay after robotic totally endoscopic coronary artery bypass grafting. Annals of Thoracic Surgery. Mar 2013;95(3):813-818. | 4
147 | Lim R, Kreidieh I, Dymond D, et al. Is the waiting list a safe place for outpatients awaiting coronary bypass surgery? Health Trends. 1991;23(4):149-152. | 3
148 | Lingard EA, Berven S, Katz JN, Kinemax Outcomes G. Management and care of patients undergoing total knee arthroplasty: variations across different health care settings. Arthritis Care & Research. Jun 2000;13(3):129-136. | 4
149 | Lucas DJ, Haut ER, Hechenbleikner EM, Wick EC, Pawlik TM. Avoiding immortal time bias in the American College of Surgeons National Surgical Quality Improvement Program readmission measure. JAMA Surgery. Aug 2014;149(8):875-877. | B
150 | Makela KT, Hakkinen U, Peltola M, Linna M, Kroger H, Remes V. The effect of hospital volume on length of stay, re-admissions, and complications of total hip arthroplasty. Acta Orthopaedica. 2011;82(1):20-26. | 4
151 | Maniar HS, Bell JM, Moon MR, et al. Prospective evaluation of patients readmitted after cardiac surgery: analysis of outcomes and identification of risk factors. Journal of Thoracic & Cardiovascular Surgery. 2014;147(3):1013-1018. | 2
152 | Manoharan SR, Baker DK, Pasara SM, Ponce B, Deinlein D, Theiss SM. Thirty-day readmissions following adult spinal deformity surgery: an analysis of the National Surgical Quality Improvement Program (NSQIP) database. Spine Journal: Official Journal of the North American Spine Society. 2016;16(7):862-866. | 4
153 | March LM, Cameron ID, Cumming RG, et al. Mortality and morbidity after hip fracture: can evidence based clinical pathways make a difference? Journal of Rheumatology. Sep 2000;27(9):2227-2231. | 2
154 | Markley J, Sabharwal K, Wang Z, Bigbee C, Whitmire L. A community-wide quality improvement project on patient care transitions reduces 30-day hospital readmissions from home health agencies. Home Healthc Nurse. Mar 2012;30(3):E1-E11. | 1
155 | Marshall DA, Christiansen T, Smith C, et al. Continuous quality improvement program for hip and knee replacement. American Journal of Medical Quality. 2015;30(5):425-431. | B
156 | Martin CT, Gao Y, Pugely AJ. Incidence And Risk Factors For 30-Day Readmissions After Hip Fracture Surgery. Iowa Orthopaedic Journal. 2016;36:155-160. | 4
157 | Marufu TC, White SM, Griffiths R, Moonesinghe SR, Moppett IK. Prediction of 30-day mortality after hip fracture surgery by the Nottingham Hip Fracture Score and the Surgical Outcome Risk Tool. Anaesthesia. May 2016;71(5):515-521. | 4
158 | Maslow J, Hutzler L, Slover J, Bosco J, 3rd. Etiology of Readmissions Following Orthopaedic Procedures and Medical Admissions. A Comparative Analysis. Bulletin of the Hospital for Joint Disease (2013). 2015;73(4):269-275. | B
159 | Matsen FA, 3rd, Li N, Gao H, Yuan S, Russ SM, Sampson PD. Factors Affecting Length of Stay, Readmission, and Revision After Shoulder Arthroplasty: A Population-Based Study.[Erratum appears in J Bone Joint Surg Am. 2015 Sep 2;97(17):e60; PMID: 26333745]. Journal of Bone & Joint Surgery - American Volume. 2015;97(15):1255-1263. | 4
160 | Maxwell BG, Wong JK, Miller DC, Lobato RL. Temporal changes in survival after cardiac surgery are associated with the thirty-day mortality benchmark. Health Services Research. 2014;49(5):1659-1669. | B
161 | Mazzeffi M, Lin HM, Flynn BC. Socioeconomic position is not associated with 30-day or 1-year mortality in demographically diverse vascular surgery patients. Journal of Cardiothoracic & Vascular Anesthesia. Jun 2012;26(3):420-426. | 1
162 | Mazzocato P, Unbeck M, Elg M, Skoldenberg OG, Thor J. Unpacking the key components of a programme to improve the timeliness of hip-fracture care: a mixed-methods case study. Scand J Trauma Resusc Emerg Med. Nov 09 2015;23:93. | 4
163 | McCormack R, Michels R, Ramos N, Hutzler L, Slover JD, Bosco JA. Thirty-day readmission rates as a measure of quality: causes of readmission after orthopedic surgeries and accuracy of administrative data. Journal of Healthcare Management. Jan-Feb 2013;58(1):64-76; discussion 76-67. | B
164 | McCutcheon BA, Ciacci JD, Marcus LP, et al. Thirty-Day Perioperative Outcomes in Spinal Fusion by Specialty Within the NSQIP Database. Spine. 2015;40(14):1122-1131. | 4
165 | McKinney M. Laying the groundwork for quality: Hospital engagement networks--call them HENs--tasked with ambitious goals for reducing readmissions and hospital-acquired conditions. Mod Healthc. May 21 2012;42(21):28-30. | 7
166 | Meehan TP, Sr., Qazi DJ, Van Hoof TJ, et al. Process Evaluation of a Quality Improvement Project to Decrease Hospital Readmissions From Skilled Nursing Facilities. Journal of the American Medical Directors Association. Aug 01 2015;16(8):648-653. | 1
167 | Merkow RP, Ju MH, Chung JW, et al. Underlying reasons associated with hospital readmission following surgery in the United States. JAMA. 2015;313(5):483-495. | 4
168 | Metcalfe D, Salim A, Olufajo O, et al. Hospital case volume and outcomes for proximal femoral fractures in the USA: an observational study. BMJ Open. 2016;6(4):e010743. | 4
169 | Miliani K, L'Heriteau F, Astagneau P, Group INS. Non-compliance with recommendations for the practice of antibiotic prophylaxis and risk of surgical site infection: results of a multilevel analysis from the INCISO Surveillance Network. Journal of Antimicrobial Chemotherapy. Dec 2009;64(6):1307-1315. | 4
170 | Miller DC, Ye Z, Gust C, Birkmeyer JD. Anticipating the effects of accountable care organizations for inpatient surgery. JAMA Surgery. 2013;148(6):549-554. | 4
171 | Minhas SV, Kester BS, Lovecchio FC, Bosco JA. Nationwide 30-Day Readmissions After Elective Orthopedic Surgery: Reasons and Implications. Journal for Healthcare Quality. 2017;39(1):34-42. | 4
172 | Mitchell PM, Gavrilova SA, Dodd AC, Attum B, Obremskey WT, Sethi MK. The impact of resident involvement on outcomes in orthopedic trauma: An analysis of 20,090 cases. Journal of Clinical Orthopaedics & Trauma. 2016;7(4):229-233. | 4
173 | Miyata H, Motomura N, Ueda Y, Matsuda H, Takamoto S. Effect of procedural volume on outcome of coronary artery bypass graft surgery in Japan: implication toward public reporting and minimal volume standards. Journal of Thoracic & Cardiovascular Surgery. 2008;135(6):1306-1312. | 4
174 | Miyata H, Motomura N, Ueda Y, Tsukihara H, Tabayashi K, Takamoto S. Toward quality improvement of thoracic aortic surgery: estimating volume-outcome effect from nationwide survey. European Journal of Cardio-Thoracic Surgery. 2009;36(3):517-521. | 4
175 | Montin L, Leino-Kilpi H, Suominen T, Lepisto J. A systematic review of empirical studies between 1966 and 2005 of patient outcomes of total hip arthroplasty and related factors. J Clin Nurs. Jan 2008;17(1):40-45. | 4
176 | Moro ML, Sommella L, Gialli M, et al. Surgical infections surveillance: results of a six-month incidence study in two Italian hospitals.[Erratum appears in Eur J Epidemiol 1992 May;8(3):484 Note: Masini R [corrected to Masetti R]]. Eur J Epidemiol. Nov 1991;7(6):641-648. | 4
177 | Morris MS, Deierhoi RJ, Richman JS, Altom LK, Hawn MT. The relationship between timing of surgical complications and hospital readmission. JAMA surgery. 2014;149(4):348-354. | 4
178 | Morris MS, Graham LA, Richman JS, et al. Postoperative 30-day Readmission: Time to Focus on What Happens Outside the Hospital. Annals of Surgery. 2016;264(4):621-631. | 4
179 | Moscelli G, Siciliani L, Tonei V. Do waiting times affect health outcomes? Evidence from coronary bypass. Soc Sci Med. 2016;161:151-159. | 3
180 | Muntz J. Duration of deep vein thrombosis prophylaxis in the surgical patient and its relation to quality issues. American Journal of Surgery. 2010;200(3):413-421. | 4
181 | Nakazawa KR, Egorova NN, Power JR, Faries PL, Vouyouka AG. The Impact of Surgical Care Improvement Project Measures on In-Hospital Outcomes following Elective Vascular Procedures. Annals of Vascular Surgery. Jan 2017;38:17-28. | 1
182 | Neuman MD, Archan S, Karlawish JH, Schwartz JS, Fleisher LA. The relationship between short-term mortality and quality of care for hip fracture: a meta-analysis of clinical pathways for hip fracture. Journal of the American Geriatrics Society. 2009;57(11):2046-2054. | 2
183 | Neuman MD, Wirtalla C, Werner RM. Association between skilled nursing facility quality indicators and hospital readmissions. JAMA. Oct 15 2014;312(15):1542-1551. | 1
184 | O'Brien SM, Shahian DM, DeLong ER, et al. Quality measurement in adult cardiac surgery: part 2--Statistical considerations in composite measure scoring and provider rating. Annals of Thoracic Surgery. Apr 2007;83(4 Suppl):S13-26. | 4
185 | Okike K, Peter-Bibb TK, Xie KC, Okike ON. Association Between Physician Online Rating and Quality of Care. J Med Internet Res. Dec 13 2016;18(12):e324. | 4
186 | Osborne NH, Nicholas LH, Ryan AM, Thumma JR, Dimick JB. Association of hospital participation in a quality reporting program with surgical outcomes and expenditures for Medicare beneficiaries. JAMA. 2015;313(5):496-504. | 1
187 | Osswald BR, Tochtermann U, Schweiger P, et al. Minimal early mortality in CABG--simply a question of surgical quality? Thoracic & Cardiovascular Surgeon. Oct 2002;50(5):276-280. | B
188 | Owen RM, Perez SD, Bornstein WA, Sweeney JF. Impact of surgical care improvement project inf-9 on postoperative urinary tract infections: do exemptions interfere with quality patient care? Archives of Surgery. Oct 2012;147(10):946-953. | 1
189 | Paxton EW, Inacio MC, Singh JA, Love R, Bini SA, Namba RS. Are There Modifiable Risk Factors for Hospital Readmission After Total Hip Arthroplasty in a US Healthcare System? Clinical Orthopaedics & Related Research. 2015;473(11):3446-3455. | 4
190 | Penson DF. Re: variation in surgical-readmission rates and quality of hospital care. Journal of Urology. May 2014;191(5):1363-1364. | B
191 | Pollock FH, Bethea A, Samanta D, Modak A, Maurer JP, Chumbe JT. Readmission within 30 days of discharge after hip fracture care. Orthopedics. 2015;38(1):e7-13. | 4
192 | Ponce B, Raines BT, Reed RD, Vick C, Richman J, Hawn M. Surgical Site Infection After Arthroplasty: Comparative Effectiveness of Prophylactic Antibiotics: Do Surgical Care Improvement Project Guidelines Need to Be Updated? Journal of Bone & Joint Surgery - American Volume. 2014;96(12):970-977. | 4
193 | Press MJ, Scanlon DP, Ryan AM, et al. Limits of readmission rates in measuring hospital quality suggest the need for added metrics. Health Aff (Millwood). Jun 2013;32(6):1083-1091. | 1
194 | Pujol N, Merrer J, Lemaire B, et al. Unplanned return to theater: A quality of care and risk management index? Orthopaedics & traumatology, surgery & research. 2015;101(4):399-403. | 4
195 | Pull ter Gunne AF, Hosman AJ, Cohen DB, et al. A methodological systematic review on surgical site infections following spinal surgery: part 1: risk factors. Spine. 2012;37(24):2017-2033. | 4
196 | Rice S. Readmission penalties have experts queasy about quality measures. Mod Healthc. Aug 10 2015;45(32):8. | 1
197 | Riegel B, Gates DM, Gocka I, et al. Effectiveness of a program of early hospital discharge of cardiac surgery patients.[Erratum appears in J Cardiovasc Nurs 1997 Apr;11(3):1]. Journal of Cardiovascular Nursing. Oct 1996;11(1):63-75. | 2
198 | Rolfson O, Wissig S, van Maasakkers L, et al. Defining an International Standard Set of Outcome Measures for Patients With Hip or Knee Osteoarthritis: Consensus of the International Consortium for Health Outcomes Measurement Hip and Knee Osteoarthritis Working Group. Arthritis care & research. 2016;68(11):1631-1639. | B
199 | Rumball-Smith J, Blakely T, Sarfati D, Hider P. The mismeasurement of quality by readmission rate: how blunt is too blunt an instrument?: a quantitative bias analysis. Medical Care. May 2013;51(5):418-424. | 1
200 | Rumball-Smith J, Hider P, Graham P. The readmission rate as an indicator of the quality of elective surgical inpatient care for the elderly in New Zealand. New Zealand Medical Journal. Feb 13 2009;122(1289):32-39. | 4
201 | Rumball-Smith J, Hider P. The validity of readmission rate as a marker of the quality of hospital care, and a recommendation for its definition. New Zealand Medical Journal. Feb 13 2009;122(1289):63-70. | 1
202 | Rumball-Smith J, Sarfati D, Hider P, Blakely T. Ethnic disparities in the quality of hospital care in New Zealand, as measured by 30-day rate of unplanned readmission/death. International Journal for Quality in Health Care. Jul 2013;25(3):248-254. | 1
203 | Saleh KJ, Bozic KJ, Graham DB, et al. Quality in orthopaedic surgery--an international perspective: AOA critical issues. Journal of Bone & Joint Surgery - American Volume. 2013;95(1):e3. | B
204 | Saleh KJ, Wood KC, Gafni A, Gross AE. Immediate surgery versus waiting list policy in revision total hip arthroplasty. An economic evaluation. J Arthroplasty. Jan 1997;12(1):1-10. | 4
205 | Sampalis J, Boukas S, Liberman M, Reid T, Dupuis G. Impact of waiting time on the quality of life of patients awaiting coronary artery bypass grafting. CMAJ Canadian Medical Association Journal. Aug 21 2001;165(4):429-433. | 4
206 | Samuel AM, Fu MC, Toy JO, et al. Most 30-day Readmissions After Anterior Cervical Discectomy and Fusion Are Not Due to Surgical Site-Related Issues: An Analysis of 17,088 Patients. Spine. 2016;41(23):1801-1807. | B
207 | Sanagou M, Wolfe R, Forbes A, Reid CM. Hospital-level associations with 30-day patient mortality after cardiac surgery: a tutorial on the application and interpretation of marginal and multilevel logistic regression. BMC Med Res Methodol. Mar 12 2012;12:28. | 4
208 | Sandvik D, Bade P, Dunham A, Hendrickson S. A hospital-to-nursing home transfer process associated with low hospital readmission rates while targeting quality of care, patient safety, and convenience: a 20-year perspective. Journal of the American Medical Directors Association. May 2013;14(5):367-374. | 1
209 | Sari I, Acar Z, Nurkalem Z, et al. Preoperative clinical status but not waiting time predicts in-hospital outcomes of surgery in patients with left main coronary artery stenosis. Tohoku J Exp Med. Oct 2007;213(2):173-180. | 3
210 | Saucedo J, Marecek GS, Lee J, Huminiak L, Stulberg SD, Puri L. How accurately are we coding readmission diagnoses after total joint arthroplasty? Journal of Arthroplasty. 2013;28(7):1076-1079. | B
211 | Schattner A. Thirty-day readmission rates and hospital quality. Int J Clin Pract. Jan 2014;68(1):139. | 1
212 | Seabrook GR. Does rigorous quality process reporting guarantee superior-quality health care? JAMA: Journal of the American Medical Association. 2013;310(3):316-317. | 7
213 | Sechriest 2nd VF, Carney JR, Kuskowski MA, et al. Incidence of knee sepsis after ACL reconstruction at one institution: the impact of a clinical pathway. Journal of Bone & Joint Surgery, American Volume. 2013;95(9):843-849. | 4
214 | Sellers MM, Merkow RP, Halverson A, et al. Validation of new readmission data in the American College of Surgeons National Surgical Quality Improvement Program. Journal of the American College of Surgeons. Mar 2013;216(3):420-427. | B
215 | Shahian DM, Meyer GS, Mort E, et al. Association of National Hospital Quality Measure adherence with long-term mortality and readmissions. BMJ Quality & Safety. Apr 2012;21(4):325-336. | B
216 | Sherman SL, Lyman S, Koulouvaris P, Willis A, Marx RG. Risk factors for readmission and revision surgery following rotator cuff repair. Clinical Orthopaedics & Related Research. 2008;466(3):608-613. | 4
217 | Shih T, Dimick JB. Reliability of readmission rates as a hospital quality measure in cardiac surgery. Annals of Thoracic Surgery. Apr 2014;97(4):1214-1218. | B
218 | Sibley RA, Charubhumi V, Hutzler LH, Paoli AR, Bosco JA. Joint Replacement Volume Positively Correlates With Improved Hospital Performance on Centers for Medicare and Medicaid Services Quality Metrics. Journal of arthroplasty. 2016;24. | 4
219 | Silber S, Muhling H, Dorr R, Zindler G, Preuss A, Stumpfl A. [Waiting times and death on the waiting list for coronary artery bypass operation. Experiences in Munich with over 1,000 patients]. Herz. Dec 1996;21(6):389-396. | 9
220 | Slamowicz R, Erbas B, Sundararajan V, Dharmage S. Predictors of readmission after elective coronary artery bypass graft surgery. Australian Health Review. Nov 2008;32(4):677-683. | 3
221 | Suhm N, Kaelin R, Studer P, et al. Orthogeriatric care pathway: a prospective survey of impact on length of stay, mortality and institutionalisation. Arch Orthop Trauma Surg. Sep 2014;134(9):1261-1269. | 4
222 | Sund R, Liski A. Quality effects of operative delay on mortality in hip fracture treatment. Quality & Safety in Health Care. Oct 2005;14(5):371-377.
223 | Takaro T, Ankeney JL, Laning RC, Peduzzi PN. Quality control for cardiac surgery in the Veterans Administration. Annals of Thoracic Surgery. Jul 1986;42(1):37-44. | 4
224 | Tepas JJ, 3rd, Kerwin AJ, deVilla J, Nussbaum MS. Macro vs micro level surgical quality improvement: a regional collaborative demonstrates the case for a national NSQIP initiative. Journal of the American College of Surgeons. Apr 2014;218(4):599-604. | 1
225 | Thakur NM. Readmission as an indicator of quality of care. Am J Psychiatry. Mar 1998;155(3):449-450. | 7
226 | Thalji NM, Suri RM, Greason KL, Schaff HV. Risk assessment methods for cardiac surgery and intervention. Nat Rev Cardiol. Dec 2014;11(12):704-714. | 7
227 | Toy JO, Basques BA, Grauer JN. Morbidity, mortality, and readmission after vertebral augmentation: analysis of 850 patients from the American College of Surgeons National Surgical Quality Improvement Program database. Spine. Nov 01 2014;39(23):1943-1949. | 4
228 | Travis J, Carr JB, Saylor D, et al. Coronary artery bypass graft surgery: surgical site infection prevention. Journal for Healthcare Quality: Promoting Excellence in Healthcare. 2009;31(4):16-23. | 2
229 | Troeng T, Janzon L. Are in-hospital deaths and long stay markers for errors in surgery? Qual Assur Health Care. 1990;2(2):149-159. | 1
230 | Tsai TC, Jha AK. Surgical-readmission rates and quality of care. New England Journal of Medicine. Dec 19 2013;369(25):2460-2461. | B
231 | Tully PJ, Baumeister H, Bennetts JS, Rice GD, Baker RA. Depression screening after cardiac surgery: A six month longitudinal follow up for cardiac events, hospital readmissions, quality of life and mental health. Int J Cardiol. Mar 01 2016;206:44-50. | 4
232 | Tuominen U, Sintonen H, Hirvonen J, et al. Is longer waiting time for total knee replacement associated with health outcomes and medication costs? Randomized clinical trial (Structured abstract). Value In Health. 2010 2015;13(8). | 4
233 | Tuominen U, Sintonen H, Aronen P, et al. Cost-utility of waiting time in total joint replacements: a randomized clinical trial. Int J Technol Assess Health Care. Jan 2013;29(1):27-34. | 4
234 | Turnbull RG, Taylor DC, Hsiang YN, et al. Assessment of patient waiting times for vascular surgery. Canadian Journal of Surgery. Apr 2000;43(2):105-111. | 1
235 | van der Boon RM, Nuis RJ, Benitez LM, et al. Frequency, determinants and prognostic implications of infectious complications after transcatheter aortic valve implantation. American Journal of Cardiology. Jul 01 2013;112(1):104-110. | 4
236 | Van Herck P, Vanhaecht K, Deneckere S, et al. Key interventions and outcomes in joint arthroplasty clinical pathways: a systematic review. Journal of Evaluation in Clinical Practice. 2010;16(1):39-49. | 4
237 | van Walraven C. The Utility of Unplanned Early Hospital Readmissions as a Health Care Quality Indicator. JAMA Intern Med. Nov 2015;175(11):1812-1814. | B
238 | Vaughan-Sarrazin M, Bayman L, Rosenthal G, Henderson W, Hendricks A, Cullen JJ. The business case for the reduction of surgical complications in VA hospitals. Surgery. 2011;149(4):474-483. | 4
239 | Veeravagu A, Patil CG, Lad SP, Boakye M. Risk factors for postoperative spinal wound infections after spinal decompression and fusion surgeries. Spine. Aug 01 2009;34(17):1869-1872. | 4
240 | Vest JR, Gamm LD, Oxford BA, Gonzalez MI, Slawson KM. Determinants of preventable readmissions in the United States: a systematic review. Implementation Science. 2010;5:88. | B
241 | Wakeam E, Hyder JA, Tsai TC, Lipsitz SR, Orgill DP, Finlayson SR. Complication timing and association with mortality in the American College of Surgeons' National Surgical Quality Improvement Program database. Journal of Surgical Research. Jan 2015;193(1):77-87. | 1
242 | Wang R, Cheng N, Xiao CS, et al. Optimal Timing of Surgical Revascularization for Myocardial Infarction and Left Ventricular Dysfunction. Chinese Medical Journal. 20th Feb 2017;130(4):392-397. | 3
243 | Weissman JS, Ayanian JZ, Chasan-Taber S, Sherwood MJ, Roth C, Epstein AM. Hospital readmissions and quality of care. Medical Care. May 1999;37(5):490-501. | 1
244 | Wennberg DE, Lucas FL, Birkmeyer JD, Bredenberg CE, Fisher ES. Variation in carotid endarterectomy mortality in the Medicare population: trial hospitals, volume, and patient characteristics. JAMA. 1998;279(16):1278-1281. | 4
245 | Williams SC, Koss RG, Morton DJ, Loeb JM. Performance of top-ranked heart care hospitals on evidence-based process measures. Circulation. Aug 08 2006;114(6):558-564. | 1
246 | Wilson GC, Cutler Quillin R, 3rd, Sutton JM, et al. Factors related to readmission after major elective surgery. Digestive Diseases & Sciences. 2015;60(1):47-53. | 4
247 | Wilson J, Charlett A, Leong G, McDougall C, Duckworth G. Rates of surgical site infection after hip replacement as a hospital performance indicator: analysis of data from the English mandatory surveillance system. Infection Control & Hospital Epidemiology. Mar 2008;29(3):219-226. | 4
248 | Wish JB. The role of 30-day readmission as a measure of quality. Clin J Am Soc Nephrol. Mar 2014;9(3):440-442. | 1
249 | Wojkowska-Mach J, Bulanda M, Jaje E, et al. The risk related to surgical site infections after hip endoarthroplasty--surveillance outcome analysis in two Polish orthopaedic centres. Ortop. May-Jun 2009;11(3):253-263. | 4
250 | Woldhek AL, Rijkenberg S, Bosman RJ, van der Voort PH. Readmission of ICU patients: A quality indicator? Journal of Critical Care. 2017;38:328-334. | 1
251 | Wong DR, Ali IS, Torchiana DF, Agnihotri AK, Bohmer RM, Vander Salm TJ. Learning in a new cardiac surgical center: an analysis of precursor events. Surgery. Feb 2009;145(2):131-137. | 4
252 | Worth LJ, Bull AL, Thorpe SM, Richards MJ. Meeting national recommendations for surgical site infection surveillance: examples and lessons from the Victorian Healthcare-associated Infection Surveillance System. Healthcare Infection. 2009;14(3):119-122. | 4
253 | Wortman PM, Smyth JM, Langenbrunner JC, Yeaton WH. Consensus among experts and research synthesis. A comparison of methods. International Journal of Technology Assessment in Health Care. 1998;14(1):109-122. | 3
254 | Xing D, Ma JX, Ma XL, et al. A methodological, systematic review of evidence-based independent risk factors for surgical site infections after spinal surgery. European Spine Journal. 2013;22(3):605-615. | 4
255 | Yanamadala S, Morrison D, Curtin C, McDonald K, Hernandez-Boussard T. Electronic Health Records and Quality of Care: An Observational Study Modeling Impact on Mortality, Readmissions, and Complications. Medicine (Baltimore). May 2016;95(19):e3332. | B
256 | Young B, Ng TM, Teng C, Ang B, Tai HY, Lye DC. Nonconcordance with surgical site infection prevention guidelines and rates of surgical site infections for general surgical, neurological, and orthopedic procedures. Antimicrob Agents Chemother. Oct 2011;55(10):4659-4663. | 4
257 | Yu S, Garvin KL, Healy WL, Pellegrini Jr VD, Iorio R. Preventing hospital readmissions and limiting the complications associated with total joint arthroplasty. Journal of the American Academy of Orthopaedic Surgeons. 2015;23(11):e60-e71. | 4
258 | Zhang JQ, Curran T, McCallum JC, et al. Risk factors for readmission after lower extremity bypass in the American College of Surgeons National Surgery Quality Improvement Program. Journal of Vascular Surgery. 2014;59(5):1331-1339. | 1

### APPENDIX D EVIDENCE TABLES

#### DATA ABSTRACTION: WAIT TIME (SYSTEMATIC REVIEWS)

Author Year Study Design | Population | Measure Details | Analytic Details | Findings | Setting; Timeframe
Hip fractures (elderly)
Leung 2010^10^ Systematic Review | Hip fracture in the elderly N= 42 observational studies | Comparison between no-delay vs delay to surgery (cut-off for wait time, mortality, and complications varied by study) | Adjustment between studies varied | Mortality: Mixed conclusions between studies Complications: Most studies show an association between increased wait time and complications Readmissions: NR | 1984-2009
Moja 2012^11^ Systematic Review | Hip fracture in the elderly N= 191,873 within 35 observational studies | Comparison between no-delay vs surgical delay (cut-off for wait time and mortality varied by study) | Adjusted for age, sex, year, study design, data source, study quality, location, baseline risk | Mortality: Association between decreased wait time and decreased all-cause mortality rate (combined unadjusted and adjusted) OR 0.74 (95% CI 0.67 to 0.81) Stratified by surgical delay (combined unadjusted and adjusted): ≤12 hours: OR 0.84 (95% CI 0.57 to 1.23) ≤24 hours: OR 0.74 (95% CI 0.62 to 0.87) ≤48 hours: OR 0.75 (95% CI 0.68 to 0.81) >96 hours: OR 0.67 (95% CI 0.39 to 1.13) Complications: NR Readmissions: NR | 1986-2011
Shiga 2008^12^ Systematic Review | Hip fracture in the elderly N= 257,367 within 16 observational studies | Comparison between wait time of ≤48-hours vs >48-hours | Adjustment between studies varied | Mortality: Association between increased wait time and increased 30-day mortality (unadjusted) OR 1.41 (95% CI 1.29 to1.54) Association between increased wait time and increased 1-year mortality (unadjusted) OR 1.32 (95% CI 1.21 to 1.43) Complications: NR Readmissions: NR | NR
Simunovic 2010^13^ Systematic Review | Hip fracture in the elderly N= 13,478 within 16 observational studies | Comparison between no-delay vs surgical delay (cut-off for wait time and complications varied by study) | Adjustment between studies was varied | Mortality: Association between decreased wait time and decreased all-cause mortality (adjusted) RR 0.81 (95% CI 0.68 to 0.96) Stratified by mortality cut-off point: 30-day mortality (unadjusted) RR 0.90 (95% CI 0.71 to 1.13) 3 to 6-month mortality (unadjusted) RR 0.87 (95% CI 0.44 to 1.72) 1-year mortality (unadjusted) RR 0.55 (95% CI 0.40 to 0.75) Complications: Pneumonia (unadjusted) RR 0.59 (95% CI 0.37 to 0.93) Pressure sores (unadjusted) RR 0.48 (95% CI 0.34 to 0.69) Deep vein thrombosis (unadjusted) RR 0.97 (95% CI 0.56 to 1.68) Pulmonary embolism (unadjusted) RR 0.66 (95% CI 0.17 to 2.58) Readmissions: NR | NR
Hip fracture (non-elderly)
Khan 2009^14^ Systematic Review | Hip fracture N= 291,413 within 52 observational studies | Comparison between no-delay vs delay to surgery (cut-off for wait time, mortality, and complications varied by study) | Adjustment between studies varied | Mortality: 10/24 studies showed an association between decreased wait time and decreased mortality (adjusted) 14/24 studies showed no association (adjusted) Complications: 6/11 studies showed an association between decreased wait time and decreased complications (adjusted) 5/11 studies showed no association (adjusted) Readmissions: NR | 1970-2007
Ankle fracture
Schepers 2013^15^ Systematic Review | Ankle fracture N= 11 observational studies | Comparison between no-delay vs surgical delay (cut-off for wait time and complications varied by study) | None | Mortality: NR Complications: Association between increased wait time and increased complications (unadjusted) OR 1.60 (95% CI 1.44 to 1.77) Readmissions: NR | 1988-2013

Table Abbreviations: CABG=coronary artery bypass grafting; CMS=Centers for Medicare & Medicaid Services; DRG=diagnosis-related group; DVT=deep vein thrombosis; EUROSCORE= European system for cardiac operative risk evaluation; HQA=Hospital Quality Alliance; HCFA=Health Care Financing Administration; HIQR=Hospital Inpatient Quality Reporting Program; LOS=length of stay; MI=myocardial infarction; MRSA=methicillin-resistant Staphylococcus aureus; NQF=National Quality Forum; NR=not reported; O/E=observed to expected; SCIP=Surgical Care Improvement Project; SSI=surgical site infection; STS=Society of Thoracic Surgeons; TJA=total joint arthroplasty; TKR=total knee replacement; THR=total hip replacement; VASQIP=Veterans Affairs Surgical Quality Improvement Program; VHA=Veterans Health Administration; VTE=venous thromboembolism

#### DATA ABSTRACTION: WAIT TIME (PRIMARY STUDIES)

Author Year Study Design | Population | Measure Details | Analytic Details | Findings | Setting; Timeframe
Cardiovascular surgery
Légaré 2005^16^ Prospective Cohort | CABG among patients with stenosis of the left main coronary artery N= 561 | Comparison between wait time within standard time or longer than standard time established for each triage level (emergent=0 days, in-hospital urgent=7 days, out-of-hospital semi-urgent A=21 days, out-of-hospital semi-urgent B=56 days) | Adjusted for propensity score, myocardial infarction within 7 days before surgery, preoperative renal failure, ejection fraction <40%, age >70 years, stenosis of left main coronary artery >70% | No statistically significant association between waiting longer than standard waiting time and composite score of in-hospital mortality, mechanical ventilation ≥ 24 hours postoperatively and postoperative length of stay > 9 days (adjusted) OR 0.7 (95% CI 0.4 to 1.2) No statistically significant association between queue assignment and out-of-hospital semi-urgent B for composite score Emergent: OR 2.5 (95% CI 0.95 to 6.5) In-hospital urgent: OR 0.9 (95% CI 0.4 to 1.9) Out-of-hospital semi-urgent A: OR 0.7 (95% 0.3 to 1.6) Complications: NR Readmissions: NR | 1 hospital in Halifax, Nova Scotia 1999-2003
Sobolev 2012^17^ Retrospective Cohort | CABG N= 9,593 | Comparison between wait time of short delay**,prolonged delay***, and excessive delay**** | Adjusted for risk score algorithm considering patient, clinical and surgical factors | Mortality: Statistically significant association between short delay and excessive delay for in-hospital mortality, but no association between prolonged delay and excessive delay (adjusted) Excessive delay (Reference) Prolonged delay OR 0.78 (95% CI 0.38 to 1.63) Short delay OR 0.32 (95% CI 0.20 to 0.51) Complications: NR Readmissions: NR | 4 cardiac centers in British Columbia 1992-2006
Hip fractures (elderly)
Meessen 2014^18^ Retrospective Cohort | Hip fracture in the elderly N= 828 | Comparison between wait time of ≤48 hours vs >48 hours | Adjusted for sex, age, Charlson comorbidity index | Mortality: No statistically significant association between wait time and 2-year all-cause mortality rate (Cox hazards analysis, adjusted) P>0.05 Complications: NR Readmissions: NR | Varese, Italy 2009
Holvik 2010^19^ Retrospective Cohort | Hip fracture in the elderly N= 567 | Comparison between wait time of ≤24 hours vs >24 hours | Adjusted for age, gender, pre-fracture residence (community or institution), number of comorbid conditions, severity of comorbidity, and number of medical complications observed during the stay | Mortality: No statistically significant association between wait time and 1-year all-cause mortality rate (adjusted) RR= 0.48 (95% CI 0.21 to 1.10) Complications: NR Readmissions: NR | Oslo, Norway 2007-2008
Karademir 2015^20^ Retrospective Cohort | Hip fracture in the elderly N= 115 | Comparison between wait time of ≤5 days vs >5 days | None | Mortality: No statistically significant association between wait time and 1-year all-cause mortality rate (unadjusted) P=0.5 Complications: NR Readmissions: NR | Istanbul, Turkey Timeframe NR
Hip fracture (non-elderly)
Clague 2002^21^ Retrospective Cohort | Hip fracture N= 462 | Comparison between wait time of ≤24-hours vs >24-hours | None | Mortality: No statistically significant association between wait time and in-hospital mortality rate (unadjusted) P>0.05 No statistically significant association between wait time and 90-day mortality rate (unadjusted) P> 0.05 Complications: NR Readmissions: NR | 1 UK hospital, 1996-1999
Griffiths 2013^22^ Retrospective Cohort | Hip fracture N= 60 | Comparison between wait time of ≤72-hours vs >72-hours | None | Mortality: No statistically significant association between wait time and 30-day mortality (unadjusted) P=0.2 Complications: Association between increased wait time and increased 30-day complications (unadjusted) P=0.008 Readmissions: NR | 1 UK hospital Timeframe NR
Lund 2014^23^ Retrospective Cohort | Hip fracture N= 6,143 | Stratified by wait time | None | Mortality: No statistically significant association between wait time and 1-year all-cause mortality rate (unadjusted) 0-12h: HR 1.00 (Reference) 12-24 hours: HR 0.89 (95% CI 0.78 to 1.01) 24-48 hours: HR 1.03 (95% CI 0.91 to 1.17) 48-72 hours: HR 1.02 (95% CI 0.84 to 1.24) 72-96 hours: HR 1.10 (95% CI 0.83 to 1.44) >96 hours: HR 1.05 (95% CI 0.81 to 1.36) Complications: NR Readmissions: NR | Danish Anaesthesia Database 2005-2007
Lurati-Buse 2014^24^ RCT | Hip fracture N= 60 | Comparison between accelerated care (medical clearance within 2 hrs of diagnosis) and standard care | None | Mortality: No statistically significant association between increased wait time and increased 30-day mortality (unadjusted) OR 0.22 (95% CI 0.02 to 2.14)* Complications: NR Readmissions: NR | 2 hospitals in Canada and 1 in India 2011-2012
Ryan 2015^25^ Retrospective Cohort | Hip fracture N= 2,121,215 | Stratified by wait time | Adjusted for age, gender, race, comorbidity burden, insurance status, day of admission, hospital factors size, teaching status, and region | Mortality: Association between increased wait time and increased in-hospital mortality (adjusted) 0-day: OR 1 (reference) 2-day: OR 1.14 (95% CI 1.06 to 1.23) ≥3-days: OR 1.34 (95% CI 1.23 to 1.46) Complications: Association between increased wait time and increased in-hospital complications (adjusted) 0-day: OR 1 (reference) 1-day: OR 1.09 (95% CI 1.06 to 1.12) 2-day: OR 1.33 (95% CI 1.29 to 1.39) ≥3-days: OR 2.08 (95% CI 2.00 to 2.16) Readmissions: NR | US National Inpatient Sample, 2000-2009
Ankle fracture
Tennent 2001^26^ Retrospective Cohort | Ankle fracture N= 47 | Comparison between wait time of ≤14-days vs >14-days | None | Mortality: NR Complications: Association between increased wait time and increased infection rate (unadjusted) ≤14-days < 50% >14-days = 50% Readmissions: NR | 2 UK hospitals
Other fractures
Vallier 2013^27^ Retrospective Cohort | Pelvis, acetabulum, femur, or spine fractures N= 1005 | Comparison between wait time of ≤24-hours vs >24-hours | Adjusted for age, injury severity, and the presence/severity of chest and/or abdominal injury | Mortality: NR Complications: Association between decreased wait time and decreased complication rate (adjusted) OR 0.731 (95% CI 0.546 to 0.986) Readmissions: NR | 1 US hospital, 2005-2013

Abbreviations: *= ESP Calculated; **= within 2 weeks for semiurgent and 6 weeks for nonurgent procedures; ***= within 6 for semi-urgent and 12 weeks for nonurgent procedures; ****= longer than 6 weeks for semi-urgent and 12 weeks for non-urgent procedures; CCS= Canadian Cardiac Society

#### DATA ABSTRACTION: READMISSIONS

Author Year Study Design | Population | Measure Details | Analytic Details | Findings | Setting; Timeframe
Hannan 2011^28^ Retrospective Cohort | CABG N= 33,936 | Risk-adjusted hospital 30-day readmissions | Stepwise logistic regression, adjusted for patient, procedure, and hospital factors. | Process Measures: NR Mortality: Association with risk-adjusted 30-day hospital mortality rates (r=0.32, P=0.047), and with hospital risk-adjusted mortality rate in highest tertile (r=0.38, P=0.03) Complications: NR | NY State Cardiac Surgery Reporting System, 2005-2007
Hannan 2003^29^ Retrospective Cohort | CABG N= 16,325 | Risk adjusted hospital 30-day readmissions | Stepwise logistic regression, adjusted for patient, procedure, and hospital factors. | Process Measures: NR Mortality: No statistically significant association with overall hospital risk-adjusted mortality rate (r=0.09, P=0.64), but association with hospital RAMR in highest tertile, OR 1.14 (95% CI 1.03 to 1.25) Complications: NR | NY State Cardiac Surgery Reporting System, 1999
Parina 2015^30^ Retrospective Cohort | CABG N= 296,063 | Risk-adjusted 30-day readmission Considered high or low outliers if 95% CIs of O/E ratio excluded 1; classified ‘discordant’ if readmission and mortality rates were not both high or both low. | Risk-adjustment for age, race, sex, LOS, Charlson index | Process Measures: NR Mortality: No association with overall mortality, among outliers 85% were discordant (CABG discordance rate: 78.3%) Complications: NR | 299 hospitals in CA, 1995-2009
Stefan 2013^31^ Retrospective Cohort | Cardiac and Vascular N= 73,573 Orthopedic N= 205,526 | 30-day risk standardized readmission rate | Predicted/expected ratio, standardized by overall mean; predicted calculated using hierarchical generalized linear models, adjusted for patient-level factors | Process Measures: Orthopedic: association for overall measure (r=-0.06; P=0.003) and appropriate care measure (r=-0.05, P=0.03) (care measures made up of SCIP measures) Cardiac + vascular: no association with overall or appropriate care measure Mortality: NR Complications: NR | CMS HIQR program, 2007
Thomas 1996^32^ Retrospective Cohort | CABG N= 4,261 | Risk-adjusted, O/E unplanned, 30-, 60-, and 90-day readmissions | Stepwise logistic regression adjusted for patient age, sex, severity, complexity, LOS, and clinical variables | Process Measures: No relationship between CABG 30-day O/E readmissions and poor quality; Charts peer-reviewed based on set of HCFA-specified generic quality screens to evaluate care provided as acceptable or problematic Mortality: NR Complications: NR | Medicare data from Michigan hospitals, 1989-1991
Tsai 2013^33^ Retrospective Cohort | CABG N= 153,496 Hip replacement N= 206,175 | Hospital-level Composite of procedure-specific risk-adjusted 30-day readmission rates | Multivariate adjustment for patient and hospital characteristics | Mortality: CABG: Readmission rate in highest mortality quartile=18.1% vs the group of lowest quartile-third quartile=17.3%-17.4% (P=0.013) Hip replacement: Readmission rate in highest mortality quartile=11.7% vs the group of lowest quartile-third quartile=10.2-10.9% (P<0.001) Process Measures: HQA surgical score - based on SCIP process measures CABG: No statistically significant difference in readmission with HQA surgical score quartile (P=0.751) Hip replacement: No statistically significant difference in readmission with HQA surgical score quartile (P=0.193) Complications: NR | National Medicare data, 2009-2010
Zitser-Gurevich 1999^34^ Prospective Cohort | CABG N=4,835 | First readmission within 100 days of CABG operation | Hospital mortality rank based on risk-adjusted 30-day mortality rates. Logistic modeling with 61 explanatory variables including patient characteristics, operative factors, and post-operative variables | Process Measures: NR Mortality: High mortality ranked hospitals had higher rates of readmission (OR=1.34, P=0.003) Complications: NR | National study of 14 hospitals: Israel 1994

#### DATA ABSTRACTION: ADHERENCE TO SURGICAL STANDARDS

Author Year Study Design | Population | Measure Details | Analytic Details | Findings | Setting; Timeframe
Auerbach 2009^35^ Retrospective Cohort | CABG N= 81,289 | Proportion of patients who failed to receive recommended SCIP measures (# of missed measures). | 30-day mortality adjusted for age, gender, DRG, comorbidities, hospital volume). | Mortality: 3 missed measures vs none missed OR 1.54 (95% CI 1.20 to 1.98), 4 or more missed measures vs none missed OR 1.63 (95% CI 1.24 to 2.15). Complications: NR Readmissions: No statistically significant association between # of missed measures and adjusted readmission (4 or more missed vs none OR 1.02 (95% CI 0.93 to 1.13). | 164 US hospitals participating in Perspective database, 2003-2005
Bhattacharyya 2009^36^ Retrospective Cohort | Hip or knee replacement N= NR | Composite score of 3 measures of surgical process quality and 3 measures of surgical outcome per CMS guidelines (based on NQF). Performance tiers calculated by deciles of hospital performance. | Inpatient mortality (no information on risk adjustment). Iatrogenic complications and urinary tract infection risk-adjusted. Readmissions (no information on risk adjustment) | Mortality: No statistically significant difference in mortality across hospital tiers, but trend toward higher rate of mortality in tier 4 (lowest quality) hospitals (r=0.116, P=0.088) Complications: No significant association of complications with hospital tier (data NR). Readmissions: Readmission avoidance index did not differ between top 20% hospitals and other hospitals (P=0.488). | CMS Hospital Quality Initiative Demonstration, 2003
Brinkman 2014^37^ Retrospective Cohort | CABG N= 506,110 | Adherence to use of preoperative beta-blocker within 24 hours preceding surgery (NQF). | Operative mortality (during procedure or within 30 days of procedure) adjusted for age, body surface area, race, sex, comorbidities, prior operations, year of surgery, hospital effects. | Mortality: No statistically significant association with operative mortality: OR 0.96 (95% CI 0.88 to 1.04). Complications: Association of beta-blocker use with increased atrial fibrillation: OR 1.09 (95% CI 1.06 to 1.12). No association with other complications (stroke, prolonged ventilation, reoperation, renal failure). Readmissions: NR | 1,107 centers from STS database, 2008-2012
Cotogni 2017^38^ Prospective Cohort | Cardiac surgery N= 741 | Adherence to prophylactic vancomycin administration timing protocol | Operative mortality or infection (during procedure or within 30 days of procedure) adjusted for age, EuroSCORE logistic, intensive care unit LOS, mechanical ventilation timing | Mortality: Association of increased mortality with protocol violation: OR 10.16 (95% CI 2.48 to 41.58) Complications: Association of increased SSI with protocol violation: OR 7.03 (95% CI 3.41 to 14.52) Readmissions: NR | 1 hospital in Turin, Italy, Time NR
Kim 2012^39^ Retrospective Cohort | Hip or knee arthroplasty N= 356 Spine surgery N= 537 | Adherence to national guideline recommended surgical antibiotic prophylaxis (SAP) (antibiotic selection, timing and duration). | Before after implementation (2007 -2nd phase) of national hospital evaluation program. No information on adjustment for confounders. | Mortality: NR Complications: Improved adherence to SAP guidelines (P<0.01) but no statistically significant changes in SSI rate, arthroplasty (P=0.44), spine surgery (P=0.28). Readmissions: NR | 6 hospitals in Korea, 2006-2008
Kurlansky 2012^40^ Retrospective Cohort | CABG N= 2,218 | Total quality score (0 to 5) based on number of NQF process measures achieved. A score of 5=high-quality care. | Major morbidity (stroke, renal failure, reoperation, sternal infection, and prolonged ventilation) adjusted for hospital volume and STS risk score. | Mortality: NR Complications: Low quality score associated with increased stroke OR 1.51 (95% CI 1.18 to 1.93), reoperation OR 1.65 (95% CI 1.25 to 2.16), prolonged ventilation OR 1.54 (95% CI 1.21 to 1.96), and renal failure OR 1.91 (95% CI 1.09 to 3.35). No association with sternal infection. Readmissions: NR | 5 cardiac surgery programs associated with Columbia University, 2007-2009
LaPar 2014^41^ Retrospective Cohort | Cardiac N= 1,703 | Adherence to SCIP measure of maintenance of 6am blood glucose levels on post-operative days 1 and 2 | STS risk-adjusted operative mortality (during procedure or within 30 days of procedure), composite major morbidity and complications. | Mortality: No statistically significant association with SCIP measure failure vs no failure: OR 1.49 (95% CI 0.54 to 4.09). Complications: No statistically significant association with SCIP measure failure vs no failure for major morbidity (OR 1.51, 95% CI 0.86 to 2.67), and major sternal complications (OR 1.58, 95% CI 0.18 to 13.7). Readmissions: NR | University of Virginia Hospital, 2010-2012
McDonnell 2013^42^ Retrospective Cohort | Cardiac N= 832 66% CABG | SCIP outliers (non-control of blood glucose at 6am on postoperative days 1 and 2) | 30-day mortality, complications (MI, infections), adjusted for serum creatinine level | Mortality: SCIP measure failure=1.8% vs compliant=1.7%; P=0.55 Complications: No statistically significant association with SCIP measure failure and complications: MI (1.8% vs 1.4%, p=0.52), stroke (1.8% vs 0.9%, p=0.39), deep sternal infection (0% vs 0.4%, p=1.00), multisystem failure (1.8% vs 0.9%, p=0.43), atrial fibrillation (16.3% vs 30.3%, p=0.05). Readmissions: NR | Boston University Medical Center, 2008-2011
Rasouli 2013^43^ Retrospective Cohort | TJA N= 23,907 | Before and after implementation of SCIP (adherence > 98% post implementation) | SSI rates within 1 year of index surgery. Adjusted for type of surgery, location, SCIP measures. | Mortality: NR Complications: After implementation, superficial SSI increased (P=0.05) and rate of deep SSI decreased (P=0.46). No change in DVT (P=0.51) and rate of PE increased (P=0.002). Readmissions: NR | Rothman Institute of Orthopedics, 2000-2009
Schelenz 2005^44^ Retrospective Cohort | Cardiac N= 3,988 | Before and after implementation of the 1998 UK national guidelines for the control of MRSA in hospitals and US guidelines on the control of SSI and infections in theatres. | MRSA rates 16 months before and after the intervention. Unadjusted. | Mortality: NR Complications: After implementation, there was a decrease in patients acquiring MRSA on ward (RR 0.41, 95% CI 0.23 to 0.76) Readmissions: NR | 1 London hospital, 1999-2002
Wang 2012^45^ Retrospective Cohort | Hip arthroplasty N= 17,714 | Highly compliant hospitals (> median level of compliance) vs less compliant hospitals (≤ median level of compliance) to SCIP measures | Hospital-level SS rates and patient level postoperative infection. Adjusted for patient, hospital and surgery variables | Mortality: NR Complications: Increased post-operative infection rates (OR 1.50, 95% CI 1.07 to 2.12) and hospital-level SSIs (OR 1.91, 95%CI 1.31 to 2.79) with higher adherence to SCIP VTE-2 prevention measure. No association with other SCIP adherence measures Readmissions: NR | 128 New York state hospitals, 2008

#### DATA ABSTRACTION: MORTALITY

Author Year Study Design | Population | Measure Details | Findings | Setting; Timeframe
Guru 2008^46^ Retrospective Cohort | CABG N= 347 | All-cause, risk-adjusted, in-hospital mortality and proportion of preventable deaths | No statistically significant correlation between all-cause-risk adjusted mortality rates and proportion of preventable deaths at hospital level (Spearman coefficient=-0.42, P=0.26) | Cardiac Care Network of Ontario, 1998-2003
Smith 2016^47^ Retrospective Cohort | Multiple N= 236,125 | Risk-adjusted 30-day mortality risk deciles | Distinct early survival risk pattern in highest risk decile for cardiac and orthopedic surgery with separation from all other deciles (eFigure, data NR) | VASQIP, 2011-2013

#### DATA ABSTRACTION: MEASUREMENT BURDEN AND UNINTENDED EFFECTS

Author Year | Performance Measure | Measurement Burden | Unintended Effects
Auerbach 2009^35^ | Adherence to surgical standard | Lack of documentation of measures may be a concern. Electronic billing systems have not been validated for measure collection. Mortality and readmissions only at index hospital. Measures inpatient adherence only and cannot account for post-discharge factors | NR
Bhattacharyya 2009^36^ | Adherence to surgical standard | Limited distribution of the composite measure scores required calculation to 4th decimal place to separate hospitals into deciles Numerous steps in performance of surgery difficult to evaluate and centrally report Administrative costs of collecting, analyzing and reporting these measures have not been reported Some deviation from standards may be clinically appropriate - not captured in measure Unknown whether individual measures have good distribution and ceiling effects to be able to distinguish between high and low performance | NR
Brinkman 2014^37^ | Adherence to surgical standard | STS database collects perioperative beta-blocker use as “yes/no” field - cannot ascertain timing, dose, or other related covariates Adherence is low - some surgeons disagree with use in specific patients (ie, some cases of off-pump revascularization) May only be clinically beneficially in specific patients - measure does not specify which patients | Giving beta-blockers to patients who might not benefit, might have harms
Clague 2002^21^ | Wait time | Presumably easily modifiable process measure Shorter and longer admission time may be beneficial to different subgroups - different measures would need to be applied to different subgroups of patients | NR
Griffiths 2013^22^ | Wait time | Difficult to determine whether delay to surgery was due to necessary medical optimization or due to non-patient factors such as surgeon or implant availability | NR
Guru 2008^46^ | Mortality | Reporting all-cause mortality does not account for the proportion that were not preventable Preventable deaths identified by chart reviews and adverse event audits - not a normally publicly reported measure (all-cause mortality reported on quality report card) All-cause mortality does not provide the level of detail required for quality improvement Preventable deaths measure is subjective - made by experts or hospital reviewers | NR
Hannan 2011^28^ | Readmission | Patient vs system measures are more predictive of 30-day readmissions. Comorbidities, preoperative and other risk factors should be considered in readmission predictors - ie, BMI was not previously considered, but is significant in this study – indicates rise in obesity. | NR
Hannan 2003^29^ | Readmission | Insufficient investigation of 30-day readmission outcome measure in the CABG literature, mortality is most commonly researched measure. Readmission=delayed complication, therefore risk-adjusted complication measure would complement, risk-adjusted mortality | Insurers may not reimburse early readmissions Hospitals may game the system and delay readmittance beyond 30 days.
Kim 2012^39^ | Adherence to surgical standard | NR | NR
Khan 2009^14^ | Wait time | Frailer patients may be more likely to be delayed (more time for assessment, correction of physiologic imbalances, etc) and may induce confounding which is difficult to account for (centrally collected database may have limited information on confounding variables) There may be different definitions of “delayed surgery” - substandard care not well defined | NR
Kurlansky 2012^40^ | Adherence to surgical standard | Surgical standards need to be surgery-specific (CABG) | NR
LaPar 2014^41^ | Adherence to surgical standard | SCIP measures fail to identify patients for whom improved outcomes and surgical quality might be achieved | NR
Leung 2010^10^ | Wait time | Can be difficult to ascertain cause of delay - which can influence outcomes | NR
Lund 2014^23^ | Wait time | Databases may lack information on guidelines and reasons for surgical delay Cut-off definitions of “early” or “late” surgery are variable | Requiring short surgical delay may influence timing of surgery (towards other shifts with less experienced surgeons and staff)
McDonnell 2013^42^ | Adherence to surgical standard | Single SCIP glucose measure not accurate depiction of glucose over time Hospital or program level committee required to implement and track SCIP measures Measure (blood glucose) is only a factor in outcomes for specific patients (with diabetes) | NR
Meessen 2014^18^ | Wait time | NR | NR
Moja 2012^11^ | Wait time | Using administrative databases may not be able to account for important confounding factors (comorbidities, etc) Difficult to ascertain reasons for surgical delay Different cut-off times used | NR
Parina 2015^30^ | Readmission | Quality indicators, like 30-day readmissions, are not well-defined or validated; no consensus on the definition of “quality”. 30-day readmission rates do not correlate closely with mortality and are therefore poor indicators of quality. New quality metric should be validated against a “gold standard”, hospital mortality rate. May be important to compare 30-day readmission to other quality outcomes (length of stay, patient safety indicators, various process measures). | NR
Rasouli 2013^43^ | Adherence to surgical standard | NR | NR
Ryan 2015^25^ | Wait time | Database may only have dates of admission and surgery - not possible to determine timing by hour | NR
Schepers 2013^15^ | Wait time | No information on reasons for postponing surgery | NR
Shiga 2008^12^ | Wait time | Causes of delay can be system or medically related - can't distinguish between them | NR
Simunovic 2010^13^ | Wait time | NR | NR
Smith 2016^47^ | Mortality | NR | Delay of intensive care management and end-of-life care to delay death beyond 30 days but not improving life expectancy or quality of care - unfounded claim in this study
Stefan 2013^31^ | Readmission | Statistically significant differences in risk-standardized 30-day readmission rate measures do not correspond to meaningful differences between high-and low-performing hospitals. | NR
Tennent 2001 | Wait time | NR | NR
Thomas 1996^32^ | Readmission | Readmission rate information is easily obtainable--bias toward using this as a quality measure. Readmission as a quality measure relies on assumptions: patients receiving good care will be stable before being discharged and patients who are not stabilized are more likely to be readmitted. | NR
Tsai 2013^33^ | Readmission | Readmission rates generally uncorrelated with other measures of hospital quality (ie, volume, mortality) Administrative data used to capture readmission may not capture other factors - need to do risk-adjustment | NR
Vallier 2013 | Wait time | Other injuries may influence timing or surgery | NR
Zitser-Gurevich 1999^34^ | Readmission | Readmission can be difficult to predict in models - making it difficult to identify high-risk patients and risk-adjust May be difficult to determine related and unrelated readmissions to index operation | NR

#### QUALITY ASSESSMENT: PRIMARY STUDIES

Author Year | Risk of selection bias? (yes/no/unclear) | Risk of performance bias? (yes/no/unclear) | Risk of detection bias? (yes/no/unclear) | Risk of bias due to confounding? (yes/no/unclear) | Risk of Attrition bias? (yes/no/unclear) | Risk of reporting bias? (yes/no/unclear) | Overall Quality (Good/Fair/Poor)
Auerbach 2009^35^ | No Perspective database. Regular auditing. Included all patients undergoing CABG during timeframe | No | No Regularly collected and maintained hospital data | No Analyses adjusted for patient and hospital level confounders | Unclear No comment on any missing data, but well-maintained database | No | Good
Bhattacharyya 2009^36^ | Unclear Data from CMS demonstration project, voluntary database; lacking data from lower 50% of hospitals | No | No Hospital collected and reported data | Unclear UTI risk-adjusted. Hematoma and readmissions not severity adjusted. | Unclear Hospitals in lowest tier were more likely to have missing data | No | Fair
Brinkman 2014^37^ | No Participation in STS database voluntary but covers almost all CABGs in US. Regular auditing. | No | No STS database | No Analysis adjusted for patient and hospital level confounders | No Excluded 0.08% for missing variables | No | Good
Cotogni 2017^38^ | No Eligibility criteria applied to all consecutive patients undergoing cardiac surgery for 1-year period | No | Unclear No information on how information was collected or outcome assessment | No Analyses adjusted for patient and surgical confounders | Unclear No patients lost to follow-up but no comment on any missing data | No | Fair
Guru 2008^46^ | No Randomly sampled deaths for 8 hospitals plus consecutive deaths for new hospital | No | Unclear Blinded reviewers, subjective outcome assessed by surgeon | Unclear Adjusted for patient characteristics only | Unclear No information on missing data or completeness of database | No | Fair
Hannan 2011^28^ | No New York administrative database (SPARCS). Regular auditing. | No | No Reasons for readmission were determined by ICD-9-CM | No Risk-adjusted for patient, surgical and hospital level variables | Unclear No comment on any missing data, but well-maintained database | No | Good
Hannan 2003^29^ | No New York administrative database (SPARCS). Regular auditing. | No | No Reasons for readmission were determined by ICD-9-CM | No Risk-adjusted for patient, surgical and hospital level variables | Unclear No comment on any missing data, but well-maintained database | No | Good
Kim 2012^39^ | Yes Mandatory reporting database for hospitals with more than 100 beds. Only 6 hospitals included, no data on #s or reasons for exclusions for lack of reliable data or for infections other than SSI | No | No Nationally recorded hospital database | Yes No adjustment for confounding variables | Unclear Patients with missing data excluded, no information on number excluded | No | Poor
Kurlansky 2012^40^ | No All surgical cases at 5 centers in program with validated data – STS compliant – validated data. | No | No | No Adjustment by predicted risk score | No Imputation guidelines from STS followed for any missing data | No | Good
LaPar 2014^41^ | No STS institutional database. included all patients undergoing cardiac surgery during timeframe | No | No STS institutional data | No Propensity score matching and STS risk-adjusted variables | No No information on missing data but well-maintained database | No | Good
Légaré 2005^16^ | Yes Convenience sample of consecutive patients | No | No | No Adjusted for propensity score, myocardial infarction within 7 days before surgery, preoperative renal failure, ejection fraction <40%, age >70 years, stenosis of left main coronary artery >70% | No | No | Fair
McDonnell 2013^42^ | No Hospital database, no info on auditing/ validation. All patients undergoing cardiac surgery during timeframe | No | No Institutional database | Yes Only discuss controlling for serum creatinine level, but no other confounding factors | Unclear No information on missing data or completeness of database | No | Poor
Parina 2015^30^ | Unclear California (OSHPD) database, excluded data from low-volume hospitals | No | No Outcomes were objective | No Risk-adjusted for patient, surgical and hospital level variables | Unclear Some patients missing sex and ethnoracial data. No information on other missing data. | No | Fair
Rasouli 2013^43^ | No Institutional database, no info on auditing/ validation. All patients with primary or revision TJA | No | No Institutional database | Unclear Only adjusted for SCIP and surgery factors | Unclear No information on missing data or completeness of database | No | Poor
Schelenz 2005^44^ | No All patients undergoing elective cardiac surgery during pre and post time periods | No | Unclear Minimal information on how data was collected and outcome assessors | Yes No adjustment for any patient factors which may have differed between time periods and no data on patient characteristics | Unclear No comment on missing data | No | Poor
Smith 2016^47^ | No VASQIP validated and maintained database | No | No | No VASQIP risk-adjustment models | No Missing data limited, SAS macro used for imputation of missing information | No | Good
Sobolev 2012^17^ | No Population-based patient registry. Inclusion/exclusion criteria applied uniformly | No | No | No Adjusted for patient, clinical, and surgical factors | Unclear Unclear handling missing data. Excluded 8.5% for missing data or “other reasons” | No | Fair
Stefan 2013^31^ | No QIO CDW database | No | No Reasons for readmission were determined by ICD-9-CM | No Risk-adjusted for patient, surgical, and hospital level variables | Unclear No mention of the proportion with missing data | No | Good
Thomas 1996^32^ | No Medicare UB-82 claims data | No | No Reasons for readmission were determined by ICD-9-CM | Unclear Risk-adjusted for patient level factors only | Unclear No mention of missing of data | No | Fair
Tsai 2013^33^ | No Medicare Inpatient 100% file and 2010 MEDPAR File | No | No Measures were objective | No Risk-adjusted using validated tool | Unclear No mention of missing of data | No | Good
Wang 2012^45^ | Unclear No information on patient-level eligibility criteria for selection. Data from state-level linked databases | No | No Regularly collected and maintained hospital data | No Adjusted for patient, hospital, and surgical confounders | Unclear Missing data excluded, varying numbers of missing data for covariates | No | Fair
Zitser-Gurevich 1999^34^ | No National Hospital Admission Registry | No | No Measures were objective | No Risk-adjusted for patient, surgical and hospital level variables | Unclear Mention missing values for left ventricular dysfunction but no mention of handling of missing data | No | Good

Abbreviations: SPARCS= Statewide Planning and Research Cooperative System; OSHPD= Office of Statewide Health Planning and Development; MEDPAR= Medicare Provider Analysis and Review; CDW=Clinical Data Warehouse; QIO=Quality Improvement Organization; VASQIP=VA surgical quality improvement program; SCIP=surgical care improvement program; TJA=total joint arthroplasty; STS=society of thoracic surgeons; SSI=surgical site infection; CABG=coronary artery bypass graft

### APPENDIX E PEER REVIEW

Comment # | Reviewer number | Comment | Author response
1. Are the objectives, scope, and methods for this review clearly described?
1 | 1 | Yes | NA
2 | 2 | Yes | NA
3 | 3 | No - I will confine my comments to cardiac surgery, which is my clinical and performance measurement area of expertise. The nominal objective of this paper is stated in its title: “Use of Performance Measures as Criteria for Selecting Community Cardiac and Orthopedic Surgical Providers for the Veterans Choice Program”. In order to mitigate accessibility issues in the VA for cardiac and orthopedic services, the VA Choice program was established to contract for such services with selected community providers, when needed. These providers must “maintain the same or similar credentials and licenses as VA providers”. The logical flow and inferences of this evidence paper are a mystery to me. The authors demean 30-day CABG mortality as a quality metric, seemingly because one study they identified showed poor correlation between this measure and clinician assessment of preventability. Yet the precedent for this metric is overwhelming. For nearly three decades, virtually every state (e.g., NY, MA, PA, NJ, CA) and national CABG quality assessment program of which I am aware has used this metric as the primary, and often sole method for assessing surgical quality. CABG surgery is actually one of the few procedures where both typical volumes and mortality rates are adequate to justify using risk adjusted mortality as a valid metric to differentiate quality (Dimick et al, JAMA 2004. 292:847). Short term perioperative morbidity and mortality have always been the mainstays of CABG performance measurement, and they are outcomes of great importance to patients. If you do not survive 30 days postop, preferably without serious short term complications such as stroke or renal failure, all other measures are irrelevant. These data are collected and available in state (e.g., NY Cardiac Surgery Reporting System) and national clinical registries (e.g., STS National Database, discussed in response to the next question), and in claims data. Other measures discussed but dismissed by the authors are similarly perplexing. The main medication process measure described in this evidence paper is beta blocker use, whose efficacy is challenged by the particular study they cite. Yet use of this medication is an ACC/AHA Class 1 recommended practice (Circulation 2011; 124: 2610 –2642) for CABG to reduce the occurrence of postoperative atrial fibrillation, based on dozens of studies (randomized and observational). Strikingly, in their discussion of process standards related to CABG, the authors do not specifically mention what is arguably the single most important CABG process measures—use of the internal mammary artery conduit—which has a well-documented association with short and long term survival, graft patency, freedom from recurrent angina, and freedom from reoperation. Ironically, at the same time the authors seem to dismiss 30-day mortality as a valid metric for selecting VA contractors for CABG, they repeatedly use this same measure as the reference upon which to establish the validity, or lack thereof, of other proposed quality metrics, such as readmissions or adherence to process of care measures. With regard to thirty day readmission, this would be low on my list of available CABG performance metrics. Thus, it was quite surprising for me to see this suddenly appear in the evidence document as the authors' most highly recommended quality measure. Readmissions are a problematic measure of CABG performance. While surgical readmissions often result from delayed occurrence or recognition of postoperative complications, the ability to risk adjust this endpoint is problematic. Typical readmission risk model c-indices are 0.60-0.65 rather than the 0.75-0.85 range of most mortality or morbidity risk models. Notably, one of the largest registry-based studies of CABG readmission showed minimal association between readmission rates and performance on a robust, multidimensional, NQF-endorsed composite measure of CABG performance (Shahian et al, Circulation. 2014; 130: 399-409). Readmissions may also be highly influenced by local and patient level socioeconomic factors that are completely out of the control of the discharging hospital, especially for hospitals serving vulnerable populations. And finally, readmissions for cardiac surgery are often to hospitals other than the index hospital (D'Agostino et al, J Thorac Cardiovasc Surg 1999; 118: 823-32. Patient's operated upon at a regional tertiary center may be subsequently readmitted to their local community hospital, perhaps unnecessarily, for problems that could have been treated as an outpatient. The index hospital may not have even been notified that the patient was being considered for readmission to another hospital. In summary, I believe the authors have wrongly concluded that mortality, morbidity and process measures are less valid indicators of CABG quality than 30-day readmission; I regard the latter as a second or third tier indicator of quality for the purposes of VA Choice selective contracting. | We appreciate these comments and below have organized our responses below into separate themes:; 1. 30-day mortality: We agree that we were coming across as dismissing 30-day mortality as a less valid performance metric than mortality. We clarified that our focus was to identify which measures meant as indirect indicators of health outcomes (eg, readmissions, process measures, etc.) are associated with health outcomes (e.g., mortality, quality of life, or function) and that our conclusion that readmission is the strongest measure of quality was relative to other indirect indicators. We agree that any performance measures that directly measure mortality, quality of life and function generally take precedence over other measures given their intrinsic importance to patients and have clarified this in the report. As for the studies that evaluate the association between 30-day mortality and preventable mortality and long-term mortality, we saw them as being in response to published criticisms about the singular use of 30-day mortality and have reframed them as such. We better emphasized that we are encouraged that the usefulness of 30-day mortality as a surrogate for long-term outcomes was reinforced in a recent VHA study, which also found no evidence of gaming to meet a 30-day metric. However, we do stand by our conclusion that the evidence linking readmission to 30-day mortality is stronger than the evidence linking process measures to 30-day mortality. The link between readmission and 30-day mortality is supported by multiple consistent studies; whereas, the link between each specific composite process measure and mortality is only supported by a single study.; 2. Shahian 2014 Circulation study: We added this to the report: “Lower readmission rates were weakly correlated (Spearman rank correlation was –0.154) with higher composite scores (including mortality, major morbidity, internal mammary artery graft and NQF-endorsed perioperative meds) in a secondary subgroup analysis of 827 CMS CABG providers from the 2010 STS database.[Shahian 2014] However, we have insufficient information to determine the strength of this evidence as this finding was only very briefly noted in the Discussion section of the main study, which was devoted to the development of the readmission measure. No other information about the methodology were provided in the publication or via author request.”; 3. Beta Blocker: Yes, we are aware that the findings of Brinkman 2014 suggesting no significant association between preoperative beta blocker use and mortality may seem counterintuitive as preoperative beta blocker use is an ACC/AHA Class 1 recommended practice for CABG to reduce the occurrence of postoperative atrial fibrillation. However, it is not uncommon for studies of patient health outcomes to contradict studies of surrogate endpoints such as atrial fibrillation.; 4. Internal mammary artery conduit: The only studies we identified that link internal mammary artery conduit use to survival, such as Boylan et. al. 1994 in the Journal of Thoracic and Cardiovascular Surgery v107, Issue 3, Pages 657-662, were those initial studies that led to its adoption as a quality standard. We did not find any studies in our search or in your list below that evaluated the link between satisfactory routine adherence to the internal mammary artery conduit use standard and health outcomes.; 5. Limitations of readmission: We agree that use of readmission is potentially limited by lack of consensus about risk adjustment, including how to handle SES and the potential for underestimating rates due to difficulties capturing readmissions to another hospital. We had already included in our Discussion a lengthy discussion of these and other limitations. We added to the Executive Summary and Conclusions a reminder of such limitations and that they must be considered in determining the usefulness of Readmissions.
4 | 4 | Yes | NA
2. Is there any indication of bias in our synthesis of the evidence?
5 | 1 | No | NA
6 | 2 | No | NA
7 | 3 | Yes - I believe the authors have systematically excluded from consideration the most widely used and respected source of clinical cardiothoracic surgery performance data in the US—the STS National Database, which is barely mentioned as an afterthought on page 7 (“...the Society for Thoracic Surgeons (STS) use NQF measures...”). The STS National Database (full disclosure—I have been a volunteer member of various STS Database working groups) was initiated in 1989 and today has over 6 million patient records. As of 2012, it had 90-95% national penetration among adult cardiac surgery programs, and that number is undoubtedly higher today. STS uses trained data managers to collect extremely granular clinical data on every patient, and case completeness rates near 100% have been demonstrated. Annual external audit by a Medicare QIN-QIO have consistently shown accuracy rates of 96-97%. The STS National Database serves as the basis of a robust portfolio of NQF-endorsed performance measures that are publicly reported by a majority of US cardiac programs and used by Consumer Reports and US News and World Report in their performance ratings. Benchmarked performance reports for a myriad of process and risk adjusted outcomes measures are provided quarterly to each participant, and beginning in 2010 a public reporting program was instituted. As of early 2017, 60% of all STS adult cardiac surgery database participants (and thus about the same percentage of all non-federal US cardiac surgery programs) are voluntarily publicly reporting their STS results on the STS or Consumer Reports websites. STS does have risk models for both 30-day all cause readmission and long-term survival. However, although components of the broad STS portfolio of performance metrics, in my opinion they are much less robust measures of CABG performance than the family of composite quality metrics that STS developed beginning a decade ago, all of which have been endorsed through the rigorous NQF process. For CABG, this composite measure encompasses four domains—risk adjusted mortality, risk adjusted morbidity (avoidance of all 5 of the most serious and common complications of CABG), use of the internal mammary artery (the demonstrably superior conduit for long-term graft patency, avoidance of recurrent angina and reoperation, and survival), and use of all 4 NQF endorsed perioperative medications. This is a much broader assessment of quality than could be provided by any individual performance measure, including mortality alone, and measure reliability and ability to discriminate performance are greatly enhanced because of the larger number of endpoints. Importantly, the STS mortality endpoint avoids the gaming issues noted by the authors of the VA study. It includes not only all deaths occurring in hospital, regardless of timing, but also all deaths within 30-days, regardless of where they occurred. Thus, there is no incentive for keeping a hopelessly ill patient alive till day 31 and then withdrawing support, as that patient's death would still be captured. It is extremely rare for a non-federal cardiac surgery provider in the US to not participate in the STS Database. I would personally be reluctant to allow a non-VA program to contract to provide VA CABG services if it did not participate in the STS Database and receive regular feedback reports. Given the near universal participation of US non-federal cardiac surgery programs in the STS Database, it would be exceptionally easy for the VA to use STS quality metrics to assess the quality of programs they are considering. STS composite CABG measures seem to optimally satisfy all the criteria one would want in a performance metric. These multidimensional, comprehensive measures are based on audited, clinically granular data, they incorporate robust risk models, they are reliable, they are used by virtually every cardiac program in the US, and they are all peer-review published and NQF-endorsed. That the possibility of using these measures to evaluate CABG performance for the VA Choice program is not even mentioned in this review is inexplicable to me. I have listed a sampling of the many peer reviewed papers describing these STS quality measurement activities in my answer to the next question. | We have already recommended that VHA decision-makers require Choice community providers to participate in a public reporting program that involves periodic auditing. We state that this could ensure the reliability of Choice community providers' performance measures, and the participation in public reporting itself may also be a strong motivator for quality improvement. This recommendation encompasses STS participation. The fact that STS measures are “based on audited, clinically granular data, they incorporate robust risk models, they are reliable, they are used by virtually every cardiac program in the US, and they are all peer-review published and NQF-endorsed” is informative. But, as a formal comparison of the strengths and weaknesses of the various available performance improvement programs was outside of the scope of this report, we cannot recommend one over another at this time. Also, reliance on STS measures alone may exclude our national network of university hospitals that are often partnered with and an important source of referrals for VA hospitals, but which are participants of other performance improvement organizations. Therefore, leaving our recommendation open to participation in any public reporting program that involves periodic auditing may better ensure Choice network provider adequacy. We agree that use of a rigorously developed and validated and widely accepted and used composite measure of direct and indirect indicators of health outcomes may also be a highly feasible and comprehensive approach to determining eligibility of Choice providers - assuming its potential advantages outweighed identified potential challenges. We have added this recommendation and a paragraph to the ‘Implications for Policy and Implementation’ section of the Discussion that defines, provides rationale for, outlines potential challenges of and ideal characteristics of composite measures based on some of the reference material you provided.
8 | 4 | No | NA
3. Are there any published or unpublished studies that we may have overlooked?
9 | 1 | No | NA
10 | 2 | No | NA
11 | 3 | Yes - Selected peer-reviewed articles relevant to CABG performance measurement and the STS National Database; 1. Shahian DM, Jacobs JP. Health services information: Lessons learned from the society of thoracic surgeons national database. In: Sobolev B, Levy A, Goring S, eds. Data and measures in health services research. Boston, MA: Springer US;2016: p. 1-24.; 2. D'Agostino RS, Jacobs JP, Badhwar V et al. The society of thoracic surgeons adult cardiac surgery database: 2016 update on outcomes and quality. Ann Thorac Surg 2016;101(1):24-32.; 3. Jacobs JP, Shahian DM, He X et al. Penetration, completeness, and representativeness of the society of thoracic surgeons adult cardiac surgery database. Ann Thorac Surg 2016;101(1):33-41.; 4. D'Agostino RS, Jacobs JP, Badhwar V et al. The society of thoracic surgeons adult cardiac surgery database: 2017 update on outcomes and quality. Ann Thorac Surg 2016.; 5. Afilalo J, Kim S, O'Brien S et al. Gait speed and operative mortality in older adults following cardiac surgery. JAMA cardiology 2016;1(3):314-321.; 6. Edwards FH, Ferraris VA, Kurlansky PA et al. Failure to rescue rates after coronary artery bypass grafting: An analysis from the society of thoracic surgeons adult cardiac surgery database. Ann Thorac Surg 2016;102(2):458-464.; 7. Shahian DM. The society of thoracic surgeons national database: “What's past is prologue”. Ann Thorac Surg 2016;101(3):841-845.; 8. Badhwar V, Rankin JS, He X et al. The society of thoracic surgeons mitral repair/replacement composite score: A report of the society of thoracic surgeons quality measurement task force. Ann Thorac Surg 2016;101(6):2265-2271.; 9. Rankin JS, Badhwar V, He X et al. The society of thoracic surgeons mitral valve repair/replacement plus coronary artery bypass grafting composite score: A report of the society of thoracic surgeons quality measurement task force. Ann Thorac Surg 2016.; 10. Bhatt DL, Drozda JP, Jr., Shahian DM et al. Acc/aha/sts statement on the future of registries and the performance measurement enterprise: A report of the american college of cardiology/american heart association task force on performance measures and the society of thoracic surgeons. J Am Coll Cardiol 2015;66(20):2230-2245.; 11. Englum BR, Saha-Chaudhuri P, Shahian DM et al. The impact of high-risk cases on hospitals' risk-adjusted coronary artery bypass grafting mortality rankings. Ann Thorac Surg 2015.; 12. Jacobs JP, Shahian DM, Prager RL et al. Introduction to the sts national database series: Outcomes analysis, quality improvement, and patient safety. Ann Thorac Surg 2015;100(6):1992-2000.; 13. Shahian DM, Grover FL, Prager RL et al. The society of thoracic surgeons voluntary public reporting initiative: The first 4 years. Ann Surg 2015;262(3):526-535.; 14. Shahian DM, He X, Jacobs JP et al. The society of thoracic surgeons composite measure of individual surgeon performance for adult cardiac surgery: A report of the society of thoracic surgeons quality measurement task force. Ann Thorac Surg 2015;100(4):1315-1325.; 15. Winkley Shroyer AL, Bakaeen F, Shahian DM et al. The society of thoracic surgeons adult cardiac surgery database: The driving force for improvement in cardiac surgery. Seminars in thoracic and cardiovascular surgery 2015;27(2):144-151.; 16. Grover FL, Shahian DM, Clark RE, Edwards FH. The sts national database. Ann Thorac Surg 2014;97(1 Suppl):S48-S54.; 17. Shahian DM. Preoperative beta-blockade in coronary artery bypass grafting surgery. JAMA Intern Med 2014;174(8):1328-1329.; 18. Shahian DM, He X, Jacobs JP et al. The sts avr + cabg composite score: A report of the sts quality measurement task force. Ann Thorac Surg 2014;97(5):1604-1609.; 19. Shahian DM, He X, O'Brien SM et al. Development of a clinical registry-based 30-day readmission measure for coronary artery bypass grafting surgery. Circulation 2014;130(5):399-409.; 20. Shahian DM, Jacobs JP, Edwards FH et al. The society of thoracic surgeons national database. Heart 2013;99(20):1494-1501.; 21. Jacobs JP, O'Brien SM, Shahian DM et al. Successful linking of the society of thoracic surgeons database to social security data to examine the accuracy of society of thoracic surgeons mortality data. J Thorac Cardiovasc Surg 2013;145(4):976-983.; 22. Overman DM, Jacobs JP, Prager RL et al. Report from the society of thoracic surgeons national database workforce: Clarifying the definition of operative mortality. World J Pediatr Congenit Heart Surg 2013;4(1):10-12.; 23. Rankin JS, He X, O'Brien SM et al. The society of thoracic surgeons risk model for operative mortality after multiple valve surgery. Ann Thorac Surg 2013;95(4):1484-1490.; 24. Afilalo J, Mottillo S, Eisenberg MJ et al. Addition of frailty and disability to cardiac surgery risk scores identifies elderly patients at high risk of mortality or major morbidity. Circ Cardiovasc Qual Outcomes 2012.; 25. Shahian DM, O'Brien SM, Sheng S et al. Predictors of long-term survival following coronary artery bypass grafting surgery: Results from the society of thoracic surgeons adult cardiac surgery database (the ascert study). Circulation 2012.; 26. Shahian DM, He X, Jacobs JP et al. The society of thoracic surgeons isolated aortic valve replacement (avr) composite score: A report of the sts quality measurement task force. Ann Thorac Surg 2012;94(6):2166-2171.; 27. Shahian DM, Edwards FH, Jacobs JP et al. Public reporting of cardiac surgery performance: Part 1--history, rationale, consequences. Ann Thorac Surg 2011;92(3 Suppl):S2-11.; 28. Shahian DM, Edwards FH, Jacobs JP et al. Public reporting of cardiac surgery performance: Part 2--implementation. Ann Thorac Surg 2011;92(3 Suppl):S12-S23.; 29. Hillis LD, Smith PK, Anderson JL et al. 2011 accf/aha guideline for coronary artery bypass graft surgery: Executive summary: A report of the american college of cardiology foundation/american heart association task force on practice guidelines. Circulation 2011;124(23):2610-2642.; 30. Jacobs JP, Edwards FH, Shahian DM et al. Successful linking of the society of thoracic surgeons database to social security data to examine survival after cardiac operations. Ann Thorac Surg 2011;92(1):32-37.; 31. Bufalino VJ, Masoudi FA, Stranne SK et al. The american heart association's recommendations for expanding the applications of existing and future clinical registries: A policy statement from the american heart association. Circulation 2011;123(19):2167-2179.; 32. Jacobs JP, Edwards FH, Shahian DM et al. Successful linking of the society of thoracic surgeons adult cardiac surgery database to centers for medicare and medicaid services medicare data. Ann Thorac Surg 2010;90(4):1150-1156.; 33. Peterson ED, Delong ER, Masoudi FA et al. Accf/aha 2010 position statement on composite measures for healthcare performance assessment: A report of american college of cardiology foundation/american heart association task force on performance measures (writing committee to develop a position statement on composite measures). J Am Coll Cardiol 2010;55(16):1755-1766.; 34. Shahian DM, Edwards F, Grover FL et al. The society of thoracic surgeons national adult cardiac database: A continuing commitment to excellence. J Thorac Cardiovasc Surg 2010;140(5):955-959.; 35. Shahian DM, O'Brien SM, Normand SL, Peterson ED, Edwards FH. Association of hospital coronary artery bypass volume with processes of care, mortality, morbidity, and the society of thoracic surgeons composite quality score. J Thorac Cardiovasc Surg 2010;139(2):273-282.; 36. O'Brien SM, Shahian DM, Filardo G et al. The society of thoracic surgeons 2008 cardiac surgery risk models: Part 2--isolated valve surgery. Ann Thorac Surg 2009;88(1 Suppl):S23-S42.; 37. Shahian DM, O'Brien SM, Filardo G et al. The society of thoracic surgeons 2008 cardiac surgery risk models: Part 3--valve plus coronary artery bypass grafting surgery. Ann Thorac Surg 2009;88(1 Suppl):S43-S62.; 38. Shahian DM, O'Brien SM, Filardo G et al. The society of thoracic surgeons 2008 cardiac surgery risk models: Part 1--coronary artery bypass grafting surgery. Ann Thorac Surg 2009;88(1 Suppl):S2-22.; 39. O'Brien SM, Shahian DM, Delong ER et al. Quality measurement in adult cardiac surgery: Part 2--statistical considerations in composite measure scoring and provider rating. Ann Thorac Surg 2007;83(4 Suppl):S13-S26.; 40. Shahian DM, Edwards FH, Ferraris VA et al. Quality measurement in adult cardiac surgery: Part 1--conceptual framework and measure selection. Ann Thorac Surg 2007;83(4 Suppl):S3-12.; 41. Shahian D, Silverstein T, Lovett A, Wolf R, Normand S-L. Comparison of clinical and administrative data sources for hospital coronary artery bypass graft surgery report cards. Circulation 2007;115(12):1518-1527.; 42. Shahian DM, Blackstone EH, Edwards FH et al. Cardiac surgery risk models: A position article. Ann Thorac Surg 2004;78(5):1868-1877.; 43. Shahian DM, Normand SL, Torchiana DF et al. Cardiac surgery report cards: Comprehensive review and statistical critique. Ann Thorac Surg 2001;72(6):2155-2168.; 44. D'Agostino RS, Jacobson J, Clarkson M, Svensson LG, Williamson C, Shahian DM. Readmission after cardiac operations: Prevalence, patterns, and predisposing factors. J Thorac Cardiovasc Surg 1999;118(5):823-832.; 45. ElBardissi AW, Aranki SF, Sheng S, O'Brien SM, Greenberg CC, Gammie JS. Trends in isolated coronary artery bypass grafting: An analysis of the society of thoracic surgeons adult cardiac surgery database. J Thorac Cardiovasc Surg 2012;143(2):273-281.; 46. Shahian DM, He X, Jacobs JP et al. Issues in quality measurement: Target population, risk adjustment, and ratings. Ann Thorac Surg 2013. | We thank the reviewer for this comprehensive list of papers that provide detailed information about the STS national database, development and validation of STS performance measure risk prediction models, linking of STS databases to social security and CMS data, and issues in quality measurement. After dual review, we did not identify any additional studies that evaluated the association between a performance measure meant as an indirect indicator of a health outcome and actual health outcomes. We did add the following articles to the Background section:; - Shahian DM, Blackstone EH, Edwards FH et al. Cardiac surgery risk models: A position article. Ann Thorac Surg 2004;78(5):1868-1877.; - Shahian DM, O'Brien SM, Filardo G et al. The society of thoracic surgeons 2008 cardiac surgery risk models: Part 3--valve plus coronary artery bypass grafting surgery. Ann Thorac Surg 2009;88(1 Suppl):S43-S62.; - Shahian DM, O'Brien SM, Filardo G et al. The society of thoracic surgeons 2008 cardiac surgery risk models: Part 1--coronary artery bypass grafting surgery. Ann Thorac Surg 2009;88(1 Suppl):S2-22.; - D'Agostino RS, Jacobs JP, Badhwar V et al. The society of thoracic surgeons adult cardiac surgery database: 2017 update on outcomes and quality. Ann Thorac Surg 2016.; - Jacobs JP, Shahian DM, He X et al. Penetration, completeness, and representativeness of the society of thoracic surgeons adult cardiac surgery database. Ann Thorac Surg 2016;101(1):33-41.; - Shahian DM, Jacobs JP, Edwards FH et al. The society of thoracic surgeons national database. Heart 2013;99(20):1494-1501.; - Peterson ED, Delong ER, Masoudi FA et al. Accf/aha 2010 position statement on composite measures for healthcare performance assessment: A report of american college of cardiology foundation/american heart association task force on performance measures (writing committee to develop a position statement on composite measures). J Am Coll Cardiol 2010;55(16):1755-1766.
12 | 4 | No | NA
4. Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
13 | 1 | Page 9, change VASQUIP to VASQIP | Changed
14 | 2 | I think this review will be very useful. My principal comment is that it would be useful to provide a more extensive summary of the controversy over adjusting for socio-economic status. This is a key policy decision facing the nominator. Another concern is that the conclusion should mention the evidence supporting readmissions as a measure for orthopedics. These comments and more minor editorial notes are included in the attached document. | Added a summary of these aspects of SES debate: (1) SES may be associated with inequalities in care that adjusted would obscure and (2) differences in outcomes by SES are due to social factors for which hospitals should not be accountable. Also added to the conclusion section the weaker evidence supporting readmissions for hip fracture.
15 | 2 | Executive Summary Table, Hip replacement: Higher risk of “remission” in highest vs… | Changed to ‘readmission’
16 | 2 | Executive Summary Table, I didn't see a reference to BB in the table | ‘BB’ removed from abbreviations
17 | 2 | Line 182, …using performance measures select and monitor… | Changed to ‘using performance measures to select and monitor’
18 | 2 | Line 248,9 (“After a period of time…”) Re-phrase more neutrally? | Changed to: “After a period of time in which the number of new performance measures adopted by the VA and non-VA organizations grew, we have begun to reduce the number and focus on the most important.”
19 | 2 | Line 253… replace “taking into account with ‘adjusting for’ | Wording revised
20 | 2 | Line 256… break into 2 sentences, “…proposed. Equitable performance measures should: (1) have…” | Revised
21 | 2 | Line 256… (2) ‘can’ be collected… | Removed ‘can’
22 | 2 | Line 260… (8) ‘and’ have minimal… | Removed the extra ‘and’
23 | 2 | Line 264,5… “Evidence is lacking…” - This strikes me as extremely cautious. If performance measurement is good for anything it should be useful for this purpose. | This Introductory statement is meant to provide rationale for conducting this review. As there is no literature on adapting performance measurement for contracting providers, the intent of our review is to address this information gap.
24 | 2 | Line 278… “feelings of over-control,” Not sure what this is intended to mean. Feelings of loss of autonomy? Feelings of being mismanaged? | Changed to “loss of autonomy”
25 | 2 | Line 308, VASQUIP- | Changed to ‘VASQIP’
26 | 2 | Line 449,50… “However, this result…” - This is the nature of systematic reviews, right? Do you really think the single controlled subsequent study outweighs the review? That's the impression you leave. Given the relationship with complications in emergent cases, this might be a useful metric. | Changed to: “Results were consistent regardless of variation in adjustment, cut-off time for wait time, and cut-off time for mortality.” No, we think the consistent findings from the subsequent study strengthen the findings of the systematic review and added this context.
27 | 2 | Line 584 “…the only study one which…” | Revised wording
28 | 2 | Line 601, ‘outlier’ | Changed to ‘outliers’
29 | 2 | Line 788-90… “ Also, although low socioeconomic status has been shown…” -Perhaps expand on this issue? There has been much discussion in the literature and at MedPAC. It might be important to summarize as a warning to policymakers. | Added a summary of these aspects of SES debate: (1) SES may be associated with inequalities in care that adjusted would obscure and (2) differences in outcomes by SES are due to social factors for which hospitals should not be accountable.
30 | 2 | Line 867… (after first sentence, this paragraph) Add a qualified statement characterizing evidence supporting use of readmissions as a metric for orthopedic procedures too. | Done.
31 | 4 | I generally agree with the approach and conclusions of the report. However, I was surprised to see that CABG volume was not included as a potential measure. There is reasonable evidence that higher CABG volumes, both from a facility and provider point of view, correlates with better outcomes. It is a relatively easy measure to obtain. Thus, I would suggest that the group review volume evidence and include it in their recommendations, if the evidence review supports its inclusion. | We identified scope as one of the general limitations of our review. In order to meet our condensed timeframe we focused our scope to a subset of the highest-priority populations and measures of the Office of Community Care. Volume was not included in this subset. We recognize this limits the applicability of our findings to broader populations and measures of interest, such as volume.

### REFERENCES

1 Centers for Medicare & Medicaid Services. Consensus core set: Orthopedic measures. 2015; https://www.cms.gov/Medicare/Quality-Initiatives-Patient-Assessment-Instruments/QualityMeasures/Downloads/Orthopedic-Measures.pdf. Accessed May 9, 2017.
2 Centers for Medicare & Medicaid Services. Consensus core set: Cardiovascular measures. 2016; https://www.cms.gov/Medicare/Quality-Initiatives-Patient-Assessment-Instruments/QualityMeasures/Downloads/Cardiovascular-Measures.pdf. Accessed May 9, 2017.
3 National Quality Forum. National quality forum: Measure search. 2017; http://www.qualityforum.org/Qps/QpsTool.aspx?m=2515&e=1. Accessed May 9, 2017.
4 Khuri SF, Daley J, Henderson W, . The department of veterans affairs' nsqip: The first national, validated, outcome-based, risk-adjusted, and peer-controlled program for the measurement and enhancement of the quality of surgical care. National va surgical quality improvement program. Annals of Surgery.1998;228(4):491.9790339
5 Khuri SF, Henderson WG, Daley J, . The patient safety in surgery study: Background, study design, and patient populations. Journal of the American College of Surgeons. Jun 2007;204(6):1089-1102.17544068
6 Dixon JL, Papaconstantinou HT, Hodges B, . Redundancy and variability in quality and outcome reporting for cardiac and thoracic surgery. Baylor University Medical Center Proceedings. 2015;28(1):14-17.25552787
7 Shiloach M, Frencher SK, Steeger JE, . Toward robust information: Data quality and inter-rater reliability in the american college of surgeons national surgical quality improvement program. Journal of the American College of Surgeons. 2010;210(1):6-16.20123325
8 Fink AS, Campbell DA, Jr., Mentzer RM, Jr., . The national surgical quality improvement program in non-veterans administration hospitals: Initial demonstration of feasibility. Annals of Surgery. Sep 2002;236(3):344-353; discussion 353-344.12192321
9 Fry DE. Surgical site infections and the surgical care improvement project (scip): Evolution of national quality measures. Surgical Infections. Dec 2008;9(6):579-584.19216670
10 Leung F, Lau TW, Kwan K, Chow SP, Kung AW. Does timing of surgery matter in fragility hip fractures? Osteoporos Int. Dec 2010;21(Suppl 4):S529-534.21057992
11 Moja L, Piatti A, Pecoraro V, . Timing matters in hip fracture surgery: Patients operated within 48 hours have better outcomes. A meta-analysis and meta-regression of over 190,000 patients. PLoS One. 2012;7(10):e46175.23056256
12 Shiga T, Wajima Z, Ohe Y. Is operative delay associated with increased mortality of hip fracture patients? Systematic review, meta-analysis, and meta-regression. Canadian Journal of Anaesthesia. 2008;55(3):146-154.18310624
13 Simunovic N, Devereaux PJ, Sprague S, . Effect of early surgery after hip fracture on mortality and complications: Systematic review and meta-analysis. CMAJ. Oct 19 2010;182(15):1609-1616.20837683
14 Khan SK, Kalra S, Khanna A, Thiruvengada MM, Parker MJ. Timing of surgery for hip fractures: A systematic review of 52 published studies involving 291,413 patients. Injury. Jul 2009;40(7):692-697.19450802
15 Schepers T, De Vries MR, Van Lieshout EM, Van der Elst M. The timing of ankle fracture surgery and the effect on infectious complications; a case series and systematic review of the literature. International Orthopaedics. 2013;37(3):489-494.23288046
16 Légaré JF, MacLean A, Buth KJ, Sullivan JA. Assessing the risk of waiting for coronary artery bypass graft surgery among patients with stenosis of the left main coronary artery. CMAJ. Aug 16 2005;173(4):371-375.16103509
17 Sobolev BG, Fradet G, Kuramoto L, Rogula B. An observational study to evaluate 2 target times for elective coronary bypass surgery. Medical Care. Jul 2012;50(7):611-619.22525613
18 Meessen JM, Pisani S, Gambino ML, . Assessment of mortality risk in elderly patients after proximal femoral fracture. Orthopedics. Feb 2014;37(2):e194-200.24679208
19 Holvik K, Ranhoff AH, Martinsen MI, Solheim LF. Predictors of mortality in older hip fracture inpatients admitted to an orthogeriatric unit in oslo, norway. Journal of Aging & Health. Dec 2010;22(8):1114-1131.20881106
20 Karademir G, Bilgin Y, Ersen A, . Hip fractures in patients older than 75 years old: Retrospective analysis for prognostic factors. International Journal Of Surgery. Dec 2015;24(Pt A):101-104.26563486
21 Clague JE, Craddock E, Andrew G, Horan MA, Pendleton N. Predictors of outcome following hip fracture. Admission time predicts length of stay and in-hospital mortality. Injury. Jan 2002;33(1):1-6.11879824
22 Griffiths EJ, Cash DJ, Kalra S, Hopgood PJ. Time to surgery and 30-day morbidity and mortality of periprosthetic hip fractures. Injury. Dec 2013;44(12):1949-1952.23639824
23 Lund CA, Moller AM, Wetterslev J, Lundstrom LH. Organizational factors and long-term mortality after hip fracture surgery. A cohort study of 6143 consecutive patients undergoing hip fracture surgery. PLoS ONE [Electronic Resource]. 2014;9(6):e99308.
24 Lurati Buse GA, Bhandari M, Devereaux P, Inverstigators T. Accelerated care versus standard care among patients with hip fracture: The hip attack pilot trial. CMAJ. Jan 07 2014;186(1):E52-60.24246589
25 Ryan DJ, Yoshihara H, Yoneoka D, Egol KA, Zuckerman JD. Delay in hip fracture surgery: An analysis of patient-specific and hospital-specific risk factors. Journal of Orthopaedic Trauma. Aug 2015;29(8):343-348.25714442
26 Tennent TD, Calder PR, Salisbury RD, Allen PW, Eastwood DM. The operative management of displaced intra-articular fractures of the calcaneum: A two-centre study using a defined protocol. Injury. Jul 2001;32(6):491-496.11476816
27 Vallier HA, Super DM, Moore TA, Wilber JH. Do patients with multiple system injury benefit from early fixation of unstable axial fractures? The effects of timing of surgery on initial hospital course. Journal of Orthopaedic Trauma. Jul 2013;27(7):405-412.23287766
28 Hannan EL, Zhong Y, Lahey SJ, . 30-day readmissions after coronary artery bypass graft surgery in new york state. Jacc: Cardiovascular Interventions. 2011;4(5):569-576.21596331
29 Hannan EL, Racz MJ, Walford G, . Predictors of readmission for complications of coronary artery bypass graft surgery. JAMA. 2003;290(6):773-780.12915430
30 Parina RP, Chang DC, Rose JA, Talamini MA. Is a low readmission rate indicative of a good hospital? Journal of the American College of Surgeons. 2015;220(2):169-176.25529903
31 Stefan MS, Pekow PS, Nsa W, . Hospital performance measures and 30-day readmission rates. Journal of General Internal Medicine. 2013;28(3):377-385.23070655
32 Thomas JW. Does risk-adjusted readmission rate provide valid information on hospital quality? Inquiry. Fall 1996;33(3):258-270.8883460
33 Tsai TC, Joynt KE, Orav EJ, Gawande AA, Jha AK. Variation in surgical-readmission rates and quality of hospital care. New England Journal of Medicine. Sep 19 2013;369(12):1134-1142.24047062
34 Zitser-Gurevich Y, Simchen E, Galai N, Braun D. Prediction of readmissions after cabg using detailed follow-up data: The israeli cabg study (iscab). Medical Care. 1999;37(7):625-636.10424633
35 Auerbach AD, Hilton JF, Maselli J, Pekow PS, Rothberg MB, Lindenauer PK. Follow the crowd or shop for the best? Volume, quality, and outcomes of coronary artery bypass surgery. Annals of Internal Medicine. 2009;150(10):696-704.19451576
36 Bhattacharyya T, Freiberg AA, Mehta P, Katz JN, Ferris T. Measuring the report card: The validity of pay-for-performance metrics in orthopedic surgery. Health Aff (Millwood). Mar-Apr 2009;28(2):526-532.19276012
37 Brinkman W, Herbert MA, O'Brien S, . Preoperative beta-blocker use in coronary artery bypass grafting surgery: National database analysis. JAMA Internal Medicine. Aug 2014;174(8):1320-1327.24934977
38 Cotogni P, Barbero C, Passera R, Fossati L, Olivero G, Rinaldi M. Violation of prophylactic vancomycin administration timing is a potential risk factor for rate of surgical site infections in cardiac surgery patients: A prospective cohort study. BMC cardiovascular disorders. 2017;17(1).
39 Kim ES, Park SW, Lee CS, Gyung Kwak Y, Moon C, Kim BN. Impact of a national hospital evaluation program using clinical performance indicators on the use of surgical antibiotic prophylaxis in korea. International Journal of Infectious Diseases. Mar 2012;16(3):e187-192.22245171
40 Kurlansky PA, Argenziano M, Dunton R, . Quality, not volume, determines outcome of coronary artery bypass surgery in a university-based community hospital network. The Journal of Thoracic and Cardiovascular Surgery. 2012;143(2):287-293. e281.22104669
41 LaPar DJ, Isbell JM, Kern JA, Ailawadi G, Kron IL. Surgical care improvement project measure for postoperative glucose control should not be used as a measure of quality after cardiac surgery. Journal of Thoracic & Cardiovascular Surgery. Mar 2014;147(3):1041-1048.24418668
42 McDonnell ME, Alexanian SM, Junqueira A, Cabral H, Lazar HL. Relevance of the surgical care improvement project on glycemic control in patients undergoing cardiac surgery who receive continuous insulin infusions. Journal of Thoracic & Cardiovascular Surgery. Feb 2013;145(2):590-594; discussion 595-597.23062416
43 Rasouli MR, Jaberi MM, Hozack WJ, Parvizi J, Rothman RH. Surgical care improvement project (scip): Has its mission succeeded? Journal of Arthroplasty. Aug 2013;28(7):1072-1075.23602416
44 Schelenz S, Tucker D, Georgeu C, . Significant reduction of endemic mrsa acquisition and infection in cardiothoracic patients by means of an enhanced targeted infection control programme. Journal of Hospital Infection. Jun 2005;60(2):104-110.15866007
45 Wang Z, Chen F, Ward M, Bhattacharyya T. Compliance with surgical care improvement project measures and hospital-associated infections following hip arthroplasty. Journal of Bone & Joint Surgery - American Volume. Aug 01 2012;94(15):1359-1366.22740029
46 Guru V, Tu JV, Etchells E, . Relationship between preventability of death after coronary artery bypass graft surgery and all-cause risk-adjusted mortality rates. Circulation. 2008;117(23):2969-2976.18541752
47 Smith T, Li X, Nylander W, Gunnar W. Thirty-day postoperative mortality risk estimates and 1-year survival in veterans health administration surgery patients. JAMA Surgery. 2016;151(5):417-422.26747331