# Evidence Brief: Effect of Geriatricians on Outcomes of Inpatient and Outpatient Care

## PREFACE

Quality Enhancement Research Initiative’s (QUERI) Evidence-based Synthesis Program (ESP) was established to provide timely and accurate syntheses of targeted healthcare topics of particular importance to Veterans Affairs (VA) managers and policymakers, as they work to improve the health and healthcare of Veterans. The ESP disseminates these reports throughout VA.

QUERI provides funding for four ESP Centers and each Center has an active VA affiliation. The ESP Centers generate evidence syntheses on important clinical practice topics, and these reports help:

- develop clinical policies informed by evidence,
- guide the implementation of effective services to improve patient outcomes and to support VA clinical practice guidelines and performance measures, and
- set the direction for future research to address gaps in clinical knowledge.

In 2009, the ESP Coordinating Center was created to expand the capacity of QUERI Central Office and the four ESP sites by developing and maintaining program processes. In addition, the Center established a Steering Committee comprised of QUERI field-based investigators, VA Patient Care Services, Office of Quality and Performance, and Veterans Integrated Service Networks (VISN) Clinical Management Officers. The Steering Committee provides program oversight, guides strategic planning, coordinates dissemination activities, and develops collaborations with VA leadership to identify new ESP topics of importance to Veterans and the VA healthcare system.

Comments on this evidence brief are welcome and can be sent to Nicole Floyd, ESP Coordinating Center Program Manager, at nicole.floyd@va.gov.

## KEY MESSAGES

The currently available research on medical care involving geriatricians suggests:

- The impact of geriatrician involvement on patient function and health care utilization varies across the different models of care that include geriatricians in different roles.

## INPATIENT CARE

- Patients receiving care in special geriatric units that are staffed by a team including a geriatrician have better function at discharge and are more likely to be discharged to home than patients receiving standard hospital care.
- Inpatient rehabilitation including a geriatrician resulted in lower nursing home admissions, improved function and lower mortality at followup (range 3-12 months) compared to usual care.
- Evidence about the effect of inpatient geriatric intervention on hospital readmission, length of stay, emergency visits, and outpatient visits is insufficient to draw conclusions.
- Neither inpatient geriatric units nor inpatient geriatric teams had lower patient mortality rates when compared with usual care.
- There is insufficient evidence to allow any conclusion about whether models of care that use geriatricians as inpatient consultants are effective.
- Geriatricians in special teams that conduct Comprehensive Geriatric Assessment and advise on patient care across hospital units (floating teams) do not improve patient outcomes.
- For all types of interventions involving geriatricians in inpatient care:
  - Detailed examinations of the impact of different components of the intervention, including the specific contribution of the geriatrician, are difficult to isolate from published studies.
  - More research is needed about what components of specific types of interventions are most likely to improve patient outcomes.

## OUTPATIENT CARE

- Geriatricians in teams and as consultants had mixed results in terms of impact on function, living at home and health services utilization.
- Interventions in which geriatricians have direct patient contact are more likely to result in better outcomes than interventions where the interaction is limited to supporting other clinicians.
- Geriatricians as primary care providers provide more effective medication management than other clinicians.
- The evidence does not show that outpatient care involving geriatricians reduced mortality compared to usual care.

## INTRODUCTION

In 2011, 42.1 percent (approximately 9 million) of all US Veterans were over 65 years old.1 An increasing number of these older Veterans are receiving health care from the Veterans Healthcare Administration (VHA). Projections are that 43 percent of all Veterans over 65 will enroll in VHA in 2013, up from 31 percent in 2003; 20 percent of Veterans over 85 received care in VHA in 2003, and this is expected to rise to 51 percent by 2013.^2^

As Veterans age, their health care needs are likely to change and increase, resulting from the development of chronic illness and age-related disability. Geriatric syndromes, such as falls and incontinence, can contribute to acute or serious problems such as fractures and pressure ulcers. Cognitive impairments, regardless of the cause, make managing both daily life and chronic conditions such as diabetes challenging. Additionally, older Veterans are more likely to take multiple medications and receive health care from several clinicians. This increases the chances for adverse drug events, miscommunication, and fragmented care that can ultimately result in negative consequences for older Veterans. Multifaceted and multidisciplinary models of care for older people have been developed, such as Comprehensive Geriatric Assessment (CGA) and Geriatric Evaluation and Management (GEM). The common elements of these models are assessment and follow-up with a focus on maximizing function and quality of life while avoiding negative outcomes to the extent possible.

Addressing the needs of older Veterans requires a combination of different models of care and the involvement of health care providers with expertise in caring for older people. Geriatricians are physicians with additional training and certification in the care of the multiple and often complex health concerns of older adults. Geriatricians can play different roles in care teams; and in these care models, their roles may range from leader of a team, to occasional consultant, to clinician with primary responsibility for care.

This evidence brief summarizes the existing research available on the impact of geriatricians, acting in various roles, on selected patient outcomes in hospital and outpatient care. The Objectives and Methods sections describe included roles and outcomes in more detail.

This report was produced in response to a request for an evidence brief from the Office of Geriatrics and Extended Care and the Healthcare Delivery Committee of the National Leadership Council of VA. An evidence brief differs from a full systematic review in that the scope of work is more narrowly defined in order to provide information needed in a specific timeframe for policy and practice decisions. The scope of work was negotiated with the requestors in order to balance their information needs and time constraints. The scope of work for this brief included outcomes that were of highest priority for the requestors, used systematic reviews as the primary source of evidence, and did not include translating articles in other languages into English.

## OBJECTIVES

The primary and secondary objectives of this review are:

PRIMARY: To evaluate the effectiveness of geriatricians as consultants, co-management providers, or individual primary care providers, on inpatient and outpatient care. We defined effectiveness as improvement in any of the following patient outcomes:

- Function (physical or cognitive)
- Nursing home admission, discharge to home, or living at home during follow-up period
- Health services utilization (hospital admission or readmission, length of hospital stay, emergency department visits, outpatient visits)
- Medication management (appropriateness, number, or adverse events)
- Mortality

These outcomes were prespecified in the scope of work agreed to by the requesting organization and the investigators. Studies that included only other outcomes, such as patient satisfaction, were not included. If studies included multiple outcomes, only the results for the included outcomes are summarized in this Brief.

SECONDARY: If outcomes are shown to be improved, to describe specific characteristics (either patient characteristics or care model characteristics) that led to more effective outcomes.

## KEY QUESTIONS

To address the proposed objectives, we will answer the following key questions:

Key Question 1A: What is the effectiveness of geriatric teams, consultative services or geriatric co-management for inpatient medical and surgical patients?

Key Question 1B: If increased effectiveness is demonstrated, are there specific characteristics (either of the patient or the care model) that lead to improved outcomes for inpatients?

Key Question 2A: What is the effectiveness of geriatric consultation, co-management, or geriatricians as primary care providers for outpatient primary care?

Key Question 2B: If geriatric care is shown to lead to improved outcomes, are there specific characteristics (either of the patient or care model) that lead to more effective outcomes among the primary care outpatient population?

## METHODS

We searched for systematic reviews, trials, and observational studies in PubMed, the Cochrane Database of Systematic Reviews^®^, the Cochrane Central Register of Controlled Trials^®^, and the Cochrane Database of Reviews of Effects on March 2, 2012, using standard search terms (for full search strategy, see Supplemental Materials) back to 1985. Additional citations were identified from reference lists, hand searching, and consultation with content experts. We limited the search to published and indexed articles involving human subjects and available in English. We did include studies conducted in countries other than the United States if they were available in English. Titles, abstracts, and articles were reviewed in duplicate by investigators and research associates trained in the critical analysis of literature.

For studies to be included, interventions had to include a geriatrician and involve inpatient or outpatient medical care. Systematic reviews had to include enough information about the interventions in the included studies for us to determine which studies included geriatricians. Long-term care and care models that integrate long-term and acute care were not included. Studies had to include a comparator, that is they could not simply describe an intervention, but rather the intervention had to be evaluated. The studies also had to report at least one of our prespecified outcomes. Studies that were part of an included systematic review were not considered separately—that is they are not reported twice—in our evidence synthesis. Detailed inclusion and exclusion criteria are provided in the Supplemental Materials.

Quality assessment of all included systematic reviews was performed by investigators and research associates using the AMSTAR criteria.3 Systematic reviews that met at least six of the 11 AMSTAR criteria were considered high quality and used as the basis for the summary of evidence in this Evidence Brief. We assessed study quality of additional controlled trials and observational studies according to adapted criteria proposed by Downs and Black (observational studies) and methods developed by the U.S. Preventive Services Task Force.4, 5 Studies assessed as fair or good quality according to these criteria and not covered in one of the included systematic reviews are described separately in the Results below. Detailed quality assessment criteria and results of our assessments for all included studies are provided in the Supplemental Materials. Brief information on primary studies rated as poor quality is also provided in the Supplemental Materials, but these studies did not contribute to our synthesis of the evidence.

A draft version of this evidence brief was reviewed by five technical experts, as well as representatives of the organizations that requested this brief. Reviewer comments were addressed and our responses were incorporated in this final version of the Evidence Brief. A disposition of comments table is included in the Supplemental Materials.

## RESULTS

Figure 1 below provides details on the number of articles identified and their disposition at each step of the review. The primary reason for exclusion at the screening phase was that the study was about a topic that did not match the objectives of the review. The most common reasons for exclusion at the full-text level were lack of a geriatrician in the intervention, lack of an included outcome, or the article was descriptive, with no comparison made between the intervention and another group or pre-intervention time period.

Figure 1 Literature Flow Chart

We identified 10 good quality systematic reviews and 78 articles reporting primary research. Of the 78 articles, 50 were included in one or more of the 10 systematic reviews and their results are not discussed separately. The 28 not included in the systematic reviews were evaluated and are presented separately.

### KEY QUESTION 1A What is the effectiveness of geriatric consultative services or geriatric co-management for inpatient medical and surgical patients?

#### OVERVIEW OF IDENTIFIED STUDIES

We included five recent, good quality systematic reviews of inpatient geriatric care involving geriatricians.6–10 We also identified four fair or good quality randomized trials11–14 and one fair quality observational study15 of inpatient care that were not included in these systematic reviews and therefore are described separately. Information on the systematic reviews is provided in Table 1 and information on the additional primary studies is reported in Table 2. Six studies were rated as poor quality16–21 and are not included in our synthesis. Brief information on these studies is provided in the Supplemental Materials.

Table 1 Inpatient Systematic Reviews Summary

Year, First Author (AMSTAR Rating) # of Included Studies # of Subjects | Type of Intervention | Subject of Study | Geriatrician Role/Tasks | Key Outcomes^*^
Year, First Author (AMSTAR Rating) # of Included Studies # of Subjects | Type of Intervention | Subject of Study | Geriatrician Role/Tasks | Mortality | Function | Nursing Home Admission/Living at Home | Length of Stay/Rehospitalizations | Medications
2010, Bachmann10 (10/11) 17 RTs 4780 | Special Units | Inpatient rehabilitation specifically designed for geriatric patients | All teams included geriatricians | +++ | +++ | +++ | NR | NR
2009, Baztan8 (8/11) 11 studies NR | Special Units | Acute geriatric units compared with conventional care units | 8 of 11 specify a geriatrician is part of unit team | ~~~ | +++ | +++ | ~~~ | NR
2011, Conroy7 (9/11) 5 RTs | Teams | CGA for older patients in the hospital who were assessed, treated and discharged in a short period of time | 2 of 5 interventions were geriatrician-led; 3 of 5 were nurse-led with geriatrician on team | ~~~ | ~~~ | ~~~ | ~~~ | NR
2004, Day9 (8/11) 58 primary research; 9 SRs | Multiple, inpatient and outpatient | Specialist Geriatric Services | All studies included people training in geriatrics, but it was not always clear whether it was a physician | ~~~ | +++ | +++ | +++ | NR
2011, Ellis6 (9/11) 22 RTs 10, 315 | Special Units and Teams | CGA in hospital for patients admitted as an emergency overall and to compare interventions on key characteristics | 20 of 22 studies included geriatricians assigned to special units (7) or teams (13) | Overall ~~~ Unit ~~~ Team ~~~ | Overall +++ Unit ??? Team ??? | Overall +++ Unit +++ Team ~~~ | Overall ??? Unit ??? Team ??? | NR

* For systematic reviews, impact on key outcomes is limited to included studies that involve geriatricians.

Abbreviations: CGA = Comprehensive Geriatric Assessment; Obs = Observational study; RT = Randomized trial; SR = Systematic Review.

Systematic Reviews, Summary Impact: +++ = Positive Impact; − − − = Negative Impact; ~~~ = No difference; ??? = Unable to determine; NR = Not studied or reported

Table 2 Inpatient: Additional Primary Studies Summary

Year, First Author (Quality Rating) Type of Study (# of Subjects) | Type of Intervention | Subject of Study | Geriatrician Role/Tasks | Key Outcomes
Year, First Author (Quality Rating) Type of Study (# of Subjects) | Type of Intervention | Subject of Study | Geriatrician Role/Tasks | Mortality | Function | Nursing Home Admission/Living at Home | Length of Stay/Rehospitalizations | Medications
1995, Germain13 (Fair) RT (108) | Teams | Geriatric assessment and management of inpatients who would qualify for a special unit | Assessment and responsibility for treatment | ~ | NR | + | + | NR
1990, Hogan14 (Fair) RT (132) | Teams | Usefulness of geriatric consult teams in acute care | Geriatrician was part of team including a nurse coordinator, an occupational therapist, a physiotherapist, a social worker, a dietitian and a representative from pastoral care. | NR | + | NR | NR | NR
1993, Inouye15 (Fair) Obs (258) | Team | Evaluation of a nurse-centered intervention. | Geriatricians provided support for geriatric resource nurses on intervention units; in one unit geriatricians participated in rounds, in the second they did not. | NR | + | NR | NR | NR
2011, Legrain11 (Good) RT (655) | Consultation | A comprehensive discharge planning intervention conducted by a geriatrician | Geriatrician, not part of regular care team, was responsible for the intervention. | 3 months: + 6 months: ~ | NR | NR | 3 months: + 6 months: ~ | NR
1997, Slaets12 (Fair) RT (237) | Teams | Inpatient multidisciplinary team focused on optimal function | Geriatricians conducted assessments, then generated and implemented a care plan. | NR | + | + | + | NR

Abbreviations: Obs = Observational study; RT = Randomized trial.

Individual Studies, Impact: + = Positive Impact; − = Negative Impact; ~ = No difference; ? = Unable to determine; NR = Not studied or reported

These reviews and primary studies evaluated several different models of care that included geriatricians:

- Comprehensive Geriatric Assessment (CGA) involves a coordinated multidisciplinary assessment designed to identify medical, physical, social and psychological problems and serve as the basis for a plan of care.
- In hospitals, CGA may be the basis for care that is provided in inpatient geriatric units known by names such as Acute Care for the Elderly (ACE) and Geriatric Evaluation and Management Units (GEMU). These units may have physical, organizational and staff characteristics designed specifically for geriatric care.
- CGA may be also used by multidisciplinary teams that provide care for patients throughout the hospital, in the different units to which older patients are admitted.
- Individual geriatricians may provide inpatient geriatrics consultations about patients under the care of other physicians. These consultations may be routinely provided for certain types of patients, or provided in response to requests by other physicians.

##### Comprehensive Geriatric Assessment

A 2011 Cochrane review of CGA for hospitalized patients6 updated a technology assessment9 and two earlier reviews conducted in 1993^22^ and 2005.^23^ This 2011 review identified 22 trials that included 10,315 patients and evaluated the overall impact of CGA as well as whether the impact on outcomes varied by characteristics of the CGA intervention. Twenty of the 22 trials included a geriatrician as part of the CGA team.

The review authors conclude that older patients who receive CGA in the hospital have more positive outcomes than patients receiving usual care. They were:

- More likely to be living at home during the follow-up period after discharge
  ○ OR 1.25, 95% CI 1.11–1.42, p=0.0002; six months post-discharge
  ○ OR 1.16, 95% CI 1.05–1.28, p=0.003; end of follow-up (median one year)
- Less likely to be institutionalized
  ○ OR 0.79, 95% CI 0.69–0.88, p<0.00001
- Less likely to have deteriorated in their level of function
  ○ OR 0.76, 95% CI 0.64–0.90, p=0.001
- More likely to have improved cognitive function
  ○ OR 1.11, 95% CI 0.02–2.01, p=0.002

However, CGA had no effect on mortality (OR 0.99, 95% CI 0.80–1.05, p=0.20).

##### Inpatient Geriatric Units

Special geriatric hospital units have been the subject of many studies since the 1980s. The 2011 Cochrane review of CGA for hospital patients6 concluded that the positive impact of CGA in hospitals are primarily the result of CGA that is incorporated into care in special geriatric units and not CGA teams that cover multiple units.

The reviewers split the interventions according to whether the CGA was based in a specialized geriatric acute care hospital unit or ward (15 studies) or the CGA was conducted by a team that ‘floats’ or treats patients in the various acute care units to which patients were admitted (7 studies). These reviewers conducted analyses of these subgroups to estimate the contribution of these two models to improvement in outcomes. Results showed that:

- CGA in special hospital units improved the odds of living at home after discharge and avoiding institutionalization when compared to usual care.
- Floating teams produced results that did not differ significantly from the outcomes of usual care.
- The authors of this review speculate that this may be because special units allow the geriatric team to have more control over care, including implementation of the recommendations based on CGA, and permit the development of greater expertise among everyone who works on the unit.

Two other systematic reviews summarized smaller numbers of studies of special inpatient units,8,10 and their findings were consistent with those of the larger review. 6

One systematic review evaluated comparisons of acute geriatric units to conventional hospital units.8 Reviewers identified 11 studies including five randomized trials, four non randomized trials, and two case control studies. Not all interventions included a geriatrician, but sensitivity analyses limiting to those that did include a geriatrician, did not change results. Meta-analyses of the results from the randomized trials (included in parentheses) as well as global analyses of all included studies found:

- Patients treated in geriatric units had lower risk of functional decline at hospital discharge (OR 0.82, 95% CI 0.68–0.99),
- But there was no significant difference in mortality either in hospital (OR 0.83, 95% CI 0.60–1.14) or mortality at three months post-discharge (OR 0.95, 95% CI 0.78–1.16),
- And no difference in readmission at three months (OR 1.11, 95% CI 0.92–1.35) among the patients treated in the special geriatric units compared to conventional units.

Another review focused on inpatient rehabilitation, comparing care specifically designed for older patients (all interventions models included geriatricians) to usual care.10 The 17 randomized trials included were split between general geriatric rehabilitation (8 studies) and rehabilitation follow-up for hip fracture (9 studies). In a meta-analysis of outcomes at discharge and at end of follow-up for all studies (range of the follow-up periods was 3–12 months) there were:

- Lower nursing home admissions (discharge: RR 0.64, 95% CI 0.51–0.81; follow-up: 0.84, 95% CI 0.72–0.99);
- Improved function (discharge: OR 1.75, 95% CI 1.31–2.35; follow-up: OR 1.36, 95% CI 1.07–1.71);
- Lower mortality (in hospital: RR 0.72, 95% CI 0.55–0.95; follow-up: RR 0.87, 95% CI 0.77–0.97).

No additional primary studies of special geriatric units were identified. All the primary trials or observational studies we identified and rated as fair or good quality were included in the systematic reviews.

##### Inpatient Geriatric Teams

In addition to the 2011 Cochrane review,6 we identified one other systematic review,7 and five individual studies (not included in the systematic reviews) that assessed the impact of inpatient, multidisciplinary teams that included geriatricians.12–15, 18 The primary studies included three fair quality randomized trials12–14 and one fair quality observational study.15 The fifth study 18 was rated poor quality and is not included in our evidence synthesis (information available in Supplemental Materials).

The additional systematic review on inpatient teams had a narrow focus. Also published in 2011, it summarized the impact of CGA conducted by teams for patients who were going to be rapidly discharged from an emergency department or urgent care/assessment units.7 The five identified studies all included geriatricians. In two of these studies the intervention was geriatrician-led and targeted toward patients who sought care after falling, while in the other three studies, nurses led the assessment and the studies included patients admitted for any reason. This analysis found no significant reductions in falls over one year, readmission after 30 days or death or nursing home admission within three months for patients cared for by inpatient CGA teams compared to usual care. The small number of studies and the fact that the overall quality of these trials was reported as poor reduces the utility of this review.

The five additional individual studies do not provide sufficient evidence to counter the conclusion arrived at in these reviews that inpatient geriatric teams provide no additional benefit compared to standard care. Information from four of these individual studies is listed in Table 2.^12–15^ All four were of fair quality, conducted in the 1990s, and the three studies12, 14, 15 that examined function report small positive effects. (We have provided limited information on the study with poor methodological quality18 in the Supplemental Materials.)

##### Inpatient Geriatric Consultation

Another approach to geriatric inpatient care is the use of individual geriatricians as consultants, similar to any other specialist who might advise or contribute to the care of a patient in the hospital. This model of geriatric care was not included in the systematic reviews we identified. It was the subject of some individual studies, but differences in the nature of the consultation, the hospitals and time periods of the studies, as well as the generally low quality of the studies make it difficult to draw firm conclusions about the inpatient consultation model.

A good quality randomized controlled trial compared the effect of a comprehensive discharge planning intervention conducted by a geriatrician with standard care in 655 patients admitted to an acute geriatric inpatient unit.11 In this study, standard care included care by a geriatrician affiliated with the acute geriatric inpatient unit and the intervention added a second geriatrician who was not part of the unit team who focused on discharge planning. The percentage of people in the intervention group with at least one emergency department visit was lower than usual care at three months (23% vs. 30.5%; p=0.03) but not significantly different at six months (35.3% vs. 40.8%; p=0.15); similarly, survival was better in the intervention group at the three-month follow-up with no significant difference at six months.

Four other studies were of poor methodological quality.17, 19–21 They are listed in the Supplemental Materials.

### KEY QUESTION 1B Are there specific characteristics that lead to improved outcomes among inpatients?

Given the diversity among hospitals and patients, we are also interested in whether inpatient geriatric care is more effective for certain patients or if there are specific components of an intervention that are essential for positive outcomes. Three of the systematic reviews6, 8, 10 included in this Evidence Brief attempted to answer these types of questions.

In addition to comparing special geriatric units to floating teams, the authors of the 2011 Cochrane review conducted several additional sub group analyses.6 They compared: a) interventions that targeted patients who were frail and most at risk of nursing home admission or functional or cognitive impairment to interventions that enrolled patients based on age; b) interventions that initiated the CGA at different times (at admission to the emergency department, within 72 hours, or later in treatment); and c) whether the inpatient CGA provided outpatient follow-up or not. They found:

- No difference in outcomes attributable to targeting patients by selected criteria as opposed to age alone;
- Timing of the CGA was difficult to evaluate as this information was not always specified by study authors; and
- No clear link between post discharge geriatric follow-up and program benefits, defined as better outcomes.

The review of inpatient geriatric hospital units8 concluded that lack of detailed information on the usual care in inpatient units (the comparator) makes it difficult to isolate the effective components of the special geriatric acute care units. This is particularly true since it is likely that ‘usual care’ varies according to characteristics such as geographic area or type of hospital. The authors were unable to conduct planned analyses by patient characteristics because the studies did not report them adequately or because the range of patients’ ages was limited.

Similarly, the review of inpatient geriatric rehabilitation10 was unable to address whether targeting patients for enrollment or program characteristics make geriatric inpatient programs more effective, because few detailed descriptions of the interventions were available.

BOTTOM LINE

Patients receiving care in special geriatric units that are staffed by a team including a geriatrician have better function and are more likely to be discharged to home than patients receiving standard hospital care.

Neither inpatient geriatric units nor inpatient geriatric teams had lower patient mortality rates when compared with usual care.

There is [underlined: not] strong evidence that the use of geriatricians in special teams that conduct CGA and advise on patient care across hospital units (floating teams) results in better outcomes.

There is insufficient evidence to allow any conclusion about whether models of care that use geriatricians as inpatient consultants are effective.

For all types of interventions involving geriatricians in inpatient care,

- Detailed examinations of the impact of different components of the intervention, including the specific contribution of the geriatrician, are difficult to isolate from published studies; and
- More research is needed about what components of specific types of interventions are most likely to work.

### KEY QUESTION 2A What is the effectiveness of geriatric consultations, co-management, or geriatricians as primary care providers for outpatient primary care?

We identified five systematic reviews24–28 that summarize studies about models of geriatric outpatient care (Table 3). Systematic reviews were not included in our assessment of evidence if they did not include any studies in which geriatricians were part of the intervention or if the interventions in the included studies were not described.

Table 3 Outpatient: Systematic Reviews Summary

Year, First Author (Quality Rating) Type of Study (# of Subjects) | Type of Intervention | Subject of Study | Geriatrician Role/Tasks | Key Outcomes
Year, First Author (Quality Rating) Type of Study (# of Subjects) | Type of Intervention | Subject of Study | Geriatrician Role/Tasks | Mortality | Function | Nursing Home Admission/Living at Home | Utilization (Length of Stay/Rehospitalizations/Emergency Department use) | Medications
2008, Beswick25 (8/11) 89 RTs 97,984 | Teams/complex interventions | Community-based complex interventions to improve function and maintain independence | Geriatricians in 19 of the 89 interventions: 6 in studies of CGA; 8 in studies of targeted CGA; 4 in community follow-up post hospitalization; and 1 in a fall prevention program. | ~~~ | ~~~ | +++ | +++ | NR
2000, Byles27 (6/11) 21 RTs | Primary and Preventive Care | Health assessments for older adults | Two studies specifically include geriatricians. | Merged in review as health outcomes: Inconsistent results across the studies with geriatricians | | | | NR
2009, Ekland24 7/11 9 RTs | Teams/complex interventions | Coordinated and integrated interventions targeting frail elderly | In 3 of the 9 studies geriatricians are part of the intervention team. | NR | ~~~ | NR | -\-\- | NR
2008, Huss28 (8/11) 21 RTs 14,603 | Primary and Preventive Care | Multidimensional Preventive Home Visits | Geriatricians were involved in 6 trials; subgroup analyses conducted comparing interventions with and without a geriatrician. | ~~~ | ~~~~ | ~~~ | NR | NR
2004, Kuo26 (6/11) 9 RTs 3,750 | Teams/complex interventions | Effect of CGA on mortality | Geriatricians were involved in the intervention in all included studies. | ~~~ | NR | NR | NR | NR

* For systematic reviews, impact on key outcomes is limited to included studies that involve geriatricians.

Abbreviations: CGA = Comprehensive Geriatric Assessment; RT = Randomized trial.

Systematic Reviews, Summary Impact: +++ = Positive Impact; -\-\- = Negative Impact; ~~~ = No difference; ??? = Unable to determine; NR = Not studied or reported

Three of the identified systematic reviews focus on complex interventions, including CGA,24–26 while the other two reviews were about home visits and screening assessments.27, 28

We also identified 11 fair-or good-quality randomized trials and observational studies that were not covered by these reviews (Table 4): five evaluated team care or comprehensive models,29–33 four studied geriatricians acting as consultants,34–37 and two assessed geriatricians who provided primary care.38, 39

Table 4 Outpatient: Additional Primary Studies Summary

Year, First Author (Quality Rating) Type of Study (# of Subjects) | Type of Intervention | Subject of Study | Geriatrician Role/Tasks | Key Outcomes
Year, First Author (Quality Rating) Type of Study (# of Subjects) | Type of Intervention | Subject of Study | Geriatrician Role/Tasks | Mortality | Function | Nursing Home Admission/Living at Home | Utilization (Length of Stay/Rehospitalizations/Emergency Department use) | Medications
2008, Avila- Beltran38 (Fair) Obs (376) | Primary Care | Comparison of primary care provided by geriatricians and generalist physicians | DIRECT Primary care; outpatient prevention and management. | NR | NR | NR | NR | +
1999, Bula37 (Fair) RT (681) | Consultation | Preventive in home CGA for people with different baseline functional status | INDIRECT Geriatricians consulted with NPs who did the assessment and follow-up on the treatment plan. | ~ | + | NR | NR | NR
2007 & 2009, Counsell29, 42 (Good) RT (951) | Team | Geriatric care model for low-income seniors | INDIRECT NP and Social worker conducted home visits and follow-up. They were supported by a team including a geriatrician. | ~ | ~ | NR | + | NR
2009, Eloniemi- Sulkava31 (Good) RT (125) | Team | An outpatient multidimensional intervention for people with dementia that included services for spouse caregivers | DIRECT Geriatrician conducted assessment and ongoing visits after home visit by case manager, and collaborated with primary care provider. | NR | NR | + at 18 months ~ at two years | NR | NR
2006, Fenton34 (Fair) Obs (583) | Consultation | Geriatric assessment and planning in primary care | DIRECT Geriatricians met with patients twice to complete assessment and screening, and set goals and address problems. | ~ | NR | ~ | + | ~
2010, Li36 (Fair) RT (310) | Consultation | CGA of community- dwelling elders | INDIRECT Geriatricians reviewed assessments and prescribed treatment conducted by community doctors. | NR | ~ | NR | NR | NR
2010, Monteserin35 (Fair) RT (620) | Consultation | Follow-up intervention in Primary Care based on results of an Assessment | DIRECT Patients in intervention group assessed as at risk of frailty were visited by a geriatrician, and recommendations were made to their general practitioner. | ~ | + | + | NR | NR
2007, Phelan30 (Good) RT (784) | Team | Senior Resource Team included in Primary Care | DIRECT Geriatrician reviews assessments done by nurse practitioner and pharmacist, and develops care plan. Geriatrician reviews plan with primary care providers and with patient in person; and participates in intense follow-up for two months for all, and longer as needed on a case-by-case basis. | - Higher death rate | ~ | ~ | NR | ~
2008, Phelan39 (Good) Obs (140) | Primary Care | Comparison of primary care provided by geriatricians and generalist physicians | DIRECT Geriatricians provided primary care; outpatient prevention and management. | NR | NR | NR | NR | + Avoiding in appropriate meds
2007, Rubenstein32 (Fair) RT (792) | Team | Team approach to primary care for Veterans | INDIRECT Geriatricians supervised physician assistant case manager who did assessments and made referrals. | NR | ~ | NR | ~ | NR
2004, Schmader33 (Good) RT (864) | Team | The effect of GEM on adverse drug events and suboptimal prescribing | DIRECT Geriatricians are part of GEM team responsible for treatment and management. | NR | NR | NR | NR | +

Abbreviations: CGA = Comprehensive Geriatric Assessment; GEM = Geriatric Evaluation and Management; Obs = Observational study; RT = Randomized trial. DIRECT = Geriatrician interacted with patients; INDIRECT = Geriatrician did not interact with patients.

Individual Studies, Impact: + = Positive Impact; - = Negative Impact; ~ = No difference; ? = Unable to determine; NR = Not studied or reported

The role of the geriatrician varied in these studies. In some, the geriatrician conducted the assessment and/or follow-up visits with the patients. In Table 4, we have labeled these as ‘Direct’ to indicate that the geriatrician was directly involved in patient care. In other interventions, the geriatrician reviewed assessments or plans made by other health care providers and advised, but did not interact with the patients. We labeled theses as ‘Indirect’ in Table 4.

The systematic reviews of complex interventions are similar in scope to the additional primary studies of care by geriatric teams we identified, and they are summarized with these studies. The home visit and screening reviews are more closely related to primary care functions and, therefore, these reviews are reported with additional individual studies of primary care provided by geriatricians.

#### Geriatricians in Teams or Complex Models of Outpatient Care

Most of the studies included in the reviews, as well as our assessment across systematic reviews, found limited and inconsistent evidence of better outcomes from outpatient care provided by multi-disciplinary teams including geriatricians compared with usual care. The results are contradictory and interventions and outcome measures differed across studies.

One systematic review published in 2009 focused on coordinated and integrated interventions targeting frail elders, and identified nine randomized trials published between 1997 and July 2007.^24^ Three of the nine studies include geriatricians in the intervention. The reviewers provided details on individual studies and a narrative analysis. Results of the studies with geriatricians paralleled the overall conclusions of the review that results are mixed with limited evidence of benefit. For example:

- One of the three studies including geriatricians documented improvement in function, while two found no difference compared to standard care; and
- One study found an increase in health services by the intervention group; the second reported a decrease in health services utilization; and the third reported no effect on hospital days.

Another review by Beswick and colleagues identified 89 trials of complex interventions including 19 studies of care that involved geriatricians.25 The review subdivided interventions into 28 studies of CGA for elderly in general (geriatricians in six); 24 of CGA targeted to frail elders (geriatricians in eight); 21 of community-based follow-up post hospital discharge (geriatricians in four); 13 of fall prevention programs (geriatricians in one); and three about group counseling (none involved geriatricians). The review found that targeted and untargeted CGA and community follow-up were associated with:

- Fewer nursing home admissions (0.87, 95% CI 0.83–0.90)
- Improved physical function (standardized mean difference −0.08, 95% CI −0.11– −0.66)
- Lower risk of hospital admissions (0.94, 95% CI 0.92–0.97)
- No difference in mortality (1.00, 95% CI 0.97–1.02)
- Subgroup analyses of interventions compared by intensity or the involvement of multiple disciplines (studies with geriatricians were higher intensity and involved multiple disciplines) did not change the results.

Trials that were conducted prior to 1993 were more likely to find a positive effect than trials conducted later. The authors of the review speculate that this may be the result of the diffusion of geriatric best practices into general care.

The third synthesis of complex interventions we identified was a meta-analysis of the impact on mortality of CGA provided either as primary care or as an outpatient consultation.26 All the interventions in the included studies involved a geriatrician. The authors hypothesized that prior individual trials found no effect due to small sample sizes and conducted a meta-analysis to determine if merged data would produce a different conclusion. Instead, the meta-analysis affirmed that CGA does not result in lower mortality. There was:

- No effect of CGA on mortality (risk ratio: 0.95, 95% CI 0.82–1.12, p=0.62).
- No effect of CGA on mortality in any of the subgroup analyses, including:
  ○ Characteristics of the intervention
  ○ How long the patients were managed by the team conducting the CGA.
- No effect on mortality across subgroup comparisons of studies that were conducted in VA and not in VA.

We identified five additional good or fair quality randomized controlled trials of geriatricians in team outpatient care.29–33 Two studies rated as poor quality primarily because the articles did not provide sufficient information on the study.40, 41 These are described in the Supplemental Materials.

Two31, 33 of the three studies that involved geriatricians working directly with patients reported benefits including lower nursing home admissions and better medication management from team care, while one study reported a higher mortality rate that the researchers were unable to explain.30

- A study conducted in Finland targeted couples in which one had dementia.31 This randomized trial evaluated a multicomponent intervention including a caseworker, geriatrician, support groups, education, coordination of social services and collaboration with primary care providers. Control group couples received usual health and social services.
  ○ Results included a lower nursing home admission rate at 18 months (11.9% vs. 24.2%, p=.05) but no significant difference at two years (24.2% vs. 28.3%, p=0.64).
  ○ Overall costs per year for the couples was significantly lower for the intervention group (15,568 EURO vs. 23,553; p=0.03).
- A study of both inpatient and outpatient Geriatric Evaluation and Management (GEM) followed Veterans for 12 months to monitor adverse drug events, inappropriate drug use and underuse.33 GEM was compared to usual VA care.
  ○ In-patient GEM was associated with a decrease in unnecessary drugs, but no difference in serious adverse reactions.
  ○ Outpatient GEM was associated with significantly fewer serious adverse reactions (RR=0.65, 0.45 – 0.93, p=0.02) and fewer instances where drugs were omitted although they were indicated for the condition.
- A randomized trial of an intervention in which a geriatric team, including a geriatrician, NP, and pharmacist, working with primary care providers and patients, was conducted in primary care practices in Seattle, Washington.30
  ○ The intervention produced no significant differences in function, hospitalization or high-risk prescribing.
  ○ Significantly more people died in the intervention group than in the control group (11.4% vs. 7.1%, p=0.03) and the researchers were unable to explain this difference. They speculated it could have been due to unmeasured differences in illness severity or to confusion about whether the geriatrician or the primary care provider was making clinical decisions.

In the other two studies of teams, geriatricians supported other clinicians.29, 32 These studies of indirect geriatrician care in teams found small differences in health services utilization and cost, but no significant differences in mortality or function.

- The results of a randomized trial of an outpatient model called GRACE that targeted low-income seniors in Indianapolis, Indiana were reported in two articles.29, 42 The intervention consisted of a support team of a nurse practitioner and social worker who conducted homes visits and followed patients and coordinated care with primary care physicians. An interdisciplinary team, led by a geriatrician, reviewed cases weekly and contributed to care plans and management recommendations.29
  ○ At two years, there was no difference in mortality, function or hospitalizations.
  ○ There was some impact on utilization:
    ▪ Lower emergency department (ED) visit rates per 1000 (1445 vs. 1748, p=0.03) in the total sample
    ▪ Lower ED visits and hospitalizations rates for the predefined subgroup of patients at high risk of hospitalization (ED: 848 vs. 1314, p=.03; Hospitalization: 396 vs. 705, p=.03)
  ○ A follow-up cost analysis42 found no difference is costs during the two years of the intervention for either all subjects or the high risk subgroup, but in the third year, one year after the intervention period, costs were lower for the intervention group ($5,088 vs. $6,575, p<0.001).
- A randomized study in the VA evaluated an intervention in which primary care patients were screened and assessed by a physician assistant who referred patients requiring follow-up to a team including geriatricians for outpatient geriatric assessment. The comparison group received normal primary care.
  ○ The results included increased identification and evaluation of geriatric conditions but no improvements in function or reductions in hospitalization at follow-up in one, two and three years after the initial screening.32

#### Geriatricians as Outpatient Consultants/Specialists

Another model of outpatient care is one in which geriatricians provide consultations about older, frail patients to another clinician who has primary responsibility for the patient’s care. In some cases, the consultation involves direct contact with patients and in others, the consultation is limited to record review and discussions with the clinicians providing care. Two of the studies we identified evaluated geriatrician consultation that included direct contact with patients34, 35 and two examined consultations that did not.36, 37 The studies of consultations that include direct involvement in patient care show some improvement in outcomes in patients who are at high risk of frailty or identified as high service users. Two additional studies43, 44 were rated as low quality and are described in the supplemental materials.

A trial of a geriatric intervention in primary care randomized patients into two groups and then assessed all participants’ risk of frailty.35 Control group patients received usual care. The experimental group patients at low risk of frailty attended a group educational session, while those at high risk received a visit from a geriatrician who made recommendations to the patient and put these recommendations in the patients’ charts for their primary care provider and nurse.

- Comparisons between the entire intervention and control group found no effect on occurrence of, or time until, the primary outcome (a composite of death or admission to nursing home or home care).
- When only the patients at high risk of frailty were compared, there was a lower rate of death or admission to long-term care in the intervention group versus the control group (16.3% vs. 28.4%, p=0.028).
- Additionally, more of the high-risk patients in the intervention group compared to the control group reversed their frailty status (27.9% vs. 13.5%, p=0.027).

An observational study evaluated an intervention in which geriatricians met twice with patients who had high numbers of outpatient visits.34 During these consult visits, the geriatrician assessed the patient, solved problems and developed plans that were shared with the primary care physician as well as the patient. Patients seen by the geriatricians were compared to a group of patients from other primary care clinics in the same health system created by matching on sex and propensity scores.

- Intervention patients had a lower rate of hospitalization (0.57, 95% CI 0.37–0.86, p=0.01) and health care costs that were 26.3 percent lower (p=0.04).
- No significant differences in mortality, nursing home admission, high-risk prescriptions or other health care utilization were identified.

Two trials of consultation by geriatricians who advised other clinicians report limited impact on function.36, 37

A randomized trial conducted in the 1990s in California tested an intervention that included home-based assessments and follow-up visits by nurse practitioners who were supported by geriatricians in making diagnoses and developing care plans.37 The investigators reported that the impact on function varied depending on the baseline values. Specifically:

- The intervention group with no Activities of Daily Living (ADL) or Instrumental Activities of Daily Living (IADL) dependency at baseline spent more time at a lower level of disability (IADL only) and less time at a higher level (IADL and ADL) compared to similar patients in the control group. The investigator’s interpretation of the pattern of the results is that the intervention delayed or decreased dependency even if dependence was not completely prevented.

A randomized trial in Taiwan evaluated an intervention in which community elders were assessed by nurses and then geriatricians used the assessment to develop treatment plans to be carried out by community physicians.36

- There was a small and not statistically significant greater rate of improvement in functional status in the intervention group compared with the group receiving usual care.

#### Geriatricians as Primary Care Providers

The evidence about geriatricians as primary care providers is limited. This model of care was not directly covered in the identified systematic reviews. However, we have included two systematic reviews, one of screening home visits28 and the other of health assessments27 as the scope of these interventions resembles primary care. We found no randomized trials evaluating geriatricians as primary care providers. Three observational studies of this model of care either have a narrow focus on one outcome38, 39 or have methodological issues and were rated low quality due to a high risk of bias.45

A meta analysis of results of trials of preventive home visits published between 2001 and 2007 was conducted to update a prior review.28

- This analysis reported favorable but not statistically significant effects on mortality, nursing home admission and function.
- The authors stratified the studies by several intervention characteristics, including whether a geriatrician was involved, and found no significant effect on any of the outcomes.
- The inclusion of a clinical examination in the home visit was associated with a reduction in functional decline (OR 0.64, 95% CI 0.48–0.87).

The second systematic review aggregated studies of the impact of health assessments for older adults.27 This review is older (studies published between 1970 and 1999) and most of the trials tested assessments conducted by health care workers other than physicians with only two trials that included geriatricians. The authors did no subgroup analyses and highlighted the need for more information and research on the effectiveness of specific components of health assessments.

- The two studies included in this review with geriatricians involved in the intervention came to conflicting conclusions:
  ○ One found that health assessments produced no change in health outcomes and were cost neutral.
  ○ Another reported improvement in health outcomes at higher cost.

Two studies not included in the systematic reviews38, 39 compared geriatricians to generalist physicians who provided primary care to older adults. Both studies examined only medication management outcomes. The results of these studies suggest that geriatricians manage medications better for older adults than other clinicians.

- One study randomly sampled patients from a geriatric clinic or general family practice clinic at an academic medical center in the Pacific Northwest region of the US. Patients had to have designated a clinic physician as their primary care provider and had at least two visits in the past two years. Chart reviews were used to collect data on inappropriate medications and this was scored, with a high number representing less inappropriate medications.
  ○ Geriatricians scored better than generalists (14.2 vs. 11.8, p=.004); and in multivariate regressions, patient factors, such as age, were not associated with the score; while having a geriatrician as a primary care provider predicted a better score.39
- An observational study was similar in terms of its research questions, but involved patients and primary care practices in Mexico City. Medications prescribed over a one-year period were evaluated as potentially inappropriate or not for patients followed by geriatricians or other physicians.
  ○ Patients who did not have a geriatrician as their physician were found to be more than two times as likely to have a potentially inappropriate medication (adjusted odds ratio 2.59, 95% CI 1.54–4.34; p<0.001).38

### KEY QUESTION 2B Are there specific characteristics that lead to more effective outcomes among outpatients?

As was the case for inpatient studies, the evidence provides only limited insight into what components of geriatrician outpatient care might work best for what types of patients. The two systematic reviews of teams/complex interventions that attempted subgroup analyses25,26 failed to identify any characteristic that was more likely to be associated with any positive outcome. In our attempt to summarize the evidence, we separated team and consulting interventions according to whether the geriatrician provided direct patient care or not. The studies of interventions involving direct care appear to report more positive results for the outcomes studied than those involving indirect care. This difference is difficult to assess in a qualitative synthesis, and may be a fruitful topic for further research and synthesis. The available evidence about geriatricians as primary care providers is limited in terms of scope and quality. Additional studies are needed to determine if geriatric primary care is more effective for specific subgroups of patients or if there are aspects of geriatrician-provided primary care that are more likely to produce benefits.

BOTTOM LINE

More evidence is available about geriatricians in outpatient teams and consultant services than about geriatricians serving as primary care providers.

Geriatricians in teams and as consultants have some positive impact on function, living at home and health services utilization.

An initial assessment suggests that interventions in which geriatricians have direct patient contact are more likely to result in better outcomes than interventions where the interaction is limited to supporting other clinicians.

Geriatricians as primary care providers provide more effective medication management than other clinicians.

The evidence does not show that outpatient care involving geriatricians reduced mortality compared to usual care.

## LIMITATIONS

We identified numerous studies of geriatric models of inpatient and outpatient care, though both the identified models and how they were evaluated varied. Furthermore, the literature is limited in that it does not facilitate easy understanding of the contribution of the different components of these care models to better outcomes for older adults. This is because the model was usually evaluated, not the different components. Relevant to this review and brief, the contribution of geriatricians was not always delineated. The contribution of geriatricians was occasionally, but not frequently, studied independently of interconnected services that are often part of complex, integrated, or models of care. For this Evidence Brief, we have attempted to separate out information regarding the effectiveness of geriatricians that was included in studies of complex interventions; however, the need to do this is a serious restriction on our ability to use the currently available literature as the evidence on the effectiveness of geriatricians. We also identified and included studies of geriatricians acting more independently as consultants or primary care providers, but we identified fewer of these studies than studies of geriatric teams or other complex models.

There are several limitations that must be acknowledged given that this is an Evidence Brief and not a full systematic review. Brief or rapid review methodology is still developing and there is not yet consensus on what represents best practice. While we conducted an extensive bibliographic search, we limited the number of databases we searched, and we did not search for grey literature or research in progress. We used existing systematic reviews as the foundation for our evidence base, and we did not re-review all of the studies included in these. While we rated the quality of the reviews and focused on those that were both most relevant to our topic and of higher quality, we are dependent on the quality of these prior reviews.

## SUPPLEMENTAL MATERIALS

SEARCH STRATEGY

MEDLINE (PubMed) searched 3/2/2012

Concept | Search# | Search string | Results | Notes
Geriatrics | #1 | “Geriatrics”[Mesh] | 25696 | Note: Mesh terms
Geriatrics | #2 | (((gerontologist) OR geriatrician) OR geriatrics) OR gerontology | 57551 | aged, and aged 80 and over retrieved too many irrelevant hits to include
Geriatrics | #3 | #1 AND #2 | 57551 | aged, and aged 80 and over retrieved too many irrelevant hits to include
Care models | #4 | ((((((((“Geriatric Assessment”[Mesh]) OR “Personnel Staffing and Scheduling”[Mesh]) OR “Health Services for the Aged”[Mesh]) OR “Referral and Consultation”[Mesh]) OR “Patient-Centered Care”[Mesh]) OR ( “Patient Care”[Mesh] OR “Patient Care Team”[Mesh] )) OR “Case Management”[Mesh]) OR “Program Evaluation”[Mesh]) OR “Interdisciplinary Communication”[Mesh] | 677349
Non-geriatricians | #5 | ((((“Medical Staff”[Mesh]) OR “Physicians”[Mesh]) OR “Primary Health Care”[Mesh]) OR “Internal Medicine”[Mesh]) OR “General Practice”[Mesh] | 263691 | These broad Mesh terms include primary care physicians and hospitalists, and attempt to cover inpatient and outpatient settings, and are included to capture the relationship of geriatrics to other providers
Union of concepts | #6 | #3 AND #4 AND #5 | 848
Geriatric referrals | #7 | (“Geriatrics”[Mesh]) AND “Referral and Consultation”[Mesh] | 212 | Targeted search for geriatric consults
| #8 | #6 OR #7 | 987

Cochrane Central Register of Controlled Trials; Cochrane Library of Systematic Reviews; Cochrane Database of Reviews of Effects (OVID) Searched 3/2/2012

Concept | Search# | Search string | Results | Notes
Geriatrics | #6 | 1. exp Geriatrics/; 2. geriatrics.mp.; 3. geriatrition.mp.; 4. gerontology.mp.; 5. gerontologist.mp.; 6. 1 or 2 or 3 or 4 or 5 | 460 | With such a small retrieval (especially after deduplication), rather than further specify the search, it was left as is
Deduplication | After deduplication with MEDLINE citations 103 unique citations remain

MEDLINE (PubMed) searched

Concept | Search# | Search string | Results | Notes
Geriatric assessment | #1 | “Geriatric Assessment”[Mesh] | 15550 | Informed by Ellis 2011 Cochrane Review
Geriatric assessment | #2 | “Health Services for the Aged”[Mesh] | 13697 | Informed by Ellis 2011 Cochrane Review
Geriatric assessment | #3 | “Geriatrics”[Mesh] | 25701 | Informed by Ellis 2011 Cochrane Review
Geriatric assessment | #4 | ((((((“Needs Assessment”[Mesh]) OR “Risk Assessment”[Mesh]) OR “Diagnostic Services”[Mesh]) OR “Health Services Needs and Demand”[Mesh]) OR “Health Services”[Mesh]) OR “Delivery of Health Care”[Mesh]) OR “Outcome and Process Assessment (Health Care)”[Mesh] | 2353860 | Informed by Ellis 2011 Cochrane Review
Geriatric assessment | #5 | 3 AND 4 | 6030 | Informed by Ellis 2011 Cochrane Review
Geriatric assessment | #6 | 1 OR 3 OR 5 | 32979 | Informed by Ellis 2011 Cochrane Review
Geriatrics in the hospital | #7 | (“Hospitals”[Mesh]) AND “Geriatrics”[Mesh] | 1051
Geriatrics in the hospital | #8 | 7 OR 6 | 33370
RCT | #9 | ((((((((groups[tiab])) OR (trial[tiab])) OR (randomly[tiab])) OR (drug therapy[sh])) OR (placebo[tiab])) OR (randomized[tiab])) OR (controlled clinical trial[pt])) OR (randomized controlled trial[pt]) | 2941705 | Cochrane RCT hedge
| #10 | 8 AND 9 | 975
After deduplication with previous searches: 877 unique citations

DETAILED INCLUSION AND EXCLUSION CRITERIA

#### Inclusion criteria for inpatient studies (PICOTS)

- [underlined: P]opulation: Medical and surgical in-patients
- [underlined: I]ntervention: A geriatrician serving in the role of consultant or co-manager either individually or as part of a care team
- [underlined: C]omparator: Standard care (without the care of a geriatrician)
- [underlined: O]utcomes: Mortality, falls, length of hospital stay, re-admission rates, functional status, incident reports, discharge to nursing home, and the number of prescriptions prescribed
- [underlined: T]iming: No restriction on minimum study duration
- [underlined: S]etting: In-patient medical and surgical wards

#### Inclusion criteria for outpatient studies (PICOTS)

- [underlined: P]opulation: Outpatient (primary care) patients
- [underlined: I]ntervention: A geriatrician serving in the role of consultant or as part of a co-management team, or as a primary care physician
- [underlined: C]omparator: Standard care (without the care of a geriatrician)
- [underlined: O]utcomes: Mortality, hospital admission, emergency department visits, functional status, nursing home placement, falls, and the number of prescriptions prescribed
- [underlined: T]iming: No restriction on minimum study duration
- [underlined: S]etting: Outpatient (primary care) facilities
- Additional inclusion criteria: International studies (studies conducted outside of the United States) will be reviewed and included on an individual basis per their applicability to the specified outcomes of interest.
- In order to focus on the current and thus more relevant literature, we will include studies published after 1985

#### Exclusions

- Population: Studies that focus on disease specific populations, such as elderly cancer patients or patients with diabetes
- Intervention: (providers) Studies that do not include a geriatrician, including only other geriatric care providers such as Geriatric Nurse Practitioners (GNPs) and other non-physician health care providers such as geriatric pharmacists, as well as specialists who have extra geriatric training
- Intervention: (model of care) Studies that examine models of care that integrate acute and long-term care, such as PACE and EVERCARE
- Comparator: Studies that do not include an appropriate comparison group
- Outcomes: Studies that do not include outcomes (e.g., opinion articles, descriptive/discussion articles, and consensus statements.) and studies that examine outcomes outside of the proposed scope of work (e.g., patient satisfaction, physician job satisfaction)
- Setting: Nursing homes or other long-term care facilities

QUALITY RATING OF SYSTEMATIC REVIEWS: INPATIENT; USING AMSTAR CRITERIA^*^

| 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11
Author, year | Was an ‘a priori’ design provided? | Was there duplicate study selection and data extraction? | Was a comprehensive literature search performed? | Was the status of publication (i.e., grey literature) used as an inclusion criterion? | Was a list of studies (included and excluded) provided? | Were the characteristics of the included studies provided? | Was the scientific quality of the included studies assessed and documented? | Was the scientific quality of the included studies used appropriately in formulating conclusions? | Were the methods used to combine the findings of studies appropriate? | Was the likelihood of publication bias assessed? | Was the of conflict of interest stated? | Number yes
Bachmann 2010^1^ | Can’t answer | Yes | Yes | Yes; included some unpublished data | Yes (excluded studies list available on request) | Yes | Yes | Yes | Yes | Yes; funnel plots, and Begg and Egger tests | Yes | 10
Baztan 2009^2^ | Can’t answer | Yes | Yes | Yes | No for excluded studies; yes for included studies | Yes | Yes | Unclear; reported results of QA, but not clear how quality was used in synthesis | Yes | Yes; attempted funnel plots | Yes | 8
Conroy 2011^3^ | Can’t answer | Yes | Yes | Yes; appears to have included published data only, excluded one study for abstract-only | No for excluded studies; yes for included studies | Yes | Yes | Trials scoring less than a mean of 9 on the van Tulder critical appraisal score were excluded | Yes | Yes; funnel plots | Yes | 9
Day 2004^4^ | Can’t answer | Can’t answer; not reported | Yes | No; published studies only; English language only | Yes | Yes | Yes | Yes | Yes | Yes; assessed publication bias within reviews included | Yes | 8
Ellis 2011^5^ | Can’t answer | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | 9

* Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Medical Research Methodology. 2007;7:10.

QUALITY RATING OF SYSTEMATIC REVIEWS: OUTPATIENT; USING AMSTAR CRITERIA^*^

| 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11
Author, year | Was an ‘a priori’ design provided? | Was there duplicate study selection and data extraction? | Was a comprehensive literature search performed? | Was the status of publication (i.e. grey literature) used as an inclusion criterion? | Was a list of studies (included and excluded) provided? | Were the characteristics of the included studies provided? | Was the scientific quality of the included studies assessed and documented? | Was the scientific quality of the included studies used appropriately in formulating conclusions? | Were the methods used to combine the findings of studies appropriate? | Was the likelihood of publication bias assessed? | Was the conflict of interest stated? | Number of yes
Beswick 2008^6^ | Can’t answer | No for study selection; yes for data extraction | Yes | No | Yes for included; no for excluded | Yes | Yes | Yes | Yes | Yes | Yes for SR; no for included studies | 8
Byles 2000^7^ | Can’t answer | Can’t answer for study selection; yes for data extraction and QA | Yes | Yes; only included published studies | Yes for included; no for excluded | Yes | Yes | Yes | N/A; meta-analysis not attempted | No | Yes for SR; no for included studies | 6
Eklund 2009^8^ | Can’t answer | Yes | Yes | Yes; only English language and published in peer-reviewed journals | Yes for included; no for excluded | Yes | Yes | Yes | N/A; meta-analysis not attempted | No | Yes for SR; no for included studies | 7
Huss 2008^9^ | Can’t answer | Yes | Yes | No; no language restrictions; included unpublished data | Yes for included; no for excluded | Yes | Yes | Yes | Yes | Yes | Yes for SR; no for included studies | 8
Kuo 2004^10^ | Can’t answer | Yes | No; only 1 electronic source (Medline) plus supplemental | No | Yes for included; no for excluded | Yes | No | N/A | Yes | Yes | Yes for SR; no for included studies | 6

* Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Medical Research Methodology. 2007;7:10.

QUALITY ASSESSMENT OF RANDOMIZED TRIALS

| | | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9
Author, Year | Setting | Country | Appropriate randomization technique | Allocation concealment adequate? | Groups (intervention and control) similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Reporting of: a) attrition b) crossovers c) adherence d) contamination | Drop out rate <20 percent | Intention-to-treat (ITT) analysis | Appropriate statistical analyses | Quality rating | Funding source
Bula 1999^11^ | Outpatient | USA | Unclear | No | Yes | Yes | No | 6a) attrition: yes 6b) crossovers: no 6c) adherence: no 6d) contamination: yes | No | Unclear | Yes | Fair | Not mentioned
Counsell 2007 & 2009^12, 13^ | Outpatient | USA | Yes | Yes | Yes | Yes | Yes | 6a) attrition: yes 6b) crossovers: no 6c) adherence: no 6d) contamination: yes | Yes | Yes | Yes | Good | NIA, private foundations
Eloniemi-Sulkava 2009^14^ | Outpatient | Finland | Yes | Yes | Yes | Yes | Unclear | 6a) attrition: yes 6b) crossovers: no 6c) adherence: no 6d) contamination: no | Yes | Yes | Yes | Good | Finnish Slot Machine Association
Fallon 2006^15^ | Inpatient | USA | No | No | No | Yes | No | 6a) attrition: yes 6b) crossovers: no 6c) adherence: no 6d) contamination: no | Unclear | Yes | Yes | Poor | Non random trial...assignment based on day/time of admission
Gayton 1987^16^ | Inpatient | Canada | No | No | Yes | Yes | Yes | 6a) attrition: yes 6b) crossovers: no 6c) adherence: sort of 6d) contamination: no | No | No | No | Poor | National Health and Welfare, Canada
Germain 1995^17^ | Inpatient | US | Yes | Unclear | No | Yes | No | 6a) attrition: yes 6b) crossovers: no 6c) adherence: no 6d) contamination: yes | Yes | No | Yes | Fair | Regional Council 05 (Eastern Township) and the Ministry of Health and Social Affairs
Hogan 1990^18^ | Inpatient | Canada | Unclear | Yes | Yes | Yes | Unclear | 6a) attrition: yes 6b) crossovers: no 6c) adherence: no 6d) contamination: yes | Yes | Yes | Yes | Fair | University Internal Medicine Research Fund
Kerski 1987^19^ | Outpatient | USA | Unclear | Unclear | Yes | Yes | Unclear | 6a) attrition: yes, 6b) crossovers: no 6c) adherence: no 6d) contamination: no | Yes | Unclear | Yes | Poor | VA
Legrain 2011^20^ | Inpatient | France | Yes | Yes | Yes | Yes | Unclear | 6a) attrition: yes 6b) crossovers: no 6c) adherence: no 6d) contamination: no | Yes | Yes | Yes | Good | French Ministry of Health
Li 2010^21^ | Outpatient | Taiwan | No | Unclear | Yes | Yes | No | 6a) attrition: yes 6b) crossovers: no 6c) adherence: no 6d) contamination: no | No | No | Yes | Fair | National Taiwan University
McLean 1994^22^ | Inpatient | UK | No | No | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Yes | Poor | Not reported
Monteserin 2010^23^ | Outpatient | USA | Yes | No | Yes | Yes | Yes | 6a) attrition: yes 6b) crossovers: no 6c) adherence: no 6d) contamination: no | Yes | No | Yes | Fair | Research Unit, Sardenya Primary Health Care Center, Barcelona, Spain
Phelan 2007^24^ | Outpatient | USA | Yes | Yes | Yes | Yes | Yes | 6a) attrition: yes 6b) crossovers: no 6c) adherence: no 6d) contamination: no | No | Yes | Yes | Good | John A. Hartford Foundation, NIA
Phelan 2008^25^ | Outpatient | USA | Yes | Yes | Yes | Yes | Yes | 6a) attrition: yes, 6b) crossovers: no 6c) adherence: no 6d) contamination: no | No | Yes | Yes | Good | Jonn A. Hartford Foundation, NIA
Rubenstein 2007^26^ | Outpatient | USA | Unclear | Unclear | Yes | Yes | No | 6a) attrition: yes 6b) crossovers: no 6c) adherence: no 6d) contamination: yes | No | Unclear | Yes | Fair | VA
Schmader 2004^27^ | Inpatient, outpatient | USA | Yes | Yes | Yes | Yes | Yes | 6a) attrition: yes 6b) crossovers: no 6c) adherence: no 6d) contamination: no | Yes | Yes | Yes | Good | VA, NIA
Slaets 1997^28^ | Inpatient | The Nether-lands | Unclear | Yes | Yes | Yes | No | 6a) attrition: yes 6b) crossovers: no 6c) adherence: no 6d) contamination: yes | Yes | Yes | Yes | Fair | Not reported

QUALITY ASSESSMENT OF COHORT STUDIES

| | | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8
Author, year | Setting | Country | Did the study attempt to enroll all (or a random sample of) patients meeting inclusion criteria, or a random sample (inception cohort)? | Were the groups comparable at baseline on key prognostic factors (e.g., by restriction or matching)? | Did the study maintain comparable groups through the study period? | Did the study use accurate methods for ascertaining exposures and potential confounders? | Were outcome assessors and/or data analysts blinded to the exposure being studied? | Did the article report attrition? | Did the study perform appropriate statistical analyses on potential confounders? | Is there important differential loss to follow-up or overall high loss to follow-up? | Quality rating | Funding source
Avila-Beltran 2008^29^ | Outpatient | Mexico | Yes | No | No | Yes | No | Yes | Yes | No | Fair
Egger 2006^30^ | Inpatient | Switzerland | Yes | No | No | Yes | Unclear | | No | No | Poor | Swiss National Science Foundation Grant
Famadas 2008^31^ | Outpatient | USA | Yes | Yes | Yes | Yes | No | Yes | Yes | No | Good
Fenton 2006^32^ | Outpatient | USA | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | No | Fair | Robert Wood Johnson Foundation
Hermush 2009^33^ | Outpatient | Israel | Unclear | No | No | No | No | No | No | Unclear | Poor | No study sponsors.
Inouye 1993^34^ | Inpatient | USA | No | No | No | Yes | Yes | Yes | Yes | No | Fair | Various grants, including one from Sandoz Foundation
Pawlson 1988^35^ | Inpatient | USA | Yes | No | No | Unclear | Unclear | No | No | No | Poor | National Institute on Aging Geriatric Medicine Academic Award
Peleg 2008^36^ | Outpatient | Israel | Yes | Unclear | Unclear | | No | No | No | Unclear | Poor | Not reported
Phillips 2005^37^ | Outpatient | USA | Yes | No | Unclear | No | Unclear | No | No | Unclear | Poor | Not reported
Sennour 2009^38^ | Inpatient | USA | Unclear | Unclear | Unclear | Unclear | No | No | No | Unclear | Poor | Methodist Health Foundation, Donald W Reynolds Foundation, John A Hartford Foundation, National Institute on Aging and Clarian Health

INPATIENT STUDIES WITH POOR QUALITY RATINGS

Year, First Author Study Design (# subjects) | Type of Intervention | Comments/Reason for Poor Rating
2006, Egger30 Obs (800) | Special Units | Unit patients had lower mortality and fewer prescriptions at follow-up compared to baseline, but results must be interpreted with caution given baseline differences in groups and methodological challenges.
2006, Fallon15 Trial (285) | Consultation | Non-random assignment by time of day of admissions determined if patient received a consultation. Additionally, other study design elements have the potential to introduce significant bias in the results.
1987, Gayton16 RT (402) | Team | No difference in mortality, LOS, NH admission or function. Poor quality due to randomization issues, drop out and non intention to treat approach to analyses.
1994 McLean22 Obs (2,496) | Consultation | Based on need patients were assessed when admitted, and assigned both a general physician and a geriatrician. Several elements of the study were not described.
1988, Pawlson35 Obs (270) | Consultation | Study compared inpatient management by geriatricians to management by general internists; however, groups were not comparable at baseline, and data collection and measurement issues were not described or addressed.
2009, Sennour38 Obs (1,538) | Consultation | A descriptive study of consultation model in one hospital. Many elements of the evaluation study were not described and data were not always provided for the comparison group.

OUTPATIENT STUDIES WITH POOR QUALITY RATINGS

Year, First Author Study Design | Type of Intervention | Comments/Primary Reasons for Poor Rating
2007, Famadas31 Obs | Team/Clinic | Primarily descriptive study of new program and most elements of the evaluation component are not described. Authors caution that selection bias is likely to be very high.
2009, Hermush33 Obs | Consultation | Visits to general practitioners were lower in patients seen by the geriatrician, but groups differed; confounding was not addressed sufficiently, and key criteria were not reported or met.
1987, Kerski19 RT | Team | All patients received a CGA, and then were randomized to follow-up in geriatric clinic with an interdisciplinary team or a general clinic with no team. No difference was found in key outcomes. Rating is based on lack of reporting of key characteristics of the trial.
2008, Peleg36 Obs | Consultation | Hospitalizations declined after the implementation of a multipart intervention that included a geriatric liaison service to the primary care clinic. The study is a pre-post design that did not meet many quality criteria and did not provide statistical tests of reported differences.
2005, Phillips37 Obs | Primary Care | Study compares patients in geriatric primary care practice to those in general medicine practices in the same health plan and finds that they have different utilization patterns and lower costs. However, differences are not statistically significant; the groups differ and confounding is not sufficiently addressed.

REVIEW COMMENTS/RESPONSES

Reviewer No. | Comment | Response
1. Are the objectives, scope, and methods for this review clearly described?
1 | Yes. | -\-
2 | Yes -\- The Authors have done a complete analysis of the available data. | -\-
3 | No -\- As noted in the comments below and attached documents, many of the terms and outcomes are poorly or loosely defined, i.e. effectiveness. Even the title, value of geriatricians, while catchy, is vague. | We have attempted to be more precise in specifying outcomes when reporting results. We have changed the title of the review.
4 | Yes. | -\-
5 | Yes. | -\-
6 | Yes. | -\-
7 | Yes. | -\-
8 | Yes. | -\-
2. Is there any indication of bias in our synthesis of the evidence?
1 | No. | -\-
2 | No. | -\-
3 | Yes.; 1. The choice of the impact of the geriatrician on mortality as the main outcome measure is problematic. The vast majority of geriatric consults and management issues focus on geriatric syndromes, quality of life, rehabilitation, case management in older adults with multiple medical problems. A priori one would not anticipate that in the majority of the settings, the intervention, often only one of many that these complex patients have received would have any measureable impact on mortality. Delayed admission to a nursing facility, reduced stress in a caregiver, reduced polypharmacy, etc. are highly significant outcomes in this population. The focus on mortality sends the wrong message.; 2. The study eliminates PACE and other interventions that are more broadly integrated along the continuum of care in older adults (supplement). These are the types of interventions that would most likely show benefit, and potentially reduce mortality yet they have been excluded from this paper.; 3. The VA health care system has its own rewards and challenges. The vast majority of studies quoted were not conduced in the VA and their applicability to the integrated VA health care system is uncertain. The authors should temper their conclusions given the scarcity of high quality randomized clinical trials in older veterans. Certainly except for the GEM trial conducted more than a decade ago, few if any trials have sufficient power to detect changes in mortality.; 4. QUERI and cooperative studies programs at the VA should partner with the GRECCs to initiative multicenter trials to more definitively examine the issues raised in this manuscript. | 1. We revised the methods section to clarify that our outcomes included mortality, function, nursing home admission/or living at home, utilization (hospital admission or readmission, emergency department visits, outpatient visits), or medication management (appropriateness, number, or adverse events). These were specified at the start of the review, before the evidence was collected.; 2. We excluded PACE and similar interventions because long-term care was excluded in the scope of work for this review. Programs such as PACE integrate long term care and acute care and the impact cannot be separated. This was specified before we conducted the search and corresponded to the priorities of the requestors.; 3. We agree that direct evidence is sparse. Our objective was to summarize all available research.; 4. This is a ‘future research need’ and could be a possible result of the review.
4 | No. | -\-
5 | No. | -\-
6 | No. | -\-
7 | No. | -\-
8 | Yes -\- No really bias but more a misunderstanding of the goals of the review. For example mortality is an irrelevant outcome when evaluating the value of geriatricians but the synthesis makes it look like the most important (negative) outcome | The organizations requesting this brief specified a priori that mortality was one of several outcomes of interest. When appropriate, we have edited the report to clarify that mortality was not our only outcome of interest (e.g., by reporting other outcomes before mortality outcomes in summary statements, etc). However, we cannot change the fact that it is one of the most frequently studied outcomes, and we believe we should report that information.
3. Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
1 | No -\- I have limited experience to really address this question. | -\-
2 | No. | -\-
3 | Yes -\- No overt mention about interventions to prevent or manage delirium in hospitalized patients. These studies should be included. | When identifying and managing delirium was part of geriatric care, the studies were included.
4 | No. | -\-
5 | Yes -\- Possibly, see #4 re: search strategy. | See response below.
6 | No. | -\-
7 | No. | -\-
8 | Yes -\- Studies related to patient/family satisfaction, improved communication and its relation to tort claims. | These outcomes were specifically excluded by the scope of work agreed to by the researchers and the groups requesting this review.
4. Please write additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
1 | Page 17: under Bottom line: the second para must have been truncated. “ an initial assessment ……are more like???? | Text was revised.
1 | Page 6. It is unclear if you are referring to comparison between care on an acute medicine unit and a specialized geriatric unit. ( para 2. ) It has not been my experience that acute admissions are made to a geriatric specialized unit but rather to an acute medicine unit and then once stable the patient is sent to the specialized geriatric unit. It is unclear whether this is truly a direct comparison. SIMILAR COMMENT FROM EMAIL MESSAGE: Just a question for clarity: Page: 6. Interventions on specialized units vs. floats on units. Were the “floats” providing care on rehab specialized units or acute medicine wards units? Were the” specialized hospital units” rehab or considered acute medicine units? | In the RCTs, patient who are admitted are randomly assigned to these specialized units. These are not long- term care or transitional units. They are acute care units that specialize in the care of elderly patients. The assignment of the teams varied somewhat by study, but from the descriptions in most studies the ‘floating teams’ provided care across a variety of units. What varies is how the patients are referred to the team (automatically or at the request of a treating physician), and whether the team becomes directly involved in care or if its recommendations are given to the clinicians with primary responsibility. We have edited the report to clarify these points.
1 | “Veterans who seek medical care are aging. The proportion of all Veterans 65 and older [underlined: who enroll] in the VA health care system is projected to increase to 43 percent in 2013, up from 31 percent in 2003.^1^ Enrollees age 85 and older are expected to have an even greater growth: from 20 percent in 2003 to 51 percent in 2013.” Do they mean who are enrolled? Or are these data for expected new enrollments? | The text has been revised to clarify that this is the percent of older Veterans who enroll in VHA for health care.
2 | Clearly one of the reasons why a CGA done on inpatients may not have as much benefit if there is no direct involvement by the Geriatrician in the patient’s care is the lack of follow-through by the primary care team on the recommendations made by the Geriatric Assessment Team. A mechanism to insure better follow-through would improve care/outcome in my opinion and the data should not be misinterpreted that the CGA has no value.. it does! | The commenter raises a good point, but because studies within our scope did not report results according to whether primary care teams followed through on the geriatrician’s recommendations, it is not possible to draw conclusions about this. Studies of follow through on recommendations probably do exist but they were outside the scope of this review.
3 | This document has been reviewed by myself and my colleague Dr. Jacob Blumenthal, a geriatrician who co-directs our geriatric medicine fellowship program and geriatric assessment clinics. We both had major concerns about this manuscript, particularly the use of mortality as the main outcome metric. We have provided many comments in the reviewer sheets and throughout the document (including one major typo). It is clear that few high quality larger randomized clinical trials have been performed that would specifically address many of the issues that this review is examining. QUERI and cooperative studies programs at the VA should partner with the GRECCs to initiative multicenter trials to more definitively examine the issues raised in this manuscript. | Thank you for the comments and we have revised the text. Mortality is one of several outcomes included in the scope of work as agreed to and specified by the requestor. We have edited the text to clarify this point.
3 | The key messages (page 1) seem frankly biased, and not the conclusion I draw from the scant literature. I would argue that what is the message from this review is that there is insufficient research into the value of Geriatrician involvement. The null hypothesis is that there is no difference in outcomes when Geriatricians are involved, and if any conclusion is to be drawn, it is that there is insufficient evidence to reject this.; 1. However, I would point out that certainly, mortality is likely the wrong primary metric! It may be interesting to compare mortality among patients cared for by Geriatricians/not, but to do these sort of randomized controlled trials would likely involve huge numbers, given the high likelihood of the outcome regardless of group assignment.; 2. A number of more meaningful metrics might include measures of morbidity such as ED/unplanned office visits, falls, adverse drug events, dependency, institutionalization….; 3. For example, I would suspect that post discharge geriatric follow-up would be associated with lower readmission (as follow-up arrangements have been demonstrated to do in a number of other settings – c.f. CHF, psych, ED), although this is by no means universal in the literature. This latter point highlights the importance of also understanding/accounting for the baseline characteristics of the group(s) examined (c.f. below – point 7). | We believe an evidence review should summarize what is known from the available research. Reviews may also highlight where more research is needed, but to avoid conclusions and only suggest more research is needed is not sufficient in our opinion. We have revised the key point wording.; 1 and 2 Outcome measures were pre- specified. Mortality was one of but not our primary outcome measure. We included these other outcomes (ED visits, adverse drug events, institutionalization, etc.) and reported them when available. We have revised the text to clarify this.; 3 Follow-up was not reported in all studies, but was included when it was available. Our ability to address this is limited by the research available. Results for Key Question 1B include what information we were able to locate. The recent Cochrane review did compare the results of studies of interventions that included outpatient follow-up after inpatient geriatric care and those that did not. They found no difference in the outcomes across studies when they compared these two groups.
3 | On the same page, Geriatric Syndromes may contribute to, but don’t necessarily cause many of the problems listed. | Edited as suggested.
3 | The handling of systemic reviews in these analyses is unclear (page 3). Are data from included studies “double-counted” (once as individual trial and again as meta-analysis? | We revised the methods to clarify that we only included individual studies that were not already included in a systematic review.
3 | On page 4, and following, the metric upon which these conclusions are made remains unclear. The words “effectiveness” is used (Key Question #1A, page 4 and following), but the measure appears to be mortality (problematic as above). Furthermore, also unclear (?uniform across study) is at what point in time it is assessed…. No one gets out of this world alive, and certainly those cared for by Geriatricians are no exception | (Page 4 lists the key question) We have listed our outcome measures (which include, but are not limited to, mortality) and when discussing particular studies, have made sure to note the time period of the outcome measure.
3 | The final paragraph on page 5 seems all alone and without a conclusion. What was the conclusion of the “technology assessment” (and what is this?) conducted by the New Zealand Department of Public Health and General Practice? What model(s) of care were examined? What were the measures? outcomes? | The technology assessment is not discussed in detail because it included the same studies that are also included in another, more recent systematic review. We have clarified this in the text.
3 | The speculation of the authors cited on page 6 “special units allow the geriatric team to have more control over care, including implementation of the recommendations based on CGA, and permit the development of greater expertise among everyone who works on the unit” is certainly a reasonable and testable hypothesis. This again points out another “hole” in the literature needing filling. Although, again, just because we don’t know what the effect is/haven’t proven its existence, does not mean that there is no effect. Prior to the DCCT, the value of “tighter” glycemic control was unproven, yet such an approach certainly was beneficial prior to 1993. | We revised the text to clarify that this speculation was made by the authors of the cited review, not the authors of this brief. The literature and the summary in this brief suggest several potential avenues for future research; however, developing a future research agenda is outside the scope of an Evidence Brief. We do hope the Brief might inform others who might take on this task in the future.
3 | With regards to Key Question 1b, on page 8, if outcome = 3 month mortality, not surprising that no relationship found with follow-up…. Certainly it is intuitive (at least to me) that there are “baseline” characteristics that are predictive of better outcomes. If data is insufficient to account for these, I don’t see how one can dismiss this likely “confounder.” As above, would suspect that post discharge follow-up (geriatric or otherwise) would be associated with lower readmission, but this is likely significantly impacted by characteristics of the discharged patient. | Yes, this is a possible and a potentially useful area for future research. In conducting a brief review of existing evidence, we are limited to the studies available, and have attempted to provide enough information without making this Brief excessively long to allow different readers to assess these potential issues.
3 | Bottom lines on page 9 are overstated, as above. In particular:; 1. I should hope that Geriatric Teams don’t reduce MORALITY (sic)….; 2. Similarly, this statement (understood as referring to mortality) is not evidence-based, as intimated above in #1. | Corrected typo. Thank you for pointing this out.
3 | On page 12, it is noted that the summarized systematic reviews have a “focus on models of care and…summarize a mix of studies that both include and do not include geriatricians.” Furthermore, the role(s) of the Geriatrician(s) is often unclear, and certainly not obviously uniform. Given these limitations, it is difficult to then use these as blanket indictments of Geriatrician involvement. | Text has been revised to clarify. We agree that it is difficult to separate out the effect of the geriatrician in many studies – this was a major limitation of the evidence base. However, we did not include a systematic review unless it was possible to tell if studies included geriatricians, and we provided this information in Tables 1 and 3. We used results based on the studies that include geriatricians when presenting the conclusions of systematic reviews.
3 | Certainly the “bottom line” found on page 17 does not make it to the “Key Messages” on page 1…and likely should. | The Bottom Line box is about the finding for outpatient studies, and the Key Messages are the overall conclusions of the review. We have clarified wording, but they are not meant to be the same.
3 | With regards to the limitations listed on page 22, these are understated. Certainly, the “large number” of studies cited is somewhat of an overstatement given their broad diversity. It is exactly because “the model was usually evaluated” and it differs between studies, that it is difficult reach blanket conclusions about “Geriatric Assessment” or Geriatrician “involvement.” Nonetheless, evaluating “parts” of what is often a multidisciplinary process, and always a multifaceted one, will likely underestimate its net effect(s). | Text has been revised to clarify and incorporate these points.
3 | The “take home” message of this review is that there is a paucity of data regarding the effect Geriatricians have, as well as the reasons behind this. The “key questions” outlined on page 2 are excellent starting points, and should (with specific, measurable and clinically meaningful outcomes) be the subject of large, randomized controlled trials. | Text has been revised to highlight the limitations of the data available.
4 | On page 17 in Bottom Line box: the 3^rd^ item, second sentence (beginning “An initial assessment suggests…”) has a typo or missing words. | Text has been revised to address this.
4 | See copy of draft for more suggestions. | Comments in the draft have been addressed.
5 | RE: 3/2/12 search (#1,2,5,6,7) add a [tiab] tag at the end of the search term so it only searches for the keyword phrase in the title and abstract of a PubMed record, which helps improve precision in the retrieval. RE: 3/2/12 search (#4) The subject terms used in the current search strategy in the document you sent are pretty thorough and appropriate. The main issue I see after further searching is that there’s no good/precise Medical Subject Heading (MeSH) term in PubMed/Medline and other databases that captures “Care Model” as a concept. Below are some keywords that could be used for searching the titles and abstracts in PubMed to perhaps pull in some relevant articles related to Care Models. management model[tiab] model of care[tiab] care approach[tiab] care intervention[tiab] care program[tiab] integrated approach[tiab] integrated system[tiab] integrated model[tiab] system of care[tiab] framework[tiab] paradigm[tiab] I would “OR” these phrases together and combine them with other relevant MeSH terms, such as Geriatrics Assessment or Health Services for the Aged and then NOT the publications I don’t want, such as letters, case reports, editorials, etc. Example: (management model[tiab] OR model of care[tiab] OR care approach[tiab] OR care intervention[tiab] OR care program[tiab] OR integrated approach[tiab] OR integrated system[tiab] OR integrated model[tiab] OR system of care[tiab]) AND (“Health Services for the Aged”[Mh] OR “Geriatric Assessment”[tw]) NOT (letter[pt] OR case reports[pt] OR editorial[pt]) AND english[la] The strategy above yields about 237 citations. Many will be related to a specific disease or condition (e.g., falls, dementia, depression), but you may also find some that are specific to geriatric assessment and care models in general. RE 3/9-12 Search (#1-10) add a [tiab] tag at the end of the search term so it only searches for the keyword phrase in the title and abstract of a PubMed record, which helps improve precision in the retrieval. | Thank you for these suggestions.
6 | Page 1: “Key Messages”—I would reorder so that the first bullet is the last (i.e., list positive findings first, then negative finding) | Edited as suggested.
6 | Page 1: “Introduction” 3^rd^ paragraph, 4^th^–5^th^ line: “Given these small numbers”—not very informative. Why are those numbers small? (e.g., 500,000 MDs for 300M people is a ratio of 600:1; 7000 geriatricians for 40M people age 65 and over is 1:5,700) | The sentence has been deleted. Discussing why there is a shortage of geriatricians is outside the scope of this Brief.
6 | Page 2: “Methods”—paragraph 2. insert “:” following the first use of “intervention” in line 3.; lline 4, change “living at home” to “discharge to home”; line5, insert “Bed Days of Care” after “readmission” [only if this is true, of course…) | Text revisions have been made to address these points.
6 | Page 6: bottom 1/3 of page, third bullet point “And no difference in readmission at three months”— following the Confidence Interval, should the word “or” instead be the word “among?” | Text corrected as suggested.
6 | Page 9: “Bottom Line”—would move 2^nd^ bullet to become first bullet (as above, Positive finding, then negative findings). | Text edited as suggested.
6 | Page 14: top of page, second open bullet: after Relative Riak figures, should this read “and a few instances…” instead of “and few instances?” | Text corrected.
6 | Page 17: top 1/3 of page, first open bullet: “then” should be “than” | Text corrected.
6 | Page 17, bottom 1/3 of page, red-bordered box:; 1. any reason for the different format compared to “Bottom Line” on page 9?; 2. move second statement to end (positive findings, negative findings); 3. second line: change “bout” to “about”; 4. Third paragraph, third line, I am guessing this should read “…are more likely to improve outcomes than intervention where…” | 1. Made format consistent; 2. Edited as suggested; 3. Corrected typo; 4. Edited sentence
7 | I was very interested in the primacy that the outcome of mortality seemed to take in the manuscript. While this is clearly one of the outcomes that emerged as being common to many of the individual studies, for this analysis there is no reason to place the mortality outcomes first in each area of discussion. I believe that many geriatricians would feel that mortality is a confounded outcome in many of these studies. The goal of geriatric care and geriatric models of care is frequently not to extend mortality. I have been involved in studies of models where the geriatric approach led to early referral to hospice or comfort care, making the mortality effects difficult to interpret. Since functional outcomes are likely to be more valued by patients and providers for this population, there is no reason to present the functional effects as a “secondary outcome.” | Mortality was one of our outcomes, but not our primary outcome measure. This has been clarified in the text. The frequency with which mortality is discussed is the result of how many studies included this as an outcome.
7 | I also felt that there is a lack of parallelism between the inpatient and outpatient analyses as presented in the manuscript. On face value the key messages seemed the same across the inpatient and outpatient realms, i.e. that more direct involvement by geriatricians produced better functional outcomes. However, the split for inpatient was most important for who had charge of the patient i.e. special geriatric unit vs. float team or consultation. This seems quite different from the split in the outpatient realm which fell between direct patient contact and indirect involvement. The difference can be highlighted by the role of consultation by an individual geriatrician which seemed to be not effective on the inpatient side, but associated with positive outcomes on the outpatient side. I think that the analyses and choices of split were fine for inpatient and outpatient side, but they were presented as showing parallel and analogous outcomes that are really not justified by the data. | We have attempted to clarify this in the text revisions.
8 | Please see numerous comments entered directly on the draft document. | Thank you. These have been addressed.
5. Are there any VA clinical performance measures, programs, quality improvement measures, patient care services, or conferences that will be directly affected by this report? If so, please provide detail.
1 | Yes, an increase in outpatient geriatricians was requested and this will be used in that deliberation. | -\-
3 | If in fact this report is accepted as providing evidence of minimal impact of geriatricians on healthcare outcomes in a variety of settings in older adults, ongoing initiatives to integrate geriatricians into PACTs, implementation of geriatric emergency departments, GEM and geriatric acute care units, etc. may be scaled back or eliminated. This is particularly problematic given that few of the studies have been conducted in the VA and the metric of whether the clinical care provided by geriatricians in these settings decreases mortality is not the main outcome(s) of interest. These analyses highlight the need for larger scale, good quality randomized control trials to more directly test the key questions proposed on page 2. | -\-
4 | Validates value of GEM Unit program in the VA system. Supports further development of Acute Care for the Elderly inpatient units in the VA as well as outpatient geriatric consultation teams providing direct patient contact. | -\-
6 | Ongoing discussion within the Healthcare Delivery Committee of the NLC concerning recommendation for growing geriatric inpatient and outpatient presence in VAMCs. | -\-
7 | This seems to directly inform the role of geriatrics in PACT models. | -\-
8 | Yes, big impact on workforce deployment in geriatric settings. | -\-
6. Please provide any recommendations on how this report can be revised to more directly address or assist implementation needs.
1 | Has there been the opportunity to review surgical inpatient care with and with geriatrics for same age groups to see if the outcomes are improved with geriatric care? | We did not separately evaluate studies of surgical inpatient care. There are some studies available that look at specific orthopedic surgeries with and without geriatric involvement, but these were outside the scope of this Brief.
1 | And can we group by gender at all ( since VA has many more men and private sector many more women in clinics ?) | Studies and systematic reviews do not provide enough information to allow this within the format of an Evidence Brief.
2 | It would be worth prospectively evaluating CGA recommendations and determine how follow-through affected outcome versus merely grouping all patients who had the CGA together. | Agree that this would be a useful area for future research.
3 | Many areas should be changed (also see attached comments).; 1. The title itself, “The value of geriatricians” should be changed as geriatricians typically are part of larger multidisciplinary teams and virtually none of the studies quoted were designed to tease out the contribution of the geriatrician per se to the outcomes. Would recommend a more generic, broader title, “impact of geriatric consultation and management on health care outcomes in older adults” or something along these lines.; 2. Key message first bullet about mortality should be moved to the third bullet with more emphasis on functional outcomes, rather than mortality; 3. The term effectiveness is used loosely without clear definition.; 4. Time points of downstream outcome measures are not consistently defined (for example discussion about inpatient geriatric teams page 7). | 1. Title has been revised, but we do include studies where geriatricians are not part of the team and function as individual specialists or primary care providers, so we cannot have the title be limited to specific models.; 2. Bullets have been reorganized; 3. We have added the outcomes that we used to define effectiveness for this review.; 4. When they were provided and/or considered in a study or systematic review they are reported. In the Evidence Brief format, we are not able to follow up with authors or check other sources to obtain additional details.
5 | Agree with summary findings as reported – use of search strategy in #4 may yield additional pertinent references.
6 | None -\- nice job. | -\-
7 | I would like to see more direct suggestions about studies that could address current deficiencies in the data. | Developing a future research needs report would be interesting and could be informed by this initial effort; however, it is outside the scope of an Evidence Brief.
8 | English language search may have limited valuable data. The European Union based on their review of literature has recently mandated geriatric specialty in all its member nations and established very strict guidelines regarding staffing by geriatricians at all levels of clinical care. | Although we agree that the exclusion of non-English language literature is a limitation of this rapid review, we did not have the resources to permit translation.
7. Please provide us with contact details of any additional individuals/stakeholders who should be made aware of this report.
| | -\-

LIST OF EXCLUDED STUDIES

Excluded Trials | Exclusion Code
1 AARP, Academy of Managed Care P, American College of Clinical P, et al. Sound medication therapy management programs. Case Manager. Jul–Aug 2006;17(4):47–50. | Publication type
2 Ahmed A, Allman RM, Kiefe CI, et al. Association of consultation between generalists and cardiologists with quality and outcomes of heart failure care. Am Heart J. Jun 2003;145(6):1086–1093. | Intervention
3 Allard J, Hebert R, Rioux M, Asselin J, Voyer L. Efficacy of a clinical medication review on the number of potentially inapprrropriate prescriptions prescribed for community - dwelling elderly people. CMAJ. 2001;164(9):1291–1296. | Intervention
4 Allen CM, Becker PM, McVey LJ, Saltz C, Feussner JR, Cohen HJ. A randomized, controlled clinical trial of a geriatric consultation team. Compliance with recommendations. JAMA. May 16 1986;255(19):2617–2621. | Outcome
5 Applebaum R, Straker J, Mehdizadeh S, Warshaw G, Gothelf E. Using high-intensity care management to integrate acute and long-term care services: substitute for large scale system reform? Care Manag J. Spring 2002;3(3):113–119. | Setting
6 Applegate WB, Miller ST, Graney MJ, Elam JT, Burns R, Akins DE. A randomized, controlled trial of a geriatric assessment unit in a community rehabilitation hospital. N Engl J Med. May 31 1990;322(22):1572–1578. | Population
7 Arbaje AI, Maron DD, Yu Q, et al. The geriatric floating interdisciplinary transition team. J Am Geriatr Soc. Feb 2010;58(2):364–370. | Outcome
8 Asplund K, Gustafson Y, Jacobsson C, et al. Hospital care for the elderly with acute medical illness. A randomised comparison of geriatric-based versus general wards [abstract]. 2000. | Publication type
9 Atkin NL, McInnes EC, Mira M, Kennedy P. GPs and geriatricians working together. Med J Aust. Oct 20 1997;167(8):455–456. | Outcome
10 Bachman SS, Collard AF, Greenberg JN, et al. An innovative approach to geriatric acute care delivery: the Choate-Symmes experience. Hosp Health Serv Adm. Nov 1987;32(4):509–520. | Intervention
11 Bakker FC, Robben SHM, Olde Rikkert MGM. Effects of hospital-wide interventions to improve care for frail older inpatients: a systematic review. BMJ Qual Saf. Aug 2011;20(8):680–691. | Intervention
12 Barker WH, Williams TF, Zimmer JG, Van Buren C, Vincent SJ, Pickrel SG. Geriatric consultation teams in acute hospitals: impact on back-up of elderly patients. J Am Geriatr Soc. Jun 1985;33(6):422–428. | Intervention
13 Barrick C, Karuza J, Levitt J. Impacting quality: assessment of a hospital-based geriatric acute care unit. American Journal of Medical Quality. 1999;14(3):133–137. | Setting
14 Baztan JJ, Gil L, Andres E, Vega E, Ruiperez I. [The community activity of a hospital geriatrics service: a practical example of coordination between primary and specialized care]. Aten Primaria. Oct 15 2000;26(6):374–382. | Foreign language
15 Beck A, Scott J, Williams P, et al. A randomized trial of group outpatient visits for chronically ill older HMO members: the Cooperative Health Care Clinic. J Am Geriatr Soc. May 1997;45(5):543–549. | Intervention
16 Beland F, Bergman H, Lebel P, et al. A system of integrated care for older persons with disabilities in Canada: results from a randomized controlled trial. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Apr 2006;61(4):367–373. | Intervention
17 Beland F, Bergman H, Lebel P, et al. Integrated services for frail elders (SIPA): a trial of a model for Canada. Can J Aging. Spring 2006;25(1):25–42. | Intervention
18 Blain A, Dardalhon B, Jouaffre V, et al. [Multidisciplinary work of a mobile geriatric team]. Soins Gerontol. Mar–Apr 2007(64):42. | Foreign language
19 Blewett LA, Johnson K, McCarthy T, Lackner T, Brandt B. Improving geriatric transitional care through inter-professional care teams. Journal of Evaluation in Clinical Practice. Feb 2010;16(1):57–63. | Setting
20 Borok GM, Reuben DB, Zendle LJ, et al. Rationale and design of a multi-center randomized trial of comprehensive geriatric assessment consultation for hospitalized patients in an HMO. J Am Geriatr Soc. May 1994;42(5):536–544. | Other: Protocol only
21 Boult C, Reider L, Leff B, et al. The effect of guided care teams on the use of health services: results from a cluster-randomized controlled trial. Archives of internal medicine. 2011;171(5):460–466. | Intervention
22 Boyd CM, Shadmi E, Conwell LJ, et al. A pilot test of the effect of guided care on the quality of primary care experiences for multimorbid older adults. J Gen Intern Med. May 2008;23(5):536–542. | Intervention
23 Bula C, Waeber G. [General internal medicine and geriatrics in the acute care setting: opportunities for collaboration]. Rev Med Suisse. Nov 8 2006;2(86):2540–2543. | Foreign language
24 Burns R, Nichols LO, Graney MJ, Cloar FT. Impact of continued geriatric outpatient management on health outcomes of older veterans. Archives of internal medicine. Jun 1995;155(12):1313–1318. | Intervention
25 Buurman BM, Parlevliet JL, van Deelen BA, de Haan RJ, de Rooij SE. A randomised clinical trial on a comprehensive geriatric assessment and intensive home follow-up after hospital discharge: the Transitional Care Bridge. BMC Health Serv Res. 2010;10:296. | Other: Protocol, study not completed
26 Callahan CM, Weiner M, Counsell SR. Defining the domain of geriatric medicine in an urban public health system affiliated with an academic medical center. J Am Geriatr Soc. Oct 2008;56(10):1802–1806. | Other: Descriptive study
27 Campbell KH, Sachs GA, Hemmerich JA, Smith SG, Stankus N, Dale W. Physician referral decisions for older chronic kidney disease patients: a pilot study of geriatricians, internists, and nephrologists. J Am Geriatr Soc. Feb 2010;58(2):392–395. | Outcome
28 Campion EW, Jette A, Berkman B. An interdisciplinary geriatric consultation service: a controlled trial. J Am Geriatr Soc. Dec 1983;31(12):792–796. | Published before 1985
29 Campion EW. The merits of geriatric consultation. JAMA. May 1 1987;257(17):2336–2337. | Publication type
30 Carlsen WR, Galluzzi KE, Forman LF, Cavalieri TA. Comprehensive geriatric assessment: applications for community-residing, elderly people with mental retardation/developmental disabilities. Ment Retard. Oct 1994;32(5):334–340. | Setting
31 Cefalu CA, Colbourne G, Duffy M, Johnson E, Lestter M, Wright J. A university-affiliated community hospital inpatient geriatrics program functioning in an administrative and educational capacity. J Am Geriatr Soc. Mar 1997;45(3):355–360. | No comparator
32 Cefalu CA. Adhering to inpatient geriatric consultation recommendations. J Fam Pract. Mar 1996;42(3):259–263. | Intervention
33 Cefalu CA. Preoperative geriatric assessment. J Am Geriatr Soc. Mar 1996;44(3):333. | Publication type
34 Challis D, Clarkson P, Williamson J, et al. The value of specialist clinical assessment of older people prior to entry to care homes. Age and ageing. Jan 2004;33(1):25–34. | Intervention
35 Champion G, Henschke P, Harris R, et al. The Geriatric Assessment Research Project: a randomised study. [abstract]. Aust NZ J Med Suppl. 1987;17(1):111. | Publication type
36 Chesney TR, Alvarado BE, Garcia A. A mild dementia knowledge transfer program to improve knowledge and confidence in primary care. J Am Geriatr Soc. May 2011;59(5):942–944. | Outcome
37 Chin MH, Wang JC, Zhang JX, Sachs GA, Lang RM. Differences among geriatricians, general internists, and cardiologists in the care of patients with heart failure: a cautionary tale of quality assessment. J Am Geriatr Soc. Nov 1998;46(11):1349–1354. | Population
38 Cho CY, Alessi CA, Cho M, et al. The association between chronic illness and functional change among participants in a comprehensive geriatric assessment program. J Am Geriatr Soc. Jun 1998;46(6):677–682. | No comparator
39 Chun AK. When is it the right time to ask for a geriatrician? Mt Sinai J Med. Jul–Aug 2011;78(4):485–488. | Other: Non- SR
40 Clarkson P, Brand C, Hughes J, Challis D. Integrating assessments of older people: examining evidence and impact from a randomised controlled trial. Age Ageing. May 2011;40(3):388–391. | Intervention
41 Clarkson P, Venables D, Hughes J, Burns A, Challis D. Integrated specialist assessment of older people and predictors of care-home admission. Psychol Med. Jul 2006;36(7):1011–1021. | Intervention
42 Coast J, Peters TJ, Inglis A. Factors associated with inappropriate emergency hospital admission in the UK. Int J Qual Health Care. Feb 1996;8(1):31–39. | Intervention
43 Collard AF, Bachman SS, Beatrice DF. Acute care delivery for the geriatric patient: an innovative approach. QRB Qual Rev Bull. Jun 1985;11(6):180–185. | Intervention
44 Conroy S, Ferguson C, Woodard J, Banerjee J. Interface geriatrics: evidence-based care for frail older people with medical crises. Br J Hosp Med (Lond). Feb 2010;71(2):98–101. | Other: Non- SR
45 Corbett HM, Lim WK, Davis SJ, Elkins AM. Care coordination in the Emergency Department: improving outcomes for older patients. Aust Health Rev. Feb 2005;29(1):43–50. | Intervention
46 Cordato NJ, Saha S, Price MA. Geriatric interventions: the evidence base for comprehensive health care services for older people. Australian Health Review. May 2005;29(2):151–155. | Publication type
47 Couderc AL, Bailly-Agaledes C, Camalet J, et al. [Adaptations of psychotropic drugs in patients aged 75 years and older in a departement of geriatric internal medecine: report of 100 cases]. Geriatr Psychol Neuropsychiatr Vieil. Jun 2011;9(2):163–170. | Foreign language
48 Counsell SR, Callahan CM, Buttar AB, Clark DO, Frank KI. Geriatric Resources for Assessment and Care of Elders (GRACE): a new model of primary care for low-income seniors. J Am Geriatr Soc. 2006;54(7):1136–1141. | Outcome
49 Covinsky KE, King JT, Jr., Quinn LM, et al. Do acute care for elders units increase hospital costs? A cost analysis using the hospital perspective. Journal of the American Geriatrics Society. 1997;45(6):729–734. | Intervention
50 Cravens DD, Mehr DR, Campbell JD, Armer J, Kruse RL, Rubenstein LZ. Home-based comprehensive assessment of rural elderly persons: the CARE project. J Rural Health. 2005;21(4):322–328. | No comparator
51 Crotty M, Halbert J, Rowett D, et al. An outreach geriatric medication advisory service in residential aged care: a randomised controlled trial of case conferencing. Age & Ageing. Nov 2004;33(6):612–617. | Setting
52 Cunliffe AL, Gladman JR, Husbands SL, Miller P, Dewey ME, Harwood RH. Sooner and healthier: a randomised controlled trial and interview study of an early discharge rehabilitation service for older people. Age Ageing. May 2004;33(3):246–252. | Intervention
53 Dapp U, Anders JA, von Renteln-Kruse W, et al. A randomized trial of effects of health risk appraisal combined with group sessions or home visits on preventive behaviors in older adults. J Gerontol A Biol Sci Med Sci. May 2011;66(5):591–598. | Intervention
54 De Jonge E, Taler G. Is there a doctor in the house? Caring. Aug 2002;21(8):26–29. | Population
55 de Vries OJ, Peeters GM, Elders PJ, et al. Multifactorial intervention to reduce falls in older people at high risk of recurrent falls: a randomized controlled trial. Arch Intern Med. Jul 12 2010;170(13):1110–1117. | Population
56 Duncan G, Caird FI. Collaboration between geriatricians and general surgeons. Health Bull (Edinb). Mar 1992;50(2):163–167. | No comparator
57 Eagle DJ, Guyatt GH, Patterson C, Turpie I, Sackett B, Singer J. Effectiveness of a geriatric day hospital. CMAJ. Mar 15 1991;144(6):699–704. | Intervention
58 Edmans J, Conroy S, Harwood R, et al. Acute medical unit comprehensive geriatric assessment intervention study (AMIGOS). Trials. 2011;12:200. | Other: Protocol only
59 Elkan R, Kendrick D, Dewey M, et al. Effectiveness of home based support for older people: systematic review and meta-analysis. BMJ. 2001;323(7315):719–725. | Intervention
60 Elliot JR, Wilkinson TJ, Hanger HC, et al. The added effectiveness of early geriatrician involvement on acute orthopaedic wards to orthogeriatric rehabilitation. N Z Med J. Mar 8 1996;109(1017):72–73. | Population
61 Ellis G, Langhorne P. Comprehensive geriatric assessment for older hospital patients. Br Med Bull. 2004;71:45–59. | Other: Review has been updated
62 Enguidanos SM, Gibbs NE, Simmons WJ, et al. Kaiser Permanente community partners project: improving geriatric care management practices. J Am Geriatr Soc. May 2003;51(5):710–714. | Outcome
63 Evans DJ, Oakey S, Almdahl S, Davoren B. Goal attainment scaling in a geriatric day hospital. Team and program benefits. Can Fam Physician. Apr 1999;45:954–960. | Intervention
64 Fairhall N, Aggar C, Kurrle SE, et al. Frailty Intervention Trial (FIT). BMC Geriatrics. 2008;8:27. | Other: Protocol only
65 Fisher A, Davis M, Rubenach S, Sivakumaran S, Smith P, Budge M. Outcomes for Older Patients With Hip Fractures: The Impact of Orthopedic and Geriatric Medicine Cocare. Journal of Orthopaedic Trauma March. 2006;20(3):172–180. | Population
66 Fletcher AE, Jones DA, Bulpitt CJ, Tulloch AJ. The MRC trial of assessment and management of older people in the community: objectives, design and interventions [ISRCTN23494848]. BMC Health Serv Res. Oct 25 2002;2(1):21. | Other: Protocol only
67 Foley KT, Szabo E, Whitelaw N. Can geriatricians maintain separate consultative and primary care roles? J Am Geriatr Soc. Sep 1995;43(9):1065. | Publication type
68 Forster A, Young J, Lambley R, Langhorne P. Medical day hospital care for the elderly versus alternative forms of care [Systematic Review]. Cochrane Database of Systematic Reviews. 2009(1). | Population
69 Friedman G, Brodsky J, Bentur N, Ben-Yehuda A, Stern Z, Isaacs B. Evaluation of a geriatric consultation unit in an acute university hospital. Aging (Milano). Jun 1995;7(3):234–236. | Outcome
70 Ganz DA, Fung CH, Sinsky CA, Wu S, Reuben DB. Key elements of high-quality primary care for vulnerable elders. Journal of General Internal Medicine. Dec 2008;23(12):2018–2023. | Intervention
71 Gilchrist WJ, Newman RJ, Hamblen DL, Williams BO. Prospective randomised study of an orthopaedic geriatric inpatient service. BMJ. Oct 29 1988;297(6656):1116–1118. | Population
72 Gold S, Bergman H. A geriatric consultation team in the emergency department. J Am Geriatr Soc. Jun 1997;45(6):764–767. | No comparator
73 Gonzalez-Montalvo JI, Alarcon T, Mauleon JL, Gil-Garay E, Gotor P, Martin-Vega A. The orthogeriatric unit for acute patients: a new model of care that improves efficiency in the management of patients with hip fracture. Hip Int. Apr–Jun 2010;20(2):229–235. | Population
74 Hackstaff L, Davis C, Katz L. The case for integrating behavior change, client-centered practice and other evidence-based models into geriatric care management. Soc Work Health Care. 2004;38(3):1–19. | Intervention
75 Hastings SN, Heflin MT. A systematic review of interventions to improve outcomes for elders discharged from the emergency department. Acad Emerg Med. Oct 2005;12(10):978–986. | Intervention
76 Hebert R, Raiche M, Dubois M-F, et al. Impact of PRISMA, a coordination-type integrated service delivery system for frail older people in Quebec (Canada): A quasi-experimental study. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. Jan 2010;65B(1):107–118. | Intervention
77 Henschke P. The Geriatric Assessment Research Project: a randomised study [abstract]. Proc Annu Conf Aust Assoc Gerontol. 1986;21(77). | Publication type
78 Hershfield NB. Effect of a geriatric consultation service on the management of patients in an acute care hospital. CMAJ. Jul 1 1987;137(1):12–13. | Publication type
79 Hinkka K, Karppi SL, Pohjolainen T, Rantanen T, Puukka P, Tilvis R. Network-based geriatric rehabilitation for frail elderly people: feasibility and effects on subjective health and pain at one year. J Rehabil Med. Jul 2007;39(6):473–478. | Population
80 Huber M, Kennard A. Functional and mental status outcomes of clients discharged from acute gerontological versus medical/surgical units. J Gerontol Nurs. Jul 1991;17(7):20–24. | Intervention
81 Hui E, Lum CM, Woo J, Or KH, Kay RL. Outcomes of elderly stroke patients. Day hospital versus conventional medical management. Stroke. Sep 1995;26(9):1616–1619. | Population
82 Jayadevappa R, Chhatre S, Weiner M, Raziano DB. Health resource utilization and medical care cost of acute care elderly unit patients. Value in Health. 2006;9(3):186–192. | Intervention
83 Kafetz K, O’Farrell J, Parry A, et al. Age-related geriatric medicine: relevance of special skills of geriatric medicine to elderly people admitted to hospital as medical emergencies. J R Soc Med. Nov 1995;88(11):629–633. | Intervention
84 Kafetz K. How effective are acute geriatric wards at admitting geriatric patients? Clin Med. Aug 2010;10(4):420–421. | Intervention
85 Kagan SH. Revisiting interdisciplinary teamwork in geriatric acute care. Geriatr Nurs. Mar 4 2010;31(2):133–136. | Publication type
86 Karppi P. Effects of a geriatric inpatient unit on elderly home care patients: a controlled trial. Aging (Milan, Italy). Jun 1995;7(3):207–211. | Setting
87 Kay G, MacTavish M, Moffatt C, Lau G. Development and evaluation of a geriatric assessment unit in a community hospital. Perspectives. 1992;16(3):2–9. | Population
88 Keeler EB, Robalino DA, Frank JC, Hirsch SH, Maly RC, Reuben DB. Cost-effectiveness of outpatient geriatric assessment with an intervention to increase adherence. Med Care. Dec 1999;37(12):1199–1206. | Publication type
89 Kehusmaa S, Autti-Ramo I, Valaste M, Hinkka K, Rissanen P. Economic evaluation of a geriatric rehabilitation programme: a randomized controlled trial. J Rehabil Med. Nov 2010;42(10):949–955. | Outcome
90 Kelley-Gillespie N. Mobile medical care units: an innovative use of Medicare funding. J Health Soc Policy. 2005;20(2):33–48. | Intervention
91 Kimber J, Silver CP. Home visiting by a geriatric department. J R Coll Gen Pract. Jan 1981;31(222):41–44. | No comparator
92 Kravitz RL, Reuben DB, Davis JW, et al. Geriatric home assessment after hospital discharge. J Am Geriatr Soc. Dec 1994;42(12):1229–1234. | No comparator
93 Lampela P, Hartikainen S, Lavikainen P, Sulkava R, Huupponen R. Effects of medication assessment as part of a comprehensive geriatric assessment on drug use over a 1-year period: a population-based intervention study. Drugs Aging. Jun 1 2010;27(6):507–521. | Intervention
94 Landefeld CS, Palmer RM, Kresevic DM, Fortinsky RH, Kowal J. A randomized trial of care in a hospital medical unit especially designed to improve the functional outcomes of acutely ill older patients. N Engl J Med. May 18 1995;332(20):1338–1344. | Intervention
95 Landefeld CS. Care of hospitalized older patients: opportunities for hospital-based physicians. J Hosp Med. Jan 2006;1(1):42–47. | Intervention
96 Lang VJ, Clark NS, Medina-Walpole A, McCann R. Hazards of hospitalization: hospitalists and geriatricians educating medical students about delirium and falls in geriatric inpatients. Gerontol Geriatr Educ. 2008;28(4):94–104. | Intervention
97 Ledesert B, Lombrail P, Yeni P, Carbon C, Brodin M. The impact of a comprehensive multi- dimensional geriatric assessment programme on duration of stay in a French acute medical ward. Age & Ageing. 1994;23(3):223–227. | Intervention
98 Lichtenstein H, Winograd CH. Geriatric consultation: a functional approach. J Am Geriatr Soc. May 1984;32(5):356–361. | No comparator
99 Lundstrom M, Edlund A, Karlsson S, Brannstrom B, Bucht G, Gustafson Y. A multifactorial intervention program reduces the duration of delirium, length of hospitalization, and mortality in delirious patients. Journal of the American Geriatrics Society. Apr 2005;53(4):622–628. | Intervention
100 MacLean DS. Outcome and cost of family physicians’ care-\-pilot study of three diagnosis-related groups in elderly inpatients. J Am Board Fam Pract. Nov–Dec 1993;6(6):588–593. | Intervention
101 MacLennan WJ, Chapman BJ, Smith M, Prescott RJ, Wang JX. Co-ordinating geriatric and general medical services; experience of a geriatric assessment ward in the Royal Infirmary of Edinburgh. Scott Med J. Jun 1992;37(3):80–82. | No comparator
102 Maly RC, Leake B, Frank JC, DiMatteo MR, Reuben DB. Implementation of consultative geriatric recommendations: the role of patient-primary care physician concordance. J Am Geriatr Soc. Aug 2002;50(8):1372–1380. | No comparator
103 Marcantonio ER, Flacker JM, Wright RJ, Resnick NM. Reducing delirium after hip fracture: a randomized trial. J Am Geriatr Soc. May 2001;49(5):516–522. | Population
104 Martin F, Oyewole A, Moloney A. A randomized controlled trial of a high support hospital discharge team for elderly people. Age Ageing. May 1994;23(3):228–234. | Intervention
105 Martinez Lozano MD, Guzman Quilo C, Primeras Consultas Study G. Management of suspected Alzheimer’s disease patients by specialist physicians at the first visit in Spain: First Consultation Study. Expert Rev Neurother. May 2011;11(5):657–663. | Population
106 Masters S, Halbert J, Crotty M, Cheney F. What are the first quality reports from the Transition Care Program in Australia telling us? Australas J Ageing. 2008;27(2):97–102. | No comparator
107 McCusker J, Dendukuri N, Tousignant P, Verdon J, Poulin de Courval L, Belzile E. Rapid two- stage emergency department intervention for seniors: impact on continuity of care. Acad Emerg Med. Mar 2003;10(3):233–243. | Intervention
108 McCusker J, Verdon J. Do geriatric interventions reduce emergency department visits: a systematic review. Journals of Gerontology Series A - Biological Sciences and Medical Sciences. 2006;61(1):53–62. | Intervention
109 McInnes E, Mira M, Atkin N, Kennedy P, Cullen J. Can GP input into discharge planning result in better outcomes for the frail aged: results from a randomized controlled trial. Fam Pract. Jun 1999;16(3):289–293. | Intervention
110 Mehta SS, Siegler EL, Henderson CR, Jr., Reid MC. Acute pain management in hospitalized patients with cognitive impairment: a study of provider practices and treatment outcomes. Pain Med. Oct 2010;11(10):1516–1524. | No comparator
111 Meissner P, Andolsek K, Mears PA, Fletcher B. Maximizing the functional status of geriatric patients in an acute community hospital setting. Gerontologist. 1989;29(4):524–528. | Intervention
112 Melis RJ, Adang E, Teerenstra S, et al. Cost-effectiveness of a multidisciplinary intervention model for community-dwelling frail older people. J Gerontol A Biol Sci Med Sci. Mar 2008;63(3):275–282. | Setting
113 Melis RJ, van Eijken MI, Teerenstra S, et al. A randomized study of a multidisciplinary program to intervene on geriatric syndromes in vulnerable older people who live at home (Dutch EASYcare Study). J Gerontol A Biol Sci Med Sci. Mar 2008;63(3):283–290. | Intervention
114 Merel SE, McCormick W. Geriatricians and hospitalists: opportunities for partnership. J Am Geriatr Soc. Sep 2010;58(9):1803–1805. | Publication type
115 Mesteig M, Helbostad JL, Sletvold O, Rosstad T, Saltvedt I. Unwanted incidents during transition of geriatric patients from hospital to home: a prospective observational study. BMC Health Serv Res. 2010;10:1. | No comparator
116 Mion LC, Palmer RM, Meldon SW, et al. Case finding and referral model for emergency department elders: a randomized clinical trial. Ann Emerg Med. Jan 2003;41(1):57–68. | Intervention
117 Mulder J, Groenier KH, Dekker JJ, Berendsen AJ, Schuling J. Is there a need for a GP consultant at a university hospital? BMC Fam Pract. 2008;9:55. | Outcome
118 National Institutes of Health Consensus Development Conference Statement: geriatric assessment methods for clinical decision-making. Journal of the American Geriatrics Society. Apr 1988;36(4):342–347. | Publication type
119 Naylor MD, Brooten D, Campbell R, et al. Comprehensive discharge planning and home follow- up of hospitalized elders: a randomized clinical trial. JAMA. 1999;281(7):613–620. | Intervention
120 Nikolaus T, Detterbeck H, Gartner U, et al. [Diagnostic house call within the scope of inpatient geriatric assessment]. Z Gerontol Geriatr. Jan–Feb 1995;28(1):14–18. | Foreign language
121 Nikolaus T, Specht-Leible N, Bach M, Oster P, Schlierf G. A randomized trial of comprehensive geriatric assessment and home intervention in the care of hospitalized patients. Age Ageing. Oct 1999;28(6):543–550. | Intervention
122 Nikolaus T, Specht-Leible N, Bach M, Wittmann-Jennewein C, Oster P, Schlierf G. Effectiveness of hospital-based geriatric evaluation and management and home intervention team (GEM-HIT). Rationale and design of a 5-year randomized trial. Z Gerontol Geriatr. Jan–Feb 1995;28(1):47–53. | Other: Protocol only
123 O’Donnell JC, Toseland RW. Does geriatric evaluation and management improve the health behavior of older veterans in psychological distress? J Aging Health. Nov 1997;9(4):473–497. | Other: Primary reports are covered by SRs
124 O’Reilly J, Lowson K, Young J, Forster A, Green J, Small N. A cost effectiveness analysis within a randomised controlled trial of post-acute care of older people in a community hospital. BMJ. Jul 29 2006;333(7561):228. | Intervention
125 Parker SG, Oliver P, Pennington M, et al. Rehabilitation of older patients: day hospital compared with rehabilitation at home. Clinical outcomes. Age Ageing. Sep 2011;40(5):557–562. | Intervention
126 Parsons M, Senior H, Kerse N, et al. Should care managers for older adults be located in primary care? A randomized controlled trial. J Am Geriatr Soc. Jan 2012;60(1):86–92. | Intervention
127 Peeters GMEE, de Vries OJ, Elders PJM, Pluijm SMF, Bouter LM, Lips P. Prevention of fall incidents in patients with a high risk of falling: design of a randomised controlled trial with an economic evaluation of the effect of multidisciplinary transmural care. BMC Geriatrics. 2007;7:15. | Other: Protocol only
128 Phelan EA, Williams B, LaCroix AZ, Grothaus L, LoGerfo JP, Wagner EH. Effects of provider practice on functional independence in older adults. Journal of the American Geriatrics Society. Aug 2004;52(8):1233–1239. | Intervention
129 Pitkala KH, Laurila JV, Strandberg TE, Kautiainen H, Sintonen H, Tilvis RS. Multicomponent geriatric intervention for elderly inpatients with delirium: effects on costs and health-related quality of life. J Gerontol A Biol Sci Med Sci. Jan 2008;63(1):56–61. | Population
130 Pope G, Wall N, Peters CM, et al. Specialist medication review does not benefit short-term outcomes and net costs in continuing-care patients. Age Ageing. May 2011;40(3):307–312. | Setting
131 Popplewell PY, Henschke PJ. What is the value of a Geriatric Assessment Unit in a teaching hospital? A comparative study of the management of elderly inpatients. Aust Health Rev. May 1983;6(2):23–25. | Published before 1985
132 Powell C, Montgomery P. The age study: the admission of geriatric patients through emergency. Age & Ageing. 1990;19(Suppl):21–22. | Publication type
133 Raj V, Parulekar M, Steel RK. Geriatric medicine in the intensive care unit. J Am Geriatr Soc. Aug 2011;59(8):1570–1571. | Publication type
134 Reuben DB, Maly RC, Hirsch SH, et al. Physician implementation of and patient adherence to recommendations from comprehensive geriatric assessment. Am J Med. Apr 1996;100(4):444–451. | Outcome
135 Reuben DB. Organizational interventions to improve health outcomes of older persons. Med Care. May 2002;40(5):416–428. | Other: Mixed interventions
136 Rikala M, Korhonen MJ, Sulkava R, Hartikainen S. The effects of medication assessment on psychotropic drug use in the community-dwelling elderly. Int Psychogeriatr. Apr 2011;23(3):473–484. | Intervention
137 Riley CG. A geriatric assessment unit: the first twelve months. N Z Med J. Nov 27 1974;80(528):435–442. | Published before 1985
138 Rizza P, Bianco A, Pavia M, Angelillo IF. Preventable hospitalization and access to primary health care in an area of Southern Italy. BMC Health Serv Res. 2007;7:134. | Intervention
139 Rockwood K, Howlett S, Stadnyk K, Carver D, Powell C, Stolee P. Responsiveness of goal attainment scaling in a randomized controlled trial of comprehensive geriatric assessment. J Clin Epidemiol. Aug 2003;56(8):736–743. | Other: Psychometric study of scale
140 Roller PD, Allman RM. Comprehensive geriatric assessment in Medicare managed care: the geriatrician’s calling card. Am J Med. Apr 1996;100(4):383–385. | Publication type
141 Romeis JC, Schey HM, Marion GS, Keith JF, Jr. Extending the extenders. Compromise for the geriatric specialization-manpower debate. J Am Geriatr Soc. Aug 1985;33(8):559–565. | Intervention
142 Rozzini R, Sabatini T, Trabucchi M. Hospital organization: general internal medical and geriatrics wards. J Gerontol A Biol Sci Med Sci. Apr 2005;60(4):535. | No comparator
143 Rubenstein LZ. Documenting impacts of geriatric consultation. J Am Geriatr Soc. Aug 1987;35(8):829–830. | Publication type
144 Rubin CD, Sizemore MT, Loftis PA, Adams-Huet B, Anderson RJ. The effect of geriatric evaluation and management on Medicare reimbursement in a large public hospital: a randomized clinical trial. Journal of the American Geriatrics Society. Oct 1992;40(10):989–995. | Intervention
145 Saad M, Harisingani R, Katinas L. Impact of geriatric consultation on the number of medications in hospitalized older patients. Consult Pharm. Jan 2012;27(1):42–48. | No comparator
146 Sahadevan S, Earnest A, Koh YL, Lee KM, Soh CH, Ding YY. Improving the diagnosis related grouping model’s ability to explain length of stay of elderly medical inpatients by incorporating function-linked variables. Ann Acad Med Singapore. Sep 2004;33(5):614–622. | No comparator
147 Scott I. Optimising care of the hospitalised elderly: a literature review and suggestions for future research. Australian and New Zealand Journal of Medicine. 1999;29(2):254–264. | Publication type
148 Scott IA. Care of older people in acute care hospitals: do we know how? Med J Aust. Nov 1 1999;171(9):485–488. | Publication type
149 Shaw FE, Bond J, Richardson DA, et al. Multifactorial intervention after a fall in older people with cognitive impairment and dementia presenting to the accident and emergency department: randomised controlled trial. BMJ. Jan 11 2003;326(7380):73. | Intervention
150 Shyu YI, Liang J, Wu CC, et al. Two-year effects of interdisciplinary intervention for hip fracture in older Taiwanese. J Am Geriatr Soc. Jun 2010;58(6):1081–1089. | Intervention
151 Silliman RA, McGarvey ST, Raymond PM, Fretwell MD. The Senior Care Study. Does inpatient interdisciplinary geriatric assessment help the family caregivers of acutely ill older patients? J Am Geriatr Soc. Apr 1990;38(4):461–466. | Outcome
152 Siu AL, Morishita L, Blaustein J. Comprehensive geriatric assessment in a day hospital. Journal of the American Geriatrics Society. Oct 1994;42(10):1094–1099. | No comparator
153 Somme D, Andrieux N, Guerot E, et al. Loss of autonomy among elderly patients after a stay in a medical intensive care unit (ICU): a randomized study of the benefit of transfer to a geriatric ward. Arch Gerontol Geriatr. May–Jun 2010;50(3):e36–40. | Intervention
154 Sonu IS, High KP, Clayton CP, Woolard NF, Hazzard WR. An evaluation of geriatrics activities within internal medicine subspecialties. Am J Med. Nov 2006;119(11):995–1000. | Intervention
155 Spinewine A, Swine C, Dhillon S, et al. Effect of a collaborative approach on the quality of prescribing for geriatric inpatients: a randomized, controlled trial. Journal of the American Geriatrics Society. May 2007;55(5):658–665. | Intervention
156 Steel K, Hays A. A consultation service in geriatric medicine at a university hospital. JAMA. Apr 10 1981;245(14):1410–1411. | Publication type
157 Stenvall M, Olofsson B, Nyberg L, Lundstrom M, Gustafson Y. Improved performance in activities of daily living and mobility after a multidisciplinary postoperative rehabilitation in older people with femoral neck fracture: a randomized controlled trial with 1-year follow-up. J Rehabil Med. Apr 2007;39(3):232–238. | Population
158 Stewart DA, Burns JM, Beard K, et al. The roles of general and geriatric medicine in the provision of acute medical care for elderly patients. Health Bull (Edinb). May 1992;50(3):259–266. | No comparator
159 Stock RD, Reece D, Cesario L. Developing a comprehensive interdisciplinary senior healthcare practice. Journal of the American Geriatrics Society. Dec 2004;52(12):2128–2133. | No comparator
160 Stuck AE, Egger M, Hammer A, Minder CE, Beck JC. Home visits to prevent nursing home admission and functional decline in elderly people: systematic review and meta-regression analysis. JAMA. 2002;287(8):1022–1028. | Other: Review has been updated
161 Stuck AE, Kharicha K, Dapp U, et al. The PRO-AGE study: an international randomised controlled study of health risk appraisal for older persons based in general practice. BMC Med Res Methodol. 2007;7:2. | Intervention
162 Stuck AE, Siu AL, Wieland GD, Adams J, Rubenstein LZ. Comprehensive geriatric assessment: a meta-analysis of controlled trials. Lancet. Oct 23 1993;342(8878):1032–1036. | Other: Review has been updated
163 Stuck AE, Zwahlen HG, Neuenschwander BE, Meyer Schweizer RA, Bauen G, Beck JC. Methodologic challenges of randomized controlled studies on in-home comprehensive geriatric assessment: the EIGER project. Evaluation of In-Home Geriatric Health Visits in Elderly Residents. Aging (Milano). Jun 1995;7(3):218–223. | Other: Method article
164 Templeton VH. Dementia care: an outpatient, community-based, multi-disciplinary approach. N C Med J. Jan–Feb 2005;66(1):64–66. | Publication type
165 Thomas DR, Brahan R, Haywood BP. Inpatient community-based geriatric assessment reduces subsequent mortality. J Am Geriatr Soc. Feb 1993;41(2):101–104. | Intervention
166 Todd M, Crawford V, Stout RW. Differences between “geriatric” and “medical” patients aged 75 and over. Ulster Med J. Apr 1993;62(1):4–10. | No comparator
167 Torres C, Ciocon JO, Galindo D, Ciocon DG. Clinical approach to urinary incontinence: a comparison between internists and geriatricians. Int Urol Nephrol. 2001;33(3):549–552. | Outcome
168 Trentini M, Semeraro S, Rossi E, et al. A multicenter randomized trial of comprehensive geriatric assessment and management: experimental design, baseline data, and six-month preliminary results. Aging (Milano). Jun 1995;7(3):224–233. | Other: Review has been updated
169 Tucker MA, Davison JG, Ogle SJ. Day hospital rehabilitation-\-effectiveness and cost in the elderly: a randomised controlled trial. Br Med J (Clin Res Ed). Nov 3 1984;289(6453):1209–1212. | Intervention
170 Twomey C, Crowley MJ, Delaney L, Hyland CM. Patient throughput in an acute geriatric unit. Ir Med J. Jul–Aug 1995;88(4):126–128. | No comparator
171 Van Craen K, Braes T, Wellens N, et al. The effectiveness of inpatient geriatric evaluation and management units: a systematic review and meta-analysis. Journal of the American Geriatrics Society. Jan 2010;58(1):83–92. | Intervention
172 Vidan Astiz MT, Sanchez Garcia E, Alonso Armesto M, et al. [Functional decline during hospitalization in elderly patients. Benefits of admission to the geriatrics service]. Rev Esp Geriatr Gerontol. May–Jun 2008;43(3):133–138. | Foreign language
173 Vidan M, Serra JA, Moreno C, Riquelme G, Ortiz J. Efficacy of a comprehensive geriatric intervention in older patients hospitalized for hip fracture: a randomized, controlled trial. J Am Geriatr Soc. Sep 2005;53(9):1476–1482. | Population
174 Vind AB, Andersen HE, Pedersen KD, Joergensen T, Schwarz P. Effect of a program of multifactorial fall prevention on health-related quality of life, functional ability, fear of falling and psychological well-being. A randomized controlled trial. Aging Clin Exp Res. Jun 2010;22(3):249–254. | Intervention
175 von Sternberg T, Hepburn K, Cibuzar P, et al. Post-hospital sub-acute care: an example of a managed care model. J Am Geriatr Soc. Jan 1997;45(1):87–91. | Setting
176 Wald H, Huddleston J, Kramer A. Is there a geriatrician in the house? Geriatric care approaches in hospitalist programs. J Hosp Med. Jan 2006;1(1):29–35. | Intervention
177 Wald HL, Glasheen JJ, Guerrasio J, Youngwerth JM, Cumbler EU. Evaluation of a hospitalist- run acute care for the elderly service. J Hosp Med. Jul–Aug 2011;6(6):313–321. | Intervention
178 Warshaw G. Geriatrics in the family practice center. Fam Med. Jan 1998;30(1):10–11. | Publication type
179 Warshaw G. Providing quality primary care to older adults. J Am Board Fam Med. May–Jun 2009;22(3):239–241. | Intervention
180 Warshaw GA, Modawal A, Kues J, et al. Community physician education in geriatrics: applying the assessing care of vulnerable elders model with a multisite primary care group. J Am Geriatr Soc. Sep 2010;58(9):1780–1785. | Intervention
181 Wasserman MR, Holthaus KM, Cosgrove K. The MedWise Center-\-an innovation in primary care geriatrics. Continuum. Jan–Feb 1998;18(1):18–23. | No comparator
182 Wenger NS, Roth CP, Shekelle PG, et al. A practice-based intervention to improve primary care for falls, urinary incontinence, and dementia. Journal of the American Geriatrics Society. Mar 2009;57(3):547–555. | Intervention
183 Whinney C, Michota F. Surgical comanagement: a natural evolution of hospitalist practice. J Hosp Med. Sep 2008;3(5):394–397. | Intervention
184 Whitehead CH, Harding S, Giles LC, Crotty M. Establishment of and first 20 months of operating an outreach geriatric clinic in a regional centre. Rural Remote Health. 2006;6(1):444. | No comparator
185 Wilhelmson K, Duner A, Eklund K, et al. Design of a randomized controlled study of a multi- professional and multidimensional intervention targeting frail elderly people. BMC Geriatr. 2011;11:24. | Intervention
186 Willett RM, Boling PA, Meyers ME, Hoban JD, Lawson SR, Schlesinger JB. Professional development in geriatrics for community-based generalist faculty. J Am Geriatr Soc. Feb 2007;55(2):300–304. | Intervention
187 Williams ME, Pulliam CC, Hunter R, et al. The short-term effect of interdisciplinary medication review on function and cost in ambulatory elderly people. J Am Geriatr Soc. Jan 2004;52(1):93–98. | Intervention
188 Winograd CH, Gerety MB, Brown E, Kolodny V. Targeting the hospitalized elderly for geriatric consultation. J Am Geriatr Soc. Dec 1988;36(12):1113–1119. | Outcome
189 Winograd CH, Stearns C. Inpatient geriatric consultation. Challenges and benefits. J Am Geriatr Soc. Aug 1990;38(8):926–932. | Publication type
190 Wong R, Chittock D, Malean N, Wilbur K. Discharge outcomes of older medical in-patients in a specialized acute care for elders unit compared with non-specialized units. Can J Geriatr. 2006;9(3):96–101. | Intervention
191 Xakellis GC. Who provides care to Medicare beneficiaries and what settings do they use? J Am Board Fam Pract. Sep–Oct 2004;17(5):384–387. | Outcome

## REFERENCES

1 United States Department of Veterans Affairs. (2012). Department of Veterans Affairs Statistics at a Glance: Pocket Card. National Center for Veterans Analysis and Statistics: Quick Facts.
2 Kinosian B, Stallard E, Wieland D. (2007). Projected use of long-term-care services by enrolled Veterans. Gerontologist.
3 Shea BJ, Grimshaw JM, Wells GA, et al. (2007). Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Medical Research Methodology.
4 Downs S, Black N. (1998). The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. Journal of Epidemiology & Community Health.
5 Harris R, Helfand M, Woolf S, et al. (2001). Current methods of the US Preventive Services Task Force: a review of the process. American Journal of Preventive Medicine.
6 Ellis G, Whitehead MA, O’Neill D, Langhorne P, Robinson D. (2011). Comprehensive geriatric assessment for older adults admitted to hospital [Systematic Review]. Cochrane Database of Systematic Reviews.
7 Conroy S, Stevens T, Parker S, Gladman J. (2011). A systematic review of comprehensive geriatric assessment to improve outcomes for frail older people being rapidly discharged from acute hospital: ‘interface geriatrics’. Age and Ageing.
8 Baztan JJ, Suarez-Garcia FM, Lopez-Arrieta J, Rodriguez-Manas L, Rodriguez-Artalejo F. (2009). Effectiveness of acute geriatric units on functional decline, living at home, and case fatality among older patients admitted to hospital for acute medical disorders: meta-analysis. BMJ.
9 Day P, Rasmussen P. (2004). What is the evidence for the effectiveness of specialist geriatric services in acute, post-acute and sub-acute settings? A critical appraisal of the literature.
10 Bachmann S, Finger C, Huss A, Egger M, Stuck AE, Clough-Gorr KM. (2010). Inpatient rehabilitation specifically designed for geriatric patients: systematic review and meta-analysis of randomised controlled trials. BMJ.
11 Legrain S, Tubach F, Bonnet-Zamponi D, et al. (2011). A new multimodal geriatric discharge-planning intervention to prevent emergency visits and rehospitalizations of older adults: the optimization of medication in AGEd multicenter randomized controlled trial. J Am Geriatr Soc.
12 Slaets JP, Kauffmann RH, Duivenvoorden HJ, Pelemans W, Schudel WJ. (1997). A randomized trial of geriatric liaison intervention in elderly medical inpatients. Psychosom Med.
13 Germain M, Knoeffel F, Wieland D, Rubenstein LZ. (1995). A geriatric assessment and intervention team for hospital inpatients awaiting transfer to a geriatric unit: a randomized trial. Aging (Milano).
14 Hogan DB, Fox RA. (1990). A prospective controlled trial of a geriatric consultation team in an acute-care hospital. Age & Ageing.
15 Inouye SK, Wagner DR, Acampora D, Horwitz RI, Cooney LM, Tinetii ME. (1993). A controlled trial of a nursing-centered intervention in hospitalized elderly medical patients: the Yale Geriatric Care Program. Journal of the American Geriatrics Society.
16 Egger SS, Bachmann A, Hubmann N, Schlienger RG, Krahenbuhl S. (2006). Prevalence of potentially inappropriate medication use in elderly patients: comparison between general medical and geriatric wards. Drugs Aging.
17 Fallon WF, Rader E, Zyzanski S, et al. (2006). Geriatric outcomes are improved by a geriatric trauma consultation service. J Trauma.
18 Gayton D, Wood-Dauphinee S, de Lorimer M, Tousignant P, Hanley J. (1987). Trial of a geriatric consultation team in an acute care hospital. J Am Geriatr Soc.
19 McLean KA, Austin CA, Neal KR, Channer KS. (1994). Integration between general and geriatric medicine: a needs related policy. J R Coll Physicians Lond.
20 Pawlson LG. (1988). Hospital length of stay of frail elderly patients. Primary care by general internists versus geriatricians. J Am Geriatr Soc.
21 Sennour Y, Counsell SR, Jones J, Weiner M. (2009). Development and implementation of a proactive geriatrics consultation model in collaboration with hospitalists. J Am Geriatr Soc.
22 Stuck AE, Siu AL, Wieland GD, Adams J, Rubenstein LZ. (1993). Comprehensive geriatric assessment: a meta-analysis of controlled trials. Lancet.
23 Ellis G, Langhorne P. (2004). Comprehensive geriatric assessment for older hospital patients. Br Med Bull.
24 Eklund K, Wilhelmson K. (2009). Outcomes of coordinated and integrated interventions targeting frail elderly people: a systematic review of randomised controlled trials. Health & Social Care in the Community.
25 Beswick AD, Rees K, Dieppe P, et al. (2008). Complex interventions to improve physical function and maintain independent living in elderly people: a systematic review and meta-analysis. Lancet.
26 Kuo H-K, Scandrett KG, Dave J, Mitchell SL. (2004). The influence of outpatient comprehensive geriatric assessment on survival: a meta-analysis. Archives of Gerontology & Geriatrics.
27 Byles JE. (2000). A thorough going over: evidence for health assessments for older persons (Structured abstract). Australian and New Zealand Journal of Public Health.
28 Huss A, Stuck AE, Rubenstein LZ, Egger M, Clough-Gorr KM. (2008). Multidimensional preventive home visit programs for community-dwelling older adults: a systematic review and meta-analysis of randomized controlled trials. Journals of Gerontology Series A-Biological Sciences & Medical Sciences.
29 Counsell SR, Callahan CM, Clark DO, et al. (2007). Geriatric care management for low-income seniors: a randomized controlled trial. JAMA.
30 Phelan EA, Balderson B, Levine M, et al. (2007). Delivering effective primary care to older adults: a randomized, controlled trial of the senior resource team at group health cooperative. J Am Geriatr Soc.
31 Eloniemi-Sulkava U, Saarenheimo M, Laakkonen M-L, et al. (2009). Family care as collaboration: effectiveness of a multicomponent support program for elderly couples with dementia. Randomized controlled intervention study. Journal of the American Geriatrics Society.
32 Rubenstein LZ, Alessi CA, Josephson KR, Trinidad Hoyl M, Harker JO, Pietruszka FM. (2007). A randomized trial of a screening, case finding, and referral system for older veterans in primary care. J Am Geriatr Soc.
33 Schmader KE, Hanlon JT, Pieper CF, et al. (2004). Effects of geriatric evaluation and management on adverse drug reactions and suboptimal prescribing in the frail elderly. Am J Med.
34 Fenton JJ, Levine MD, Mahoney LD, Heagerty PJ, Wagner EH. (2006). Bringing geriatricians to the front lines: evaluation of a quality improvement intervention in primary care. J Am Board Fam Med.
35 Monteserin R, Brotons C, Moral I, et al. (2010). Effectiveness of a geriatric intervention in primary care: a randomized clinical trial. Fam Pract.
36 Li CM, Chen CY, Li CY, Wang WD, Wu SC. (2010). The effectiveness of a comprehensive geriatric assessment intervention program for frailty in community-dwelling older people: a randomized, controlled trial. Arch Gerontol Geriatr.
37 Bula CJ, Berod AC, Stuck AE, et al. (1999). Effectiveness of preventive in-home geriatric assessment in well functioning, community-dwelling older people: secondary analysis of a randomized trial. J Am Geriatr Soc.
38 Avila-Beltran R, Garcia-Mayo E, Gutierrez-Robledo LM, Avila-Funes JA. (2008). Geriatric medical consultation is associated with less prescription of potentially inappropriate medications. J Am Geriatr Soc.
39 Phelan EA, Genshaft S, Williams B, LoGerfo JP, Wagner EH. (2008). A comparison of how generalists and fellowship-trained geriatricians provide “geriatric” care. J Am Geriatr Soc.
40 Famadas JC, Frick KD, Haydar ZR, Nicewander D, Ballard D, Boult C. (2008). The effects of interdisciplinary outpatient geriatrics on the use, costs and quality of health services in the fee-for-service environment. Aging Clin Exp Res.
41 Kerski D, Drinka T, Carnes M, Golob K, Craig WA. (1987). Post-geriatric evaluation unit follow-up: team versus nonteam. J Gerontol.
42 Counsell SR, Callahan CM, Tu W, Stump TE, Arling GW. (2009). Cost analysis of the Geriatric Resources for Assessment and Care of Elders care management intervention. J Am Geriatr Soc.
43 Hermush V, Daliot D, Weiss A, Brill S, Beloosesky Y. (2009). The impact of geriatric consultation on the care of the elders in community clinics. Arch Gerontol Geriatr.
44 Peleg R, Press Y, Asher M, et al. (2008). An intervention program to reduce the number of hospitalizations of elderly patients in a primary care clinic. BMC Health Serv Res.
45 Phillips SL, Phillips JV, Branaman-Phillips J, Miller DJ. (2005). Geriatric versus non-geriatric approach of care to moderate Pra risk senior population. J Am Med Dir Assoc.

### SUPPLEMENTAL MATERIALS REFERENCES

1 Bachmann S, Finger C, Huss A, Egger M, Stuck AE, Clough-Gorr KM. (2010). Inpatient rehabilitation specifically designed for geriatric patients: systematic review and meta-analysis of randomised controlled trials. BMJ.
2 Baztan JJ, Suarez-Garcia FM, Lopez-Arrieta J, Rodriguez-Manas L, Rodriguez-Artalejo F. (2009). Effectiveness of acute geriatric units on functional decline, living at home, and case fatality among older patients admitted to hospital for acute medical disorders: meta-analysis. BMJ.
3 Conroy S, Stevens T, Parker S, Gladman J. (2011). A systematic review of comprehensive geriatric assessment to improve outcomes for frail older people being rapidly discharged from acute hospital: ‘interface geriatrics’. Age and Ageing.
4 Day P, Rasmussen P. (2004). What is the evidence for the effectiveness of specialist geriatric services in acute, post-acute and sub-acute settings? A critical appraisal of the literature.
5 Ellis G, Whitehead MA, O’Neill D, Langhorne P, Robinson D. (2011). Comprehensive geriatric assessment for older adults admitted to hospital. Cochrane Database of Systematic Reviews.
6 Beswick AD, Rees K, Dieppe P, et al. (2008). Complex interventions to improve physical function and maintain independent living in elderly people: a systematic review and meta-analysis. Lancet.
7 Byles JE. (2000). A thorough going over: evidence for health assessments for older persons (Structured abstract). Australian and New Zealand Journal of Public Health.
8 Eklund K, Wilhelmson K. (2009). Outcomes of coordinated and integrated interventions targeting frail elderly people: a systematic review of randomised controlled trials. Health & Social Care in the Community.
9 Huss A, Stuck AE, Rubenstein LZ, Egger M, Clough-Gorr KM. (2008). Multidimensional preventive home visit programs for community-dwelling older adults: a systematic review and meta-analysis of randomized controlled trials. Journals of Gerontology Series A-Biological Sciences & Medical Sciences\.
10 Kuo H-K, Scandrett KG, Dave J, Mitchell SL. (2004). The influence of outpatient comprehensive geriatric assessment on survival: a meta-analysis. Archives of Gerontology & Geriatrics.
11 Bula CJ, Berod AC, Stuck AE, et al. (1999). Effectiveness of preventive in-home geriatric assessment in well functioning, community-dwelling older people: secondary analysis of a randomized trial. J Am Geriatr Soc.
12 Counsell SR, Callahan CM, Tu W, Stump TE, Arling GW. (2009). Cost analysis of the Geriatric Resources for Assessment and Care of Elders care management intervention. J Am Geriatr Soc.
13 Counsell SR, Callahan CM, Clark DO, et al. (2007). Geriatric care management for low-income seniors: a randomized controlled trial. JAMA.
14 Eloniemi-Sulkava U, Saarenheimo M, Laakkonen M-L, et al. (2009). Family care as collaboration: effectiveness of a multicomponent support program for elderly couples with dementia. Randomized controlled intervention study. Journal of the American Geriatrics Society.
15 Fallon WF, Rader E, Zyzanski S, et al. (2006). Geriatric outcomes are improved by a geriatric trauma consultation service. J Trauma.
16 Gayton D, Wood-Dauphinee S, de Lorimer M, Tousignant P, Hanley J. (1987). Trial of a geriatric consultation team in an acute care hospital. J Am Geriatr Soc.
17 Germain M, Knoeffel F, Wieland D, Rubenstein LZ. (1995). A geriatric assessment and intervention team for hospital inpatients awaiting transfer to a geriatric unit: a randomized trial. Aging (Milano).
18 Hogan DB, Fox RA. (1990). A prospective controlled trial of a geriatric consultation team in an acute-care hospital. Age & Ageing.
19 Kerski D, Drinka T, Carnes M, Golob K, Craig WA. (1987). Post-geriatric evaluation unit follow-up: team versus nonteam. J Gerontol.
20 Legrain S, Tubach F, Bonnet-Zamponi D, et al. (2011). A new multimodal geriatric discharge-planning intervention to prevent emergency visits and rehospitalizations of older adults: the optimization of medication in AGEd multicenter randomized controlled trial. J Am Geriatr Soc.
21 Li CM, Chen CY, Li CY, Wang WD, Wu SC. (2010). The effectiveness of a comprehensive geriatric assessment intervention program for frailty in community-dwelling older people: a randomized, controlled trial. Arch Gerontol Geriatr.
22 McLean KA, Austin CA, Neal KR, Channer KS. (1994). Integration between general and geriatric medicine: a needs related policy. J R Coll Physicians Lond.
23 Monteserin R, Brotons C, Moral I, et al. (2010). Effectiveness of a geriatric intervention in primary care: a randomized clinical trial. Fam Pract.
24 Phelan EA, Balderson B, Levine M, et al. (2007). Delivering effective primary care to older adults: a randomized, controlled trial of the senior resource team at group health cooperative. J Am Geriatr Soc.
25 Phelan EA, Genshaft S, Williams B, LoGerfo JP, Wagner EH. (2008). A comparison of how generalists and fellowship-trained geriatricians provide “geriatric” care. J Am Geriatr Soc.
26 Rubenstein LZ, Alessi CA, Josephson KR, Trinidad Hoyl M, Harker JO, Pietruszka FM. (2007). A randomized trial of a screening, case finding, and referral system for older veterans in primary care. J Am Geriatr Soc.
27 Schmader KE, Hanlon JT, Pieper CF, et al. (2004). Effects of geriatric evaluation and management on adverse drug reactions and suboptimal prescribing in the frail elderly. Am J Med.
28 Slaets JP, Kauffmann RH, Duivenvoorden HJ, Pelemans W, Schudel WJ. (1997). A randomized trial of geriatric liaison intervention in elderly medical inpatients. Psychosom Med.
29 Avila-Beltran R, Garcia-Mayo E, Gutierrez-Robledo LM, Avila-Funes JA. (2008). Geriatric medical consultation is associated with less prescription of potentially inappropriate medications. J Am Geriatr Soc.
30 Egger SS, Bachmann A, Hubmann N, Schlienger RG, Krahenbuhl S. (2006). Prevalence of potentially inappropriate medication use in elderly patients: comparison between general medical and geriatric wards. Drugs Aging.
31 Famadas JC, Frick KD, Haydar ZR, Nicewander D, Ballard D, Boult C. (2008). The effects of interdisciplinary outpatient geriatrics on the use, costs and quality of health services in the fee-for-service environment. Aging Clin Exp Res.
32 Fenton JJ, Levine MD, Mahoney LD, Heagerty PJ, Wagner EH. (2006). Bringing geriatricians to the front lines: evaluation of a quality improvement intervention in primary care. J Am Board Fam Med.
33 Hermush V, Daliot D, Weiss A, Brill S, Beloosesky Y. (2009). The impact of geriatric consultation on the care of the elders in community clinics. Arch Gerontol Geriatr.
34 Inouye SK, Wagner DR, Acampora D, Horwitz RI, Cooney LM, Tinetii ME. (1993). A controlled trial of a nursing-centered intervention in hospitalized elderly medical patients: the Yale Geriatric Care Program. Journal of the American Geriatrics Society.
35 Pawlson LG. (1988). Hospital length of stay of frail elderly patients. Primary care by general internists versus geriatricians. J Am Geriatr Soc.
36 Peleg R, Press Y, Asher M, et al. (2008). An intervention program to reduce the number of hospitalizations of elderly patients in a primary care clinic. BMC Health Serv Res.
37 Phillips SL, Phillips JV, Branaman-Phillips J, Miller DJ. (2005). Geriatric versus non-geriatric approach of care to moderate Pra risk senior population. J Am Med Dir Assoc.
38 Sennour Y, Counsell SR, Jones J, Weiner M. (2009). Development and implementation of a proactive geriatrics consultation model in collaboration with hospitalists. J Am Geriatr Soc.