# Evidence Brief: Use of Intradialytic Parenteral Nutrition (IDPN) to Treat Malnutrition in Hemodialysis Patients

### Background

The ESP Coordinating Center (ESP CC) is responding to a request from the Veterans Affairs Renal Field Advisory Committee for an evidence brief on the use of Intradialytic Parenteral Nutrition (IDPN) for the treatment of malnutrition among hemodialysis patients. Findings from this evidence brief will be used to develop recommendations on the use of IDPN in the treatment of Veteran hemodialysis patients with malnutrition.

### Methods

To identify studies, we searched MEDLINE®, Cochrane Database of Systematic reviews, Cochrane Central Register of Controlled Trials, and other sources up to October 2017. We used prespecified criteria for study selection, data abstraction, and rating internal validity and strength of the evidence. See our PROSPERO protocol for our full methods.

## EXECUTIVE SUMMARY

Chronic kidney disease (CKD) is a major public health concern, affecting 14.8% of US adults in 2011-2014, and was the 9th leading cause of death in the US in 2016. Progression of CKD leads to endstage renal disease (ESRD), a total and permanent failure of kidney function requiring kidney transplant or maintenance hemodialysis. More than half (63.1%) of all prevalent ESRD cases receive hemodialysis, and despite its advantages, hemodialysis patients often suffer poor health outcomes, including substantially worse survival rates than the general population. Malnutrition affects 20-60% of hemodialysis patients and is one of the strongest predictors of mortality and morbidity in this population. A range of therapies exist for treatment of malnutrition in hemodialysis patients, and guidelines recommend nutritional counseling and oral nutrition supplements as first-line treatment for malnutrition in hemodialysis patients. If dietary counseling and oral nutrition supplements do not improve nutrition, guidelines recommend enteral tube feeding.

Parenteral nutrition is another option for patients who cannot tolerate oral or enteral routes, due to malfunction of the GI tract, chronic nausea, vomiting, or anorexia, or for patients with previous failed attempts with oral or enteral routes. Intradialytic parenteral nutrition (IDPN) is a form of partial parenteral nutrition administered during regularly scheduled dialysis sessions. Proponents of IDPN state that it is a safe and convenient way to supplement nutrient intake during a time when patients are already receiving treatment. However, IDPN therapy has a risk of harms (infection, fluid overload, chemical imbalance, etc) and increased costs compared to other therapies. Guidelines recommend use of IDPN only after nutritional counseling, oral, and/or enteral routes have been tried. However, barriers to following treatment recommendations (taste of oral supplements, nausea, lack of support, concerns about tube feeding, etc), ease of use, and potential profit have led to earlier pursuit of IDPN.

IDPN does not appear to improve patient health or clinically important nutritional outcomes compared to the standard and recommended treatments of oral supplementation or dietary counseling (Executive Summary Table). For IDPN to best demonstrate a clinically important benefit over recommended treatment, ideally (1) it would significantly reduce the risk of mortality, (2) it would improve the functional status and quality of life of survivors, and (3) these benefits could be attributed specifically to IDPN and not differences between intervention and control groups in concomitant treatments, disease state, level of malnutrition, or other potentially confounding factors. However, primarily because detail about control group treatment regimens is inadequate to determine applicability to current practice, current evidence does not reliably demonstrate such benefits for IDPN. For example, in one of the most recent RCTs that compared IDPN to “standardized nutritional counseling”, IDPN increased rates of a 15% improvement in serum prealbumin at 4 weeks compared to control (41% IDPN vs 20.5% control, P = .0415). However, the meaningfulness and reliability of this finding is unclear because (1) the RCT lacked adequate information to determine what kind of intervention (if any) the control group received, and (2) although the 15% was noted to be a “relevant” increase, clinical justification for this threshold was not provided, data were not provided for this threshold at the end of the study (16 weeks), and this threshold was not pre-specified in the protocol. Compared with oral supplements, in the only RCT with an adequately described control group treatment regimen, IDPN did not improve mortality, hospitalization, or quality of life. Additionally, compared with “usual care”, although studies demonstrated some benefits for IDPN, such as a mortality benefit seen for patients with lower baseline serum albumin levels (≤ 3.3 g/dL), inadequate detail about the control group treatment regimen similarly limits the usefulness of this evidence, and the clinical importance of the nutritional improvements is unclear as they were based on changes in mean scores and not clinically relevant thresholds. No study has compared IDPN to enteral tube feeding. Limited data are available regarding the adverse effects of IDPN. Commonly reported adverse events, including nausea, muscle pain, infections, and procedural complications, may be common in this patient population due to disease severity and comorbidities, and no differences between IDPN and control groups were reported.

Executive Summary Table Effect of IDPN on Patient Health and Nutritional Outcomes

| Patient Health Outcomes | | Nutritional Indicators
IDPN Compared to Oral Supplements
| No improvement in mortality, hospitalization or quality of life; Evidence: 1 fair-quality RCT^1^ | | Variable effect with no improvement in nutritional indicators except serum albumin in a single study; Evidence: 2 fair-quality RCTs^1,2^ and 1 fair-quality cohort study^3^
IDPN Compared to Dietary Counseling
| No improvement in mortality, hospitalization, or quality of life; Evidence: 1 fair-quality RCT^4^ | | Variable effects on serum prealbumin No improvement in serum albumin or SGA; Evidence: 1 fair-quality RCT^4^
IDPN Compared to Usual Care^*^
| Variable effect on mortality; effect differs by baseline serum albumin level; Evidence: 3 fair-quality cohort studies^5-7^ | | Variable effect with improvement in at least one nutritional indicator; Evidence: 2 fair-quality RCTs^8,9^ and 3 fair-quality cohort studies^5,7,10^
| No improvement in quality of life; Evidence: 1 fair-quality RCT^9^

≈ No difference in outcomes; ⇵ mixed effects on outcomes

Patient Health Outcomes=mortality, hospitalization, or quality of life/functional impairment

Nutritional Indicators=serum albumin, serum prealbumin, subjective global assessment, malnutrition inflammation score, body mass index, body weight, mid-arm circumference, triceps-skinfold thickness

* Usual care=following regular protocol of treatment; may include dietary counseling or oral supplements based on patient condition and physician recommendation

Despite existing guidelines recommending IDPN only for hemodialysis patients with refractory malnutrition, IDPN is commonly being requested or used prior to other treatment options. However, current evidence is inadequate to demonstrate a benefit for IDPN over recommended treatments. Although IDPN has not been explicitly studied in hemodialysis patients who have failed adequate trials of or are unable to receive dietary counseling, oral, and/or enteral tube feeding due to malfunctioning GI tract or other issues, since evidence ‒ albeit limited ‒ has not raised concerns about IDPN safety, we agree with existing guidelines that it appears reasonable to consider use of IDPN in this population. Future research or coverage with evidence development efforts should focus on comparing IDPN with enteral tube feeding, as well as aiming for more clinically relevant outcome assessment, larger sample sizes, longer follow-up duration, and better-characterized control groups.

## EVIDENCE BRIEF

### INTRODUCTION

#### PURPOSE

The ESP Coordinating Center (ESP CC) is responding to a request from the Veterans Affairs Renal Field Advisory Committee for an evidence brief on the use of Intradialytic Parenteral Nutrition (IDPN) for the treatment of malnutrition among hemodialysis patients. Findings from this evidence brief will be used to develop recommendations on the use of IDPN in the treatment of Veteran hemodialysis patients with malnutrition.

#### BACKGROUND

Chronic kidney disease (CKD) is a major public health concern, affecting 14.8% of US adults in 2011-2014,^11^ and was the 9th leading cause of death in the US in 2016.^12^ The kidneys are responsible for filtering waste and extra fluid out of the blood stream. CKD is a gradual loss of this kidney function and can be caused by a wide range of factors, including diabetes, high blood pressure, kidney disease, and recurrent kidney infection. The Veteran population has high rates of certain comorbidities linked to CKD, including diabetes mellitus and hypertension. Thus, the prevalence of CKD in Veterans is estimated to be about 47%, substantially higher than in the general population.^13,14^ Additionally, VHA patients have a lower rate of kidney transplantation and are more likely to die on the transplant waitlist compared to those with private insurance.^15^ Progression of CKD can ultimately lead to end-stage renal disease (ESRD), a total and permanent failure of kidney function. When the kidneys can no longer remove waste and extra fluid from the blood stream, this can lead to swelling, exhaustion, seizures, coma, and ultimately death.^16^ In 2014, the unadjusted prevalence of ESRD was 2,067 per million, an increase of 54.1% since 2000.^11^ Patients with ESRD require kidney transplant or dialysis treatment to replace kidney function. The most common treatment for ESRD is hemodialysis, with more than half (63.1%) of all prevalent ESRD cases receiving hemodialysis. Hemodialysis filters a patient’s blood outside of the body through a dialysis machine. Although hemodialysis is not a cure for kidney failure, it ameliorates the detrimental effects of kidney failure, and can greatly extend life expectancy.^17^ Despite its advantages, hemodialysis patients often suffer poor health outcomes, including substantially worse survival than the general population (57% 3-year survival among hemodialysis patients vs 92% 3-year survival among age- and sex-matched general population) and higher mortality rates than kidney transplant patients (166 deaths vs 30 deaths per 1,000 patient years).^11^

One of the strongest predictors of morbidity and mortality among hemodialysis patients is malnutrition, affecting 20-60% of patients.^18–20^ Malnutrition refers to deficiencies or adverse changes in nutritional or energy intake, and can lead to loss of body mass, poor wound healing, and organ failure. In the general population, malnutrition is usually caused by inadequate intake of energy or nutrients.^21^ However, in hemodialysis patients, malnutrition is the result of a complex interplay between many factors, including inadequate food intake, chronic inflammation, blood loss, comorbid diseases, dietary restrictions, and renal and dialysis insufficiency.^20,22–24^ The interaction between these factors and disease state results in losses in protein and energy stores and metabolic alterations, termed protein-energy wasting (PEW) or protein-energy malnutrition (PEM).^20,24^ Clinical criteria to define malnutrition vary, and have changed over time. Current guidelines for the treatment of malnutrition in hemodialysis patients (see Supplemental Materials Appendix A) generally include one or more clinical, anthropometric, or biochemical measures, and the European Society of Clinical Nutrition and Metabolism (ESPEN) recently provided a minimum set of criteria for diagnosing malnutrition (Figure 1).^25^ One of the more notable changes in the recent ESPEN criteria is that serum protein levels (eg, serum albumin) are no longer included as a preferred marker of nutritional status, as they can commonly be reduced due to inflammation, and not necessarily malnutrition.^25^

Figure 1 Criteria for Diagnosing Malnutrition

A range of therapies exist for treatment of malnutrition in hemodialysis patients. Guidelines recommend nutritional counseling as a first-line treatment for malnutrition in hemodialysis (see Supplemental Materials Appendix A). Nutritional counseling generally involves working with a registered dietician or nutritionist to assess patient- and disease-specific nutrient and energy needs, monitor intake and indicators of nutritional status, determine deficiencies, and educate patients on ways to improve or increase total energy or specific nutrient intake. Meal trays may also be provided during dialysis sessions. However, this is not commonly practiced in the US due to concerns of postprandial hypotension, choking and infection risks, and control of diabetes and phosphorus levels.^26^ Guidelines commonly recommend oral supplementation to aide in improving nutrient and energy intake, often in conjunction with nutritional counseling, if patients are unable to meet energy and nutrient requirements through eating meals. Oral supplements typically include liquids, bars, or shakes, which may be standard nutritional supplements (eg, ZonePerfect®, Ensure®), or may be designed for patients on dialysis to meet specific nutritional needs and dietary restrictions (eg, Nepro®).^27,28^ Oral supplements can be provided during dialysis sessions (intradialytic oral supplementation) or more frequently outside of dialysis sessions.^29^ Oral nutrition supplementation has been shown to improve nutritional indicators (ie, serum albumin), but there are limited data on long-term clinical outcomes.^27^ Common barriers to compliance and satisfaction with dietary counseling and oral nutrition supplements can include taste, nausea, diarrhea, and lack of support (ie, difficulty timing meals on dialysis days, limited food access, support for food preparation, finding foods/supplements meeting dietary restrictions, etc).

When dietary counseling and oral nutrition do not adequately improve nutritional status, guidelines recommend enteral tube feeding. This is when a small, flexible tube is surgically or endoscopically inserted into the nose (for short-term needs, generally < 3 months) or through the abdomen (for longer-term needs) to feed the gastrointestinal (GI) tract directly.^30,31^ The frequency and composition of the feedings is prescribed by the patient’s clinical and nutritional team and can be modified based on changes in nutritional status indicators to provide more or less of the required nutrition. Patients are encouraged to continue eating with a feeding tube in place, and feeding and maintenance of the tube can be done by the patient or caregiver at home. Although patients may be concerned about the appearance of the tube and the logistics of feeding and maintaining the tube at home, nutritionists particularly recommend oral and enteral supplementation because they maintain the usual physiological mechanisms of the GI tract.

Parenteral nutrition (PN) is another option for patients who cannot tolerate oral or enteral tube routes, due to malfunction of the GI tract, chronic nausea, vomiting, or anorexia, or for patients with previous failed attempts with oral and/or enteral tube routes. PN is the infusion of an intravenous nutritional formula into the blood stream, and is commonly used among hospitalized patients.^32^ Intradialytic PN (IDPN) is a form of partial parenteral nutrition administered during regularly scheduled dialysis sessions as a supplement (commonly 3 times per week), and requires the patient to get some of their nutrients orally outside of dialysis time.^29,33–35^ IDPN often consists of a mixture of amino acids, glucose, and lipids, which may be purchased as a commercially available standardized multi-chamber PN solution (eg, Kabiven®^36^ or Clinimix®^37^) or may be compounded directly by hospital- or clinic-associated pharmacies. Commercially available standardized solutions may be being labor- and cost-saving compared to pharmacy compounding,^38^ but the trade-off is that they cannot be tailored to meet individual patient’s unique nutritional needs.

The estimated cost of IDPN therapy is ~$300/day per patient, compared to about $1 for each bar or shake of standard nutritional supplement (ZonePerfect®^39^, Ensure®^40^), or $2-4 per can of disease-specific oral supplement (Nepro®^41^). Many insurers, including Medicare, Priority Health, and Blue Cross Blue Shield, typically only cover IDPN under specific eligibility criteria (eg, ≥ 10% sustained weight loss for at least 3 months, serum albumin ≤ 3.4 g/dL, AND failure to respond to oral or enteral nutrition treatment) (see Supplemental Materials Appendix B for full details). The current (2013) VHA Nutrition Therapy Handbook does not include guidelines for provision or coverage of IDPN, and use within VHA clinics and approval of requests from outside clinics varies among VHA sites.

Despite existing guidelines recommending IDPN only for hemodialysis patients with refractory malnutrition, IDPN is commonly being requested or used prior to other treatment options. For example, the VHA receives requests from community providers for IDPN for patients who have not tried oral or enteral tube nutrition therapies. These requests most commonly come from Fresenius and DaVita, which are for-profit companies that treated the largest percentage (69%) of hemodialysis patients in the US in 2014.^42^ Interest in earlier initiation of IDPN may be due to multiple factors, including the barriers to oral or enteral tube nutrition described above, IDPN’s non-invasive and passive nature, ease of use, profit, and/or clinical staffing (eg, lack of onsite nephrologists or dieticians). Proponents of IDPN state that it is a safe and convenient way to supplement nutrient intake during a time when patients are already receiving treatment. However, IDPN therapy has a potential for risk of harms (infection, fluid overload, chemical imbalance, hyperglycemia, etc) and increased costs compared to other therapies.^20,43^

Due to its higher cost, initiating IDPN prior to other treatment options would ideally be supported by improved patient health outcomes and nutritional status compared to other therapies. In hemodialysis patients, decreased serum albumin (< 3.5-4.0 g/dL) and prealbumin (< 20-30 mg/dL) levels are often cited as the strongest predictors of poor health outcome, including mortality.^1,18,19,44–46^ However, more recently, protein levels are not recommended in the screening and outcome assessment of malnutrition.^25^ Single nutritional indicators may be low for various reasons, including inflammation or stress, and thus cannot be used alone to assess overall nutrition status.^25^ Clinical response to protein administration also may vary depending upon inflammation, oral intake, and the amount of protein in IDPN (which varies amongst IDPN solutions). Additionally, statistically significant mean improvements in biochemical markers do not always translate into clinically significant benefits. Therefore, full evaluation of IDPN’s benefit-risk profile would ideally include achievement of a clinically-relevant improvement in multiple markers of nutritional status (biochemical, weight status and change, SGA score, etc), as well as improvements in quality of life and/or mortality without increasing the risk of important harms.

The most recent systematic review from 2010 concluded that data at that time were insufficient to definitively determine the benefit of IDPN.^47^ However, since 2010, 3 new randomized controlled trials have emerged. The objective of this evidence brief is to synthesize the evidence regarding the effectiveness, harms, and cost-effectiveness of using intradialytic parenteral nutrition (IDPN) in hemodialysis patients with malnutrition.

#### KEY QUESTIONS

Key Question 1: What is the effectiveness of IDPN for the treatment of malnutrition in hemodialysis patients?

Key Question 2: What are the potential adverse effects of using IDPN for the treatment of malnutrition in hemodialysis patients?

Key Question 3: What is the cost-effectiveness of using IDPN for the treatment of malnutrition in hemodialysis patients?

Key Question 4: Do the effectiveness and potential adverse effects of IDPN differ per patient characteristics (eg, patient demographics, comorbidities, disease severity)?

#### ELIGIBILITY CRITERIA

The ESP included studies that met the following criteria:

- [underlined: P]opulation: Hemodialysis patients
- [underlined: I]ntervention: Intradialytic parenteral nutrition (IDPN)
- [underlined: C]omparator: Any other nutritional supplementation
- [underlined: O]utcomes:
  - o Clinically relevant improvement in individual indicators of nutrition status (eg, body weight, arm-muscle circumference, triceps-skinfold thickness, serum albumin, (ie, percent of patients reaching pre-specified threshold)), global nutrition status (eg, subjective global assessment, malnutrition inflammation score), mortality, morbidity, hospitalization, quality of life, cost-effectiveness
  - o Harms: Any (eg, unsafe increases in serum triglycerides, nausea, hypoglycemia, infections)
- [underlined: T]iming: Any
- [underlined: S]etting: Any
- [underlined: S]tudy design: Any, but may prioritize to accommodate timeline using a best-evidence approach

#### ANALYTIC FRAMEWORK

The analytic framework below (Figure 2) illustrates the [underlined: P]opulation, [underlined: I]nterventions, [underlined: C]omparators, [underlined: O]utcomes, [underlined: T]iming, [underlined: S]etting, and [underlined: S]tudy design (PICOTSS) of interest that guided this review and their relationship to the key questions. This evidence brief evaluates the link between IDPN, health, and clinically significant outcomes (Key Question 1) and potential risks (Key Question 2). Key Question 4 examines whether the benefits and/or risks of IDPN differ per patient characteristics (eg, patient demographics, comorbidities, disease severity). Key Question 3 examines the cost-effectiveness of IDPN and is not included in the analytic framework.

Figure 2 Analytic Framework of IDPN for Malnutrition in Hemodialysis Patients

## METHODS

We followed the steps in the systematic review process outlined below. The complete description of our methods can be found on the PROSPERO international prospective register of systematic reviews (http://www.crd.york.ac.uk/PROSPERO/; registration number CRD42017074001). A draft version of this report was reviewed by peer reviewers as well as clinical leadership (Supplemental Materials Appendix F).

Figure 3 Review Methods

## RESULTS

### Literature Flow

The literature flow diagram (Figure 4) summarizes the results of the search and study selection processes (see Appendix D in supplemental materials for full list of excluded studies).

Figure 4 Literature Flowchart

Our search identified 286 unique, potentially relevant articles. We included 5 RCTs,^1,2,4,8,9^ 6 cohort studies,^3,5–7,10,48^ and 3 systematic reviews.^27,47,49^ The 3 systematic reviews did not include formal assessment of individual study quality,^47,49^ or did not find any studies for the key question relating to IDPN,^27^ and were used only to identify relevant primary studies. We did not identify any comparative studies assessing cost-effectiveness outcomes, and to fill this gap we included one non-comparative before-after study reporting cost-effectiveness.^50^

Table 1 summarizes characteristics of the included RCT and cohort studies (see Supplemental Materials Appendix E for full evidence tables). Except for one large retrospective cohort,^6^ most studies were small (sample size range 12-196) with follow-up ranging from 12 weeks to 2 years. Mean patient age was 65 years (range 37 to 80) with an even distribution of male to female patients (mean 50% male). All but 3 studies^5,6,48^ were outside of the US, and no studies were specifically in a VA population. Patients were most often on chronic hemodialysis, with at least 6 months on dialysis prior to inclusion in the study. IDPN treatment varied among studies and was often ill-described. The majority of IDPN were standard solutions, but were not purchased premixed. Two studies^1,4^ tailored IDPN solutions to patient characteristics. The most common comparison was to “usual recommended diet”, but limited information was given on the details of the diet or if any nutritional counseling was provided. No studies compared IDPN to enteral tube nutrition support. Baseline nutritional status was commonly reported as serum albumin (mean=3.77 g/dL (range 3.02 to 3.8 g/dL)) or BMI (range 19.2 to 23.4 kg/m^2^), and the criteria for malnutrition varied across studies, with most utilizing serum albumin of < 3.5 g/dL or < 4.0 g/dL along with at least one other predictor of malnutrition (weight loss, BMI, nutritional score or assessment, etc). All but 3 studies^3,7,48^ were rated as fair quality, with common methodological limitations including unclear or high levels of nonadherence (eg, 19-26% discontinued oral supplementation and 24% discontinued IDPN^1^), unclear or between-group differences in attrition (eg, 17% control vs 0% IDPN^2^) among RCTs, lack of information about criteria for inclusion and exclusion of patients, and unclear handling of missing data. Three poor-quality studies had the additional methodological limitation of unadjusted baseline differences between intervention and control groups. We sent requests for scientific information to 4 commercial dialysis providers and/or IDPN manufacturers to identify additional published, unpublished, and supplemental data on published studies. We received responses from 2 dialysis providers and/or IDPN manufacturers, but no new material was identified.

Table 1 Characteristics of Included RCTs and Cohorts

Author, Year N | Study Design Follow-up | Mean age % male | Baseline mean SA (g/dL) | Baseline mean BMI/BW | Intervention | Comparator
Cano, 1990^8^ N= 26 | RCT 12 weeks | 58 years 58% male | 3.7 | % BW: 88.8 | IDPN 3x/week | Usual recommended diet
Cano, 2007 FineS^1^ N=186 | RCT 2 years | 68 years 47% male | 3.16 | BMI: 22.8 | IDPN + oral Per usual dialysis | Oral sup.
Capelii,1994^5^ N=81 | Retrospective Cohort 1 year | 60 years 51% male | 3.02 | NR | IDPN 3x/week | Usual recommended diet +/- oral sup.
Chertow,1994^6^ N=24,196 | Retrospective Cohort 1 year | 58 years 50% male | 3.74 | NR | IDPN Details NR | Usual recommended diet
Hiroshige,1998^7^ N=28 | Prospective cohort 6 months | 77 years 57% male | 3.41 | BMI: 19.2 | IDPN 3x/week | Usual recommended diet
Joannidis, 2008^10^ N=12 | Prospective cohort 6 months | 80 years 50% male | 3.57 | BMI: 22.4 | IDPN Per usual dialysis | Usual recommended diet
Liu, 2016^2^ N=32 | RCT 9 months | 72 years 44% male | 3.74 | BMI: 21.4 | AA+50% G OR 50% G 3x/week | Oral sup. + nutritional counseling
Marsen,2017^4^ N=107 | RCT 28 weeks | 74 years 47% male | 3.44 | BMI: 22.6 | IDPN 3x/week | Nutrition counseling
Oguz, 2001^3^ N=20 | Prospective cohort 4 months | NR NR | 3.8 | BMi: 23.4 | AA only 3x/week | Oral amino acids + calcium
Piraino, 1981^48^ N=46 | Prospective cohort 20 weeks | NR NR | NR | NR | EAA + NEAA + G OR EAA + G 3-4x/week | Weight-stable chronic HD patients
Thabet, 2017^9^ N=40 | RCT 6 months | 37 years 58% male | 3.02 | BMI: 19.4 | IDPN + IV vitamins 3x/week | IV vitamins

Abbreviations: G=glucose; EAA=essential amino acids; NEAA=non-essential amino acids; RCT=randomized controlled trial; HD=heinodialysis; NR=not reported; BMI=body mass index; BW=body weight; SA=semm albumin; sup=supplements; FineS: French Intradialytic Nutrition Evaluation Study; IV=intravenous

### KEY QUESTION 1 What is the effectiveness of IDPN for the treatment of malnutrition in hemodialysis patients?

#### IDPN Compared to Oral Supplements

IDPN does not appear to improve patient health or nutritional outcomes compared to oral supplementation (Table 2). One year of individualized IDPN treatment did not improve 2-year mortality, hospitalization rate, or quality of life in the French Intradialytic Nutrition Evaluation Study (FineS) RCT of 186 malnourished chronic hemodialysis patients.^1^ Additionally, in 2 RCTs using IDPN^1^ or amino acid plus glucose infusion^2^, there were no differences in improvements in BMI, serum albumin, serum prealbumin, or subjective global assessment score (SGA) compared to oral supplements. This evidence is limited by small sample size and nonadherence (19-26% discontinued oral supplements and 24% discontinued IDPN)^1^ or differences in attrition between groups (17% control vs 0% IDPN).^2^ The only significant improvement in nutritional indicators was in a single, small (N = 20) prospective cohort from Turkey which reported significantly increased serum albumin after 4 months in patients receiving IDPN but not in patients receiving oral amino acid supplementation.^3^ However, this study did not directly compare intervention and control groups, and is limited by lack of adherence (40% of patients transferred from oral supplements to IDPN due to non-compliance) and no statistical adjustment for these potential confounding factors.

Table 2 Effect of IDPN versus Oral Supplements on Patient Health and Nutritional Outcomes

| Evidence
| 1 fair-quality RCT (N=186)^1^ | 1 fair-quality RCT (N=32)^2^
Patient Health Outcomes
Mortality | Mortality rate: 43% vs 39% (P = NS)
Hospitalization | # days hospitalized/days follow-up: 0.008 vs 0.06 (P = NS)
QoL/ Functional Impairment | No difference in Karnofsky score (data NR)
Nutritional Outcomes^*^
SA
PA
SGA
BMI
MAC
TSF

* full data available in Supplemental Materials Appendix E; Data presented as intervention versus control

= data not reported

≈ = no difference in outcomes

Abbreviations: SA=serum albumin; NS=non-significant; NR=not reported; QoL=quality of life; PA=serum prealbumin; SGA=subjective global assessment; BMI=body mass index; MAC=mid-arm circumference; TSF=triceps-skinfold thickness; PC=prospective cohort

#### IDPN Compared to Dietary Counseling

A single RCT of 107 chronic hemodialysis patients funded and co-authored by an employee of Fresenius Kabi Germany GmbH compared 16 weeks of IDPN, “individually compounded according to official recommendations with products supplied by Fresenius Kabi Deutschland GmbH”, to patients maintained on “regular food behavior”.^4^ All patients received nutritional counseling at baseline, but it is unclear what (if any) intervention the control group received throughout the study period. IDPN did not consistently improve patient health or nutritional outcomes. More patients receiving IDPN reached a 15% improvement in serum prealbumin at 4 weeks compared to control (41% IDPN vs 20.5% control, P = .0415). However, the meaningfulness and reliability of this finding is unclear as (1) although the 15% threshold was noted to be a “relevant” increase, clinical justification for this threshold was not provided, data for this threshold were not provided at the end of the study (16 weeks), and this threshold was not pre-specified in the protocol; (2) the mean improvement in serum prealbumin (26.31 mg/L) at 16 weeks did not reach the threshold of > 30 mg/L found to be associated with a mortality reduction in Cano 2007; (3) it did not improve the % of patients who achieved the > 30 mg/L threshold (48.7% vs 31.8%, P = .1164); (4) it did not improve clinical outcomes of mortality (26.4% vs 12.9%, ESP calculated P = .09), hospitalization (hospitalization rate: 59% vs 43.2%, P = .15), or quality of life (change in SF-12 score: -2.74 vs 0.34, P = .1175); and (5) the study had the important limitations of small sample size, indirect outcomes, and lack of information on what kind of intervention (if any) the control group received and potential co-interventions.

#### IDPN Compared to Usual Care

IDPN generally reduced risk of mortality and improved mean scores on various nutritional outcomes compared to usual care (Table 3). However, usual care was not well-defined in these studies; it was commonly only reported as “usual recommended diet” making it difficult to assess applicability to specific clinical circumstances. Additionally, we do not have any information about the quality of life or functionality of the patients who survived. The largest non-randomized study^6^ found that the effects of IDPN on 1-year mortality were dependent upon baseline serum albumin levels. Patients with lower baseline serum albumin (≤ 3.3 g/dL) had reduced odds of death with IDPN treatment (OR range 0.61 to 0.72, P < .01, estimated from Figure 2). Conversely, patients with higher baseline serum albumin (> 3.3 g/dL) had similar or increased odds of death compared to controls (OR range 0.85 (estimated from Figure 2), P = .10 to 2.6, P < .005). Although this study was large, interpretation of its findings is limited as we do not have details about what intervention or control patients received during the study period (including duration or specifics of IDPN treatment, receipt of other nutritional interventions, etc), making it difficult to judge intervention adherence or potential co-interventions in this study. Additionally, we have no information on quality of life or function in the surviving patients. One smaller (N = 81) non-randomized study (baseline serum albumin 3.02 g/dL) also found improved survival with IDPN treatment, but it was small (N = 81) in addition to lacking of information on control group care.^5^ Additionally, a single RCT of 40 chronic hemodialysis patients with refractory anemia reported no improvements in nutritionally related functional capacity with IDPN treatment or usual care.^9^ Although several studies found improved mean scores on various nutritional outcomes compared to usual care, no study reported the proportion of patients reaching clinically meaningful improvements in nutritional outcomes. These studies are limited by small sample size (all but one N < 100), lack of information on intervention adherence, and limited statistical adjustment for potential confounders among non-randomized studies. Two studies with additional limitations (no adjustment for potential confounders)^7,48^ reported similar findings.

Table 3 Effect of IDPN versus Usual Care on Patient Health and Nutritional Outcomes

| Evidence
| 1 fair-quality RCT (N=26)^8^ | 1 fair-quality RCT (N=40)^9^ | 1 fair-quality RC (N=81)^5^ | 1 fair-quality RC (N=24,196)^6^ | 1 fair-quality PC (N=12)^10^
Patient Health Outcomes
Mortality | | | RR survival =1.34 (P < .01) | OR death range 0.57† to 2.6 (P < .01)
QoL/ Functional Impairment | | Functional capacity (data NR)
Nutritional Outcomes*
SA
PA
SGA/MIS
BMI
BW | | | Survivors; Non-survivors
MAC
TSF

= data not reported; ≈ No difference in outcomes, ↑ = improvement in outcomes with IDPN: ⇵ = mixed effect on outcomes; Data presented as intervention versus control; † Estimated from Figure; *full data available in Supplemental Materials Appendix E

Abbreviations: SA=serum albumin; PA=serum prealbumin; SGA=subjective global assessment; MIS=malnutrition inflammation score; BMI=body mass index; BW=body weight; MAC=mid-arm circumference; TSF=triceps-skinfold thickness; RC=retrospective cohort; PC=prospective cohort

We are aware of 20 additional before-after studies with no non-IDPN control.^51–67^ ^68–70^ Most of these studies report significant increases in at least one nutritional or patient health indicator after IDPN treatment. However, these studies were not formally included in our synthesis due to inherent weaknesses in study design.^71^

### KEY QUESTION 2 What are the potential adverse effects of using IDPN for the treatment of malnutrition in hemodialysis patients?

Limited data are available regarding the adverse effects of IDPN, with only 4 of the included studies reporting adverse events. Two RCTs^1,4^ reported 12-14% of patients experiencing adverse events causing discontinuation of IDPN. Commonly reported adverse events included nausea, muscle pain, infections, hyperglycemia, and procedural complications. No differences in adverse events between intervention and control groups were reported, and some of these events may be common in this population due to disease state.^72^ However, interpretation of these findings as consistent evidence of adverse effects is limited by (1) heterogeneity in outcomes, treatment duration, and follow-up duration; and (2) adverse events in these studies that may have been artificially underestimated due to more frequent laboratory monitoring and/or assessment.

### KEY QUESTION 3 What is the cost-effectiveness of using IDPN for the treatment of malnutrition in hemodialysis patients?

A single study with no concurrent non-IDPN comparator reported a significant decrease in the average number of hospitalizations, cost of hospitalizations, and the length of stay (P < .05) after 6 months of IDPN therapy. However, when the cost of IDPN was taken into account, there were no overall cost savings for the 6 months of therapy.^50^ This evidence is limited by a lack of comparison to a concurrent non-IDPN control group^71^ and limited information on patient, dialysis, and IDPN characteristics.

### KEY QUESTION 4 Do the effectiveness and potential adverse effects of IDPN differ per patient characteristics?

There is insufficient evidence to draw conclusions about the differential effectiveness of IDPN in subgroups. Although the effects of IDPN may be greater in patients with lower baseline serum albumin levels, our confidence in these findings is low as they must be considered taking into account the previously described limitations of serum protein levels in screening and outcome assessment of malnutrition. A single, large, non-randomized study reported mortality by baseline serum albumin level.^6^ For patients with baseline serum albumin ≤ 3.3 g/dL there was reduced odds of death with IDPN treatment. However, for patients with baseline serum albumin ≤ 3.4 or 3.5 g/dL, there was no difference in mortality with IDPN treatment, and for patients with baseline serum albumin > 3.5 g/dL the odds of death were higher among IDPN-treated patients than control patients.

## SUMMARY AND DISCUSSION

### KEY FINDINGS AND CLINICAL IMPLICATIONS

The outcomes of untreated malnutrition are poor and associated costs are high. Therefore, treatment of malnutrition in hemodialysis patients is a priority, and early efforts to improve oral intake and the use of enteral nutrition supplements are important. IDPN has been proposed as a safe and convenient way to supplement nutrient intake to improve nutritional status and patient health outcomes for malnourished hemodialysis patients during a time when patients are already receiving treatment. Due to its higher cost, however, initiating IDPN prior to guideline-recommended first-line treatment options would ideally be supported by improved patient health outcomes and nutritional status compared to other therapies. For IDPN to best demonstrate a clinically important benefit over recommended treatment, ideally (1) it would significantly reduce the risk of mortality, (2) it would improve the functional status and quality of life of survivors, and (3) these benefits could be attributed specifically to IDPN and not to differences between intervention and control groups in concomitant treatments, disease state, level of malnutrition, or other potentially confounding factors. However, primarily because detail about control group treatment regimens is inadequate to determine applicability to current practice, current evidence does not reliably demonstrate such benefits for IDPN. IDPN has not significantly improved patient health or nutritional outcomes better than the current guideline-recommended treatments of dietary counseling and oral supplementation in any of 3 RCTs.^1,2,4^ No studies have compared IDPN to enteral tube feeding. Compared to usual care, 2 RCTs^8,9^ and 5 cohort studies^5–7,10,48^ showed varied results on the effect of IDPN on patient health and nutritional outcomes, with improvements in single nutritional indicators commonly reported. However, single nutritional indicators are not sufficient to fully assess a patient’s overall nutritional or clinical status as they may be low for various reasons, including inflammation or stress, and thus cannot be used alone to assess nutritional status. For example, clinical response to protein administration may vary depending upon inflammation, oral intake, and the amount of protein in IDPN (which varies amongst IDPN solutions). For these reasons, serum protein levels (eg, serum albumin, serum prealbumin) are more recently not recommended in the screening and outcome assessment of malnutrition.^25^ Also, statistically significant mean improvements in biochemical markers do not always translate into clinically significant benefits. Therefore, full evaluation of IDPN’s benefit-risk profile would ideally include achievement of a clinically relevant improvement in multiple markers of nutritional status (biochemical, weight status and change, SGA score, etc), as well as improvements in quality of life and/or mortality, without increasing the risk of important harms.

Limited data are available regarding the adverse effects of IDPN. Commonly reported adverse events included nausea, muscle pain, infections, hyperglycemia, and procedural complications, and no differences in adverse events between intervention and control groups were reported. However, interpretation of these findings as consistent evidence of adverse effects is limited by (1) heterogeneity in outcomes, treatment duration, and follow-up duration, and (2) adverse events in these studies may have been artificially underestimated due to more frequent laboratory monitoring and/or assessment.

Evidence on the cost-effectiveness of IDPN is limited to a single study with no concurrent non-IDPN comparator which reported a significant decrease in the average number of hospitalizations, cost of hospitalizations, and the length of stay (P < .05) after 6 months of IDPN therapy, but no overall cost savings when the cost of IDPN was taken into account.^50^ However, this study did not include comparison to a concurrent non-IDPN control group,^70^ and provided limited details about patient, dialysis, and IDPN characteristics. Evidence is also limited on which patient subgroups may benefit the most from IDPN, with a single, large, non-randomized study reporting that patients with a lower baseline serum albumin level may be more likely to improve with IDPN.^6^ Although this study was large, interpretation of its findings is limited as we do not have details about what intervention or control patients received during the study period, making it difficult to judge intervention adherence or potential co-interventions in this study.

Despite existing guidelines recommending IDPN only for hemodialysis patients with refractory malnutrition, IDPN is commonly being requested or used prior to other treatment options. However, IDPN has not been demonstrated to improve patient health or nutritional outcomes better than the current guideline recommended treatments of dietary counseling and oral supplementation. Due to the substantially higher cost of IDPN and unknown cost-effectiveness, broad usage of IDPN prior to other treatment options does not appear warranted. We agree with existing guidelines^35,73^ which state that IDPN is a reasonable treatment option when confronted with patients who fail to respond to these initial treatments or are unable to receive these treatments due to malfunctioning gastrointestinal tract or other issues. There are no set recommendations for how long dietary counseling and/or oral supplementation should be tried before considering IDPN. However, chronic malnourishment for 3 to 6 months has been listed as indication that current treatments are not working.

### LIMITATIONS

There are important limitations for the evidence in this review. Apart from one large retrospective cohort,^6^ most studies were small (sample size range 12-196) with relatively short follow-up (range 12 weeks to 2 years). Measurement of clinically important outcomes such as quality of life, function, and cost-effectiveness was limited. Only a single study^4^ included measurement of clinically relevant improvement in a nutritional indicator, but the meaningfulness and reliability of this finding is limited by small sample size, short follow-up duration, indirect outcomes, and lack of information on what kind of intervention (if any) the control group received and potential co-interventions. The published studies were heterogeneous and lacked sufficient detail to assess differences in outcome based on treatment duration, IDPN solution, dialysis regimen and modality, follow-up, patient characteristics (disease severity, comorbidities, etc) and outcome assessment. No studies compared IDPN to enteral tube feeding. Additionally, the majority of studies were compared to usual care, which was ill-defined, limiting the interpretation of the findings in specific clinical circumstances. Applicability to Veterans is likely low as only 3 studies were within the US^5,6,48^ and no studies were specifically in a Veteran population. Although the mean patient age was likely applicable to Veterans (mean patient age was 65 years; median Veteran age was 64 years in 2015^74^) there was generally an even distribution of male to female patients (mean 50% male) in the studies, while Veterans are predominantly male (92%).^74^ Additionally, some studies excluded patients with diabetes and the prevalence of diabetes in the Veteran population is about 20.5%.^75^

Limitations of our review methods include our literature search, our scope, and our use of sequential instead of independent dual assessment. For our literature search, we limited the timeframe and used existing systematic and narrative reviews to identify earlier studies. To meet our condensed timeframe, we focused on the most patient important health outcomes and did not include all intermediate markers of nutritional status. Additionally, although widely used, sequential dual review has not been empirically compared to independent dual review and may increase the risk of error and bias.

### FUTURE RESEARCH

The treatment pathway for malnourishment in hemodialysis patients is generally recommended as (1) dietary counseling, (2) oral supplementation, then (3) enteral tube feeding. In order to determine when IDPN should be used, comparisons to each treatment are needed. Further studies comparing IDPN to dietary counseling are warranted. The current best evidence is limited by sample size (N < 110), short follow-up duration (28 weeks), indirect outcomes, and lack of information on what kind of intervention (if any) the control group received and potential co-interventions.^4^ Additional studies comparing IDPN to oral supplementation are also justified due to limitations in sample size (N < 200) and potentially follow-up duration (2 years).^1^ Although RCTs can be preferred because of their greater methodological rigor, we recognize that they may not be feasible due to their higher cost. Additionally, large samples with high levels of adherence and long follow-up time may not be practical in this population due to disease severity and progression. Finally, no study has compared IDPN to enteral tube feeding. In order to justify initiation of IDPN prior to trying enteral tube feeding (for patients with functioning GI tracts), IDPN should be shown to improve patient health and/or nutritional status better than enteral tube feeding in adequately powered, methodologically sound RCTs.

## CONCLUSIONS

IDPN has not been demonstrated to improve patient health or clinically important nutritional outcomes over the current guideline recommending treatments of dietary counseling and oral supplementation. Therefore, because of its higher cost, broad usage of IDPN prior to other treatment options does not appear warranted. However, because of its potential improvements in nutritional indicators, we agree with existing guidelines that IDPN is a reasonable treatment option when confronted with patients who fail to respond to these initial treatments or are unable to receive these treatments due to malfunctioning gastrointestinal tract or other issues. Limited data are available regarding the adverse effects of IDPN, but there does not appear to be significant differences in adverse events between IDPN and control groups. Future research should focus on comparing IDPN with enteral tube feeding, as well as further studies of IDPN compared to oral and/or dietary counseling with larger sample sizes, longer follow-up duration, and better-characterized control groups.

Acknowledgements: We would like to thank Julia Haskin, MA for editorial support, and Mark Helfand, MD, MS, MPH and Katherine Mackey, MD, MPP for clinical review of the draft.

## References

1. Cano NJ, Fouque D, Roth H, et al. Intradialytic parenteral nutrition does not improve survival in malnourished hemodialysis patients: A 2-year multicenter, prospective, randomized study. J Am Soc Nephrol. Sep 2007;18(9):2583–2591.17656473
2. Liu Y, Xiao X, Qin DP, et al. Comparison of intradialytic parenteral nutrition with glucose or amino acid mixtures in maintenance hemodialysis patients. Nutrients. 2016;8(6):02.
3. Oguz Y, Bulucu F, Vural A. Oral and parenteral essential amino acid therapy in malnourished hemodialysis patients. Nephron. Oct 2001;89(2):224–227.11549907
4. Marsen TA, Beer J, Mann H. Intradialytic parenteral nutrition in maintenance hemodialysis patients suffering from protein-energy wasting. Results of a multicenter, open, prospective, randomized trial. Clin Nutr. Feb 2017;36(1):107–117.26708726
5. Capelli JP, Kushner H, Camiscioli TC, Chen SM, Torres MA. Effect of intradialytic parenteral nutrition on mortality rates in end-stage renal disease care. Am J Kidney Dis. Jun 1994;23(6):808–816.8203363
6. Chertow GM, Ling J, Lew NL, Lazarus JM, Lowrie EG. The association of intradialytic parenteral nutrition administration with survival in hemodialysis patients. Am J Kidney Dis. Dec 1994;24(6):912–920.7985668
7. Hiroshige K, Iwamoto M, Kabashima N, Mutoh Y, Yuu K, Ohtani A. Prolonged use of intradialysis parenteral nutrition in elderly malnourished chronic haemodialysis patients. Nephrology, dialysis, transplantation: official publication of the European Dialysis and Transplant Association-European Renal Association. 1998;13(8):2081–2087.9719170
8. Cano N, Labastie-Coeyrehourq J, Lacombe P, et al. Perdialytic parenteral nutrition with lipids and amino acids in malnourished hemodialysis patients. Am J Clin Nutr. Oct 1990;52(4):726–730.2119558
9. Thabet AF, Moeen SM, Labiqe MO, Saleh MA. Could intradialytic nutrition improve refractory anaemia in patients undergoing haemodialysis? J Ren Care. 2017;43(3):183–191.28636166
10. Joannidis M, Rauchenzauner M, Leiner B, et al. Effect of intradialytic parenteral nutrition in patients with malnutrition-inflammation complex syndrome on body weight, inflammation, serum lipids and adipocytokines: Results from a pilot study. Eur J Clin Nutr. Jun 2008;62(6):789–795.17522619
11. United States Renal Data System. 2017 USRDS annual data report: Epidemiology of kidney disease in the United States. Bethesda, MD: National Institutes of Health, National Institute of Diabetes and Digestive and Kidney Diseases; 2017.
12. Centers for Disease Control and Prevention. Leading causes of death. FastStats 2017; https://www.cdc.gov/nchs/fastats/leading-causes-of-death.htm. Accessed November 16th, 2017.
13. Patel N, Golzy M, Nainani N, et al. Prevalence of various comorbidities among veterans with chronic kidney disease and its comparison with other datasets. Renal Failure. 2016;38(2):204–208.26671425
14. The Management of Chronic Kidney Disease Working Group. VA/DoD clinical practice guideline for the management of chronic kidney disease in primary care. Vol Version 3.0-2014. Washington D.C.: U.S. Department of Veterans Affairs/Department of Defense; 2014.
15. Augustin J, Arrigain S, Balabhadrapatruni K, Desai N, Schold J. Significantly lower rates of transplantation and increased wait list mortality among kidney transplant candidates with VA insurance. Presented at: American Society of Nephrology: Kidney Week. 2017.
16. National Institute of Diabetes and Digestive and Kidney Diseases. What I need to know about living with kidney failure. In: National Institutes of Health of the U.S. Department of Health and Human Services, ed. Bethesda, MD: National Kidney and Urologic Diseases Information Clearinghouse; 2014.
17. National Institute of Diabetes and Digestive and Kidney Diseases. Hemodialysis: What is hemodialysis and how does it work? In: National Institutes of Health of the U.S. Department of Health and Human Services, ed. Bethesda, MD: National Kidney and Urologic Diseases Information Clearinghouse; 2014.
18. Kato A, Takita T, Furuhashi M, Maruyama Y, Hishida A. Comparison of serum albumin, c-reactive protein and carotid atherosclerosis as predictors of 10-year mortality in hemodialysis patients. Hemodialysis International. 2010;14(2):226–232.20345387
19. Dwyer JT, Larive B, Leung J, et al. Are nutritional status indicators associated with mortality in the hemodialysis (hemo) study? Kidney International. 2005;68(4):1766–1776.16164653
20. Corbello J, Rosner MH. Intradialytic total parenteral nutrition (IDPN): Evidence-based recommendations. Practical Gastroenterology. 2009:13.
21. Johns Hopkins University. Health library: Malnutrition. https://www.hopkinsmedicine.org/healthlibrary/conditions/adult/pediatrics/Malnutrition22.Malnutrition. Accessed January 9th, 2018.
22. Piccoli GB, Moio MR, Fois A, et al. The diet and haemodialysis dyad: Three eras, four open questions and four paradoxes. A narrative review, towards a personalized, patient-centered approach. Nutrients. 2017;9(4):372.
23. Chung S, Koh ES, Shin SJ, Park CW. Malnutrition in patients with chronic kidney disease. Open Journal of Internal Medicine. 2012;2(02):89.
24. Carrero JJ, Stenvinkel P, Cuppari L, et al. Etiology of the protein-energy wasting syndrome in chronic kidney disease: A consensus statement from the international society of renal nutrition and metabolism (ISRNM). J Ren Nutr. Mar 2013;23(2):77–90.23428357
25. Cederholm T, Bosaeus I, Barazzoni R, et al. Diagnostic criteria for malnutrition-an ESPEN consensus statement. Clin Nutr. 2015;34(3):335–340.25799486
26. Kalantar-Zadeh K, Ikizler TA. Let them eat during dialysis: An overlooked opportunity to improve outcomes in maintenance hemodialysis patients. J Ren Nutr. 2013;23(3):157–163.23313434
27. St rat ton RJ, Bircher G, Fouque D, et al. Multinutrient oral supplements and tube feeding in maintenance dialysis: A systematic review and meta-analysis. Am J Kidney Dis. 2005:46(3):387-405.
28. Lacson E, Jr., Wang W, Zebrowski B, Wingard R, Hakim RM. Outcomes associated with intradialytic oral nutritional supplements in patients undergoing maintenance hemodialysis: A quality improvement report. Am J Kidney Dis. 2012;60(4):591–600.22632807
29. Ikizler TA. Nutrition support for the chronically wasted or acutely catabolic chronic kidney disease patient. Seminars in Nephrology. 2009;29(l):75–84.19121477
30. University of Pittsburgh Medical Center. Home gastronomy tube feeding. 2017; informational webpage. Available at: http://www.upmc.com/patients-visitors/education/nutrition/Pages/home-gastrostomy-tube-feeding.aspx. Accessed November 21st, 2017.
31. Feeding Tube Awareness Foundation. Tube types. 2016; informational webpage. Available at: http://www.feedingtubeawareness.org/tube-feeding-basics/tubetypes/. Accessed November 21st, 2017.
32. American Society for Parenteral and Enteral Nutrition. A.S.P.E.N. Parenteral nutrition fact sheet. 2012; http://www.nutritioncare.org/About [underlined: Clinical Nutrition/PN Fact Sheet April 2012/]. Accessed February 8, 2018.
33. Lazarus JM, Recommended criteria for initiating and discontinuing intradialytic parenteral nutrition therapy. Am J Kiclney Dis. Jan 1999;33(1):211–216.
34. Blue Cross of Idaho. Intradialytic parenteral nutrition. MP 8.01.44 2003; https://www.bcidaho.com/providers/medical [underlined: policies/the/mp 80144.asp]. Accessed January 9th, 2018.
35. Worthington P, Balint J, Bechtold M, et al. When is parenteral nutrition appropriate? J Parenler Enteral Nutr. 2017;41(3):324–377.
36. Fresenius Kabi. Kabiven and perikabiven. 2018; http://kabivenusa.com/. Accessed February 8, 2018.
37. Baxter. Parenteral nutrition. 2018; http://www.baxter.com/products-expertise/parenteral-nutrition/products/tpn-bag-solution.page. Accessed February 8, 2018.
38. Alfonso JE, Berlana D, Ukleja A, Boullata J. Clinical, ergonomic, and economic outcomes with multichamber bags compared with (hospital) pharmacy compounded bags and multibottle systems: A systematic literature review. J Par enter Enteral Nutr. 2017;41(7):1162–1177.
39. Walmart. Zoneperfect nutrition bar. 2018; https://www.walmart.com. Accessed February 8, 2018.
40. Target. Ensure complete balanced nutrition nutritional shake. 2018; https://www.target.com. Accessed February 8, 2018.
41. Abbott Store. Nepro with carbsteady shake. 2017; online store for nutritional products and diabetes care. Available at: https://abbottstore.com. Accessed November 28th, 2017.
42. United States Renal Data System. 2016 annual data report: Epidemiology of kidney disease in the United States. Bethesda, MD: National Institutes of Health, National Institute of Diabetes and Digestive and Kidney Diseases; 2016.
43. Sabatino A, Regolisti G, Karupaiah T, et al. Protein-energy wasting and nutritional supplementation in patients with end-stage renal disease on hemodialysis. Clin Nutr. Jun 2017;36(3):663–671.27371993
44. Kalantar-Zadeh K, Cano NJ, Budde K, et al. Diets and enteral supplements for improving outcomes in chronic kidney disease. Nature Reviews Nephrology. 2011;7(7):369–384.21629229
45. Lacson E, Wang W, Hakim RM, Teng M, Lazarus JM. Associates of mortality and hospitalization in hemodialysis: Potentially actionable laboratory variables and vascular access. Am J Kidney Dis. 2009;53(1):79–90.18930570
46. Chertow GM, Ackert K, Lew NL, Lazarus JM, Lowrie EG. Prealbumin is as important as albumin in the nutritional assessment of hemodialysis patients. Kidney International. 2000;58(6):2512–2517.11115085
47. Sigrist MK, Levin A, Tejani AM. Systematic review of evidence for the use of intradialytic parenteral nutrition in malnourished hemodialysis patients. J Ren Nutr. 2010;20(1):1–7.19788956
48. Piraino AJ, Firpo JJ, Powers DV. Prolonged hyperalimentation in catabolic chronic dialysis therapy patients. J Parenter Enteral Nutr. Nov-Dec 1981;5(6):463–477.
49. Foulks CJ. An evidence-based evaluation of intradialytic parenteral nutrition. Am J Kidney Dis. Jan 1999;33(1):186–192.9915289
50. Cranford W. Cost effectiveness of IDPN therapy measured by hospitalizations and length of stay. Nephrology News & Issues. 1998;12(9):33–35, 37–39.
51. Avery-Lynch M. Intradialytic parenteral nutrition in hemodialysis patients: Acute and chronic intervention. CANNT J. Apr-Jun 2006;16(2):30–33.
52. Berneis K, Iseli-Schaub J, Garbani E, Meier R, Kiss D. Effects of intradialytic parenteral nutrition in chronic haemodialysis patients with malnutrition: A pilot study. Wien Klin Wochenschr. Nov 12 1999;111(21):876–881.10599149
53. Bilbrey G. Is intradialytic parenteral nutrition of benefit in hemodialysis patients? Semin Dialysis. 1993;6:168–170.
54. Bilbrey G, Cohen T. Identification and treatment of protein calorie malnutrition in chronic hemodialysis patients. Dialysis & Transplantation. 1989;18(12):669–700.
55. Cherry N, Shalansky K. Efficacy of intradialytic parenteral nutrition in malnourished hemodialysis patients. Am J Health Syst Pharm. Sep 15 2002;59(18):1736–1741.12298111
56. Czekalski S, Hozejowski R. Intradialytic amino acids supplementation in hemodialysis patients with malnutrition: Results of a multicenter cohort study. J Ren Nutr. Apr 2004;14(2):82–88.15060872
57. Korzets A, Azoulay O, Ori Y, et al. The use of intradialytic parenteral nutrition in acutely ill haemodialysed patients. J Ren Care. Mar 2008;34(1):14–18.18336518
58. Madigan KM, Olshan A, Yingling DJ. Effectiveness of intradialytic parenteral nutrition in diabetic patients with end-stage renal disease. J Am Diet Assoc. Jun 1990;90(6):861–863.2111834
59. Mortelmans AK, Duym P, Vandenbroucke J, et al. Intradialytic parenteral nutrition in malnourished hemodialysis patients: A prospective long-term study. JPEN J Parenter Enteral Nutr. Mar-Apr 1999;23(2):90–95.10081999
60. Noè D, Lanzi P, Spiti R, et al. Effects of intradialytic parenteral nutrition on the nutritional status of malnourished uremic patients. Nutritional Therapy & Metabolism. 2013;31(4):176–181.
61. Olshan A, Bruce J, Schwartz A. Intradialytic parenteral-nutrition administration during outpatient hemodialysis. Dialysis & Transplantation. 1987;16(9):495–496.
62. Powers DV, Jackson A, Piraino AJ. Prolonged intradialysis hyperalimentation in chronic hemodialysis patients with an amino acid solution (renamin amino acid injection) formulated for renal failure. Perspectives in Clinical Nutrition. Baltimore, MD: Urban & Schwarzenberg. 1989:191–205.
63. Schulman G, Wingard RL, Hutchison RL, Lawrence P, Hakim RM. The effects of recombinant human growth hormone and intradialytic parenteral nutrition in malnourished hemodialysis patients. Am J Kidney Dis. May 1993;21(5):527–534.8488821
64. Siskind MS, Lien YH. Effect of intradialytic parenteral nutrition on quality of life in hemodialysis patients. Int J Artif Organs. Aug 1993;16(8):599–603.8225651
65. Smolle KH, Kaufmann P, Holzer H, Druml W. Intradialytic parenteral nutrition in malnourished patients on chronic haemodialysis therapy. Nephrol Dial Transplant. 1995;10(8):1411–1416.8538934
66. Snyder S, Bergen C, Sigler MH, Teehan BP. Intradialytic parenteral nutrition in chronic hemodialysis patients. ASAIO Trans. Jul-Sep 1991;37(3):M373–375.1751194
67. Szklarek-Kubicka M, Fijalkowska-Morawska J, Zaremba-Drobnik D, Ucinski A, Czekalski S, Nowicki M. Effect of intradialytic intravenous administration of omega-3 fatty acids on nutritional status and inflammatory response in hemodialysis patients: A pilot study. J Ren Nutr. 2009;19(6):487–493.19616450
68. Thunberg B, Jain VK, Patterson PG, Cestero RV, Swamy AP. Nutritional measurements and urea kinetics to guide intradialytic hyperalimentation. Proc Clin Dial Transplant Forum. 1980;10:22–28.6810345
69. Dezfuli A, Scholl D, Lindenfeld SM, et al. Severity of hypoalbuminemia predicts response to intradialytic parenteral nutrition in hemodialysis patients. J Ren Nutr. 2009;19(4):291–297.19477140
70. Foulks CJ. The effect of intradialytic parenteral nutrition on hospitalization rate and mortality in malnourished hemodialysis patients. J Ren Nutr. 1994;4(1):5–10.
71. Effective Practice and Organization of Care. What study designs should be included in an EPOC review? EPOC Resources for Review Authors. 2013.
72. Chandrashekar A, Ramakrishnan S, Rangarajan D. Survival analysis of patients on maintenance hemodialysis. Indian Journal of Nephrology. 2014;24(4):206.25097332
73. Cano NJ, Aparicio M, Brunori G, et al. ESPEN guidelines on parenteral nutrition: Adult renal failure. Clinical Nutrition. 2009;28(4):401–414.19535181
74. National Center for Veterans Analysis and Statistics. Profile of veterans: 2015, data from the American community survey. US Department of Veterans Affairs; 2017.
75. Liu Y, Sayam S, Shao X, et al. Prevalence of and trends in diabetes among veterans, United States, 2005-2014. Preventing Chronic Disease; 2017;14. https://www.cdc.gov/pcd/issues/2017/17_0230.htm. Accessed February 8, 2018.

## Appendix A Guidelines for Treatment of Malnutrition in Hemodialysis

Organization Year | Focus | Criteria for Malnutrition | Recommended First-line Treatment | Criteria for IDPN Initiation | Contraindications | Criteria for IDPN Discontinuation
American Society for Parenteral and Enteral Nutrition (A.S.P.E.N.) 2017^1^ | Appropriateness of PN | Energy intake of ≤50% for 5-7 days Failure to achieve nutrition goals after 7 days | Oral or enteral | Malnourished and unable to tolerate adequate oral intake or EN | Diabetic patients who may experience hypoglycemia upon discontinuation of IDPN | NR
British Columbia IDPN Work Group 2014^2^ | Provincial standards for IDPN | Patients must meet any 3 of the following criteria: 1) 3-month average SA <3.4 g/dL 2) Weight loss >10% of usual body weight or current weight <90% of ideal body weight 3) SGA score: B or C 4) Diet history showing a decreased intake 5) Documented diagnosis of Gl disorder | “Standard nutrition intervention” – oral nutritional supplements or tube feeding | Malnourished AND the patient must demonstrate the following: 1) Failed attempts to increase nutritional status with oral nutritional supplements, 2) Not be a candidate for tube feeding, 3) Able to meet ≥50% of needs orally | Allergy to eggs, corn, or sulfites; Excessive, chronic fluid overload; Patient refusal to initiate IDPN; Patient is palliative with no anticipated increase in quality of life with IDPN | Patient must meet any 3 of the following criteria: 1) 3-month average SA >3.4 g/L 2) Increasing dry weight trend 3) Improved SGA score: A or B 4) Increased oral intake OR the patient demonstrates one of the following: 1) No benefit after 6 months of IDPN 2) Complications of/intolerance to IDPN
Department of Veterans Affairs, Veterans Health Administration Nutrition Therapy Handbook 2013^3^ | ONS, EN, PN, any disease | ≥ 2 of the following characteristics: 1) Insufficient energy intake: <75% estimated energy requirement for >7 days (acute injury or illness/chronic illness) or for ≥ 3 months (social, environmental circumstances) 2) Weight loss, including (≥1-2% in 1 week, ≥5% in 1 month, ≥7.5% in 3 months, ≥10% in 6 months, or ≥20% in 1 year) 3) Mild to moderate loss of muscle mass 4) Mild to moderate loss of subcutaneous fat 5) Mild to moderate localized or generalized fluid accumulation - may mask weight loss 6) Diminished functional status (hand grip test) | Nutrition consult and trial of meeting nutrition with regular food and beverage items. ONS may be prescribed for malnourished patients after failure of food or diet management | IDPN not specified | NA | NA
The European Society for Clinical Nutrition and Metabolism (E.S.P.E.N.), 2009^4^ | Guidelines for adult parenteral nutrition | 1) BMI <20kg/m^2^ 2) >10% weight loss over 6 months 3) SA < 3.5 g/dL 4) PA < 300 mg/L | Oral nutritional supplements | When nutritional counseling and oral nutritional supplements are unsuccessful in outpatients | NR | NR
German Medical Science, 2009^5^ | Parenteral nutrition in patients with renal failure | 1) Middle pre-dialysis SA 3 months 2) Middle pre-dialysis serum creatinine 3 months 3) Weight loss >10% of ideal body weight or >20% of normal body weight (no time limit) 4) Clinical examination indicates moderate to severe malnutrition 4) Dietary history indicating protein intake <0.8 g/kg, reduced calorie intake <25 kcal/kg 5) SGA score C | Enteral nutrition and/or parenteral nutrition if state of renal failure requires more aggressive therapy – general recommendation to establish at least minimal enteral nutrition to enhance intestinal integrity even if parenteral is indicated | Malnourished AND: 1) Modifiable causes of malnutrition are excluded 2) enhanced oral or enteral supply is unsuccessful or cannot be carried out | NR | NR
International Society of Renal Nutrition and Metabolism, 2013^6^ | Consensus statement for the management of PEW Evidence, expert opinion | 1) Poor appetite and/or poor oral intake 2) DPI<1.2 (CKD 5D) or <0.7 (CKD 3-4); DEI < 30 kcal/kg/day 3) SA < 3.8 g/dL or PA < 28 mg/dL 4) Unintentional weight loss: > 5% of IBW or EDW over 3 months 5) Worsening nutritional markers over time 6) SGA in PEW range | CKD-specific oral nutritional supplementation | Beneficial for individuals who cannot tolerate oral or enteral administration of nutrients with SA< 3g/dL | | NR
National Kidney Foundation/Kidney Disease Outcomes Quality Initiative (KDOQI), 2000^7^ | Clinical practice guideline for nutrition in chronic renal failure | Use of a broad panel of nutritional status markers for diagnosing PEW malnutrition and wasting: BMI, SGA, handgrip strength, waist circumference, SA, serum creatinine | Nutrition counseling with individualized care plan, updated at least quarterly | Must exhibit the following: 1) Evidence of protein or energy malnutrition and 2) Inadequate DPI or DEI 3) Inability to administer or tolerate adequate oral nutrition, including food supplements or tube feeding Combine IDPN with oral or enteral supplement | | If combination of IDPN or Intraperitoneal Amino Acids does not meet protein and energy requirements, daily total or partial parenteral nutrition should be considered
Nottingham University Hospitals, 2016^8^ | Clinical practice guideline | Spontaneous nutrition intake is < 29kcal/kg/IBW and < 0.8g protein/kg of IBW | Enteral and oral routes (food fortification advice and the use of oral nutritional supplements) with intense dietetic support | Malnourished AND 1) Enteral feeding and oral routes have failed or are unsafe/not practical 2) Full dietetic assessment including risk of refeeding syndrome conducted by dietician | 1) Allergy to eggs, corn and sulphites 2) Palliative patient with no anticipated increase in QOL 3) Fluid overload (patient gains .4% dry weight) Uncontrolled diabetes (blood glucose above 20 mmol/l) 4) Receiving blood transfusion on the dialysis day 5) Deranged liver function tests 6) Septic patients and chronic infection (with elevated CRP) | NR
UK Renal Association, 2010^9^ | Clinical practice guideline for nutrition in chronic kidney disease | 1)BMI <18.5 kg/m^2^ 2) an unintentional weight loss >10% in 3-6 months 3) BMI <20 kg/m^2^ AND unintentional weight loss >5% in 3-6 months | ONS first, EN if nutrient intake is still suboptimal despite ONS | IDPN suggested for select cases when tube feeding is declined or clinically inappropriate | NR | NR

Abbreviations: DEI=dietary energy intake, DPI=dietary protein intake, EN=enteral nutrition, EDW=estimated dry weight. IBW=ideal body weight. IDPN=intradialytic parenteral nutrition, NA=not applicable, N.I.C.E.=National Institute of Clinical Excellence, NR=not reported, PEW=protein energy wasting, ONS=oral nutrition supplements, PN=parenteral nutrition, SA=serum albumin, SGA= subjective global assessment (Grade A: well-nourished, B: mild to moderately malnourished, C: severely malnourished), PA=pre-serum

## Appendix B IDPN Insurance Coverage

Agency Last Review Date | What’s covered? | Coverage details | Conditions for coverage
Aetna 2017 | IDPN | [underlined: No. 0061] Parenteral nutrition may be either “self-mixed” (ie, the member or family caregiver is taught to prepare the nutrient solution aseptically) or “premixed”. The doctor must justify the need for pre-mixed parenteral nutritional solutions. | ANY of the following criteria:; - Documentation of a failure of enteral (ie, oral or tube feeding) nutrition, as defined by either of the following:; - o A non-edematous or post-dialysis documented loss of greater than 10 % of body weight over a 3-month period; or; - o Total protein less then 6 g/dL or serum albumin less than 3.4 g/dL;; - A condition in which it is necessary for the gastrointestinal tract to be totally non-functioning for a period of time;; - Evidence of structural or functional bowel disease that makes oral and tube feedings inappropriate;; - Hyperemesis gravidarum (only in cases of failed medical management or when used in a step-therapy program);; - Member is peri-operative (regardless of disease state) and unable to tolerate oral or tube feedings.; Parenteral nutrition is not considered medically necessary for members with a functioning gastrointestinal tract whose need for parenteral nutrition is only due to:; - A physical disorder impairing food intake such as the dyspnea of severe pulmonary or cardiac disease;; - A psychological disorder impairing food intake such as depression;; - A side effect of a medication;; - A swallowing disorder;; - A temporary defect in gastric emptying such as a metabolic or electrolyte disorder;; - Disorders inducing anorexia such as cancer;; - Renal failure and/or dialysis*; *Members receiving intra-dialytic parenteral nutrition must meet the criteria for total parenteral nutrition set forth above.
Blue Cross of Idaho 2014 | IDPN | [underlined: MP 8.01.44] | Considered medically necessary when it is offered as an alternative to a regularly scheduled regimen of total parenteral nutrition only in patients who would be considered candidates for total parenteral nutrition (TPN)(/e, a severe pathology of the alimentary tract that does not allow absorption of sufficient nutrients to maintain weight and strength commensurate with the patient’s general condition). Considered not medically necessary in patients who would be considered a candidate for TPN, but for whom the intradialytic parenteral nutrition is not offered as an alternative to TPN, but in addition to regularly scheduled infusions to TPN. Considered investigational in patients who would not otherwise be considered candidates for TPN.
Centers for Medicare and Medicaid Services (CMS) 2015 | IDPN (solution only) | [underlined: NCD Publication No. 100-3 Manual Section No. 180.2] [underlined: PRM-1-2711.6] [underlined: 42 CFR 423.100] [underlined: B3-2130. A3-3110.4. HO-228.4. A3-3111. HO-229] Covered under Part B if the therapy was being provided because of a non-functioning digestive tract. Otherwise it is covered under Part D. | Medication given by injection (parenterally) is not covered if standard medical practice indicates that the administration of the medication by mouth (orally) is effective and is an accepted or preferred method of administration. Physician’s written order or prescription and sufficient medical documentation to permit an independent conclusion that the requirements of the benefit are met and that parenteral nutrition therapy is medically necessary. Coverage of parenteral nutrition therapy for this and any other condition must be approved on an individual, case-by-case basis initially and at periodic intervals of no more than three months by the Medicare Administrative Contractor (A/B MAC (B)) medical consultant or specially trained staff, relying on such medical and other documentation as the A/B MAC (B) may require.
Cigna 2017 | IDPN | [underlined: Medical Coveraae Policv: 0136] | The individual is on chronic hemodialysis AND the individual is a candidate for total parenteral nutrition (ie, nutritional status cannot be adequately maintained on oral or enteral feedings).
Priority Health 2016 | IDPN | [underlined: Medical Policv No. 91517-R4] Clinical re-evaluation after 6 months for consideration of continued treatment | SA < 3.4 g/dL or protein < 6 g/dL AND one of the following:; - BMI < 18.5 kg/m^2^; - Unintentional weight loss > 10% within the last 6 months; - BMI < 20 kg/m^2^ and unintentional weight loss > 5% within the last 3-6 months
United Healthcare 2017 | IDPN, infusion pumps, supply kit, administration kit | [underlined: Policy Number: N-001] Covered in accordance with Medicare coverage criteria. | Documentation must be clear and precise to verify that the patient suffers from a permanently impaired gastrointestinal tract and that there is insufficient absorption of nutrients to maintain adequate strength and weight. Records should document that the patient cannot be maintained on oral or enteral feedings and that due to severe pathology of the alimentary tract, the patient must be intravenously infused with nutrients. Infusions must be vital to the nutritional stability of the patient and not supplemental to a deficient diet or deficiencies caused by dialysis. Physical signs, symptoms and test results indicating severe pathology of the alimentary tract must be clearly evident in any documentation submitted.
Health Net/ Ceritene Corporation 2017 | IDPN | [underlined: CP.PHAR.205] Initial approval duration for IDPN is for 3 months. Continued approval duration is 6 months, given that the member has no evidence of unacceptable complications from treatment and documentation supports positive response to therapy. | Documented failure of enteral nutrition as shown by ANY of the following:; - Weight loss > 10% of ideal body weight in 3 months or > 20% of usual body weight; - Total protein < 6 g/dL in past 4 weeks; - SA < 3.4 g/dL in past 4 weeks; AND evidence of structural or functional bowel disease that makes oral or tube feedings inappropriate, or a condition in which the gastrointestinal tract is non-functioning for a period of time AND; - Patient has ESRD; - Patient is undergoing hemodialysis; - IDPN is offered as an alternative to regularly scheduled TPN.
Independence Blue Cross 2017 | IDPN | [underlined: Policy No. 08.00.17q] After an initial 3-month trial, continued coverage will depend on the degree of improvement in nutritional status, taking into consideration the individual’s serum albumin levels. | When it is infused as an alternative to a regularly scheduled regimen of TPN in individuals who meet the medical necessity criteria for TPN, OR In individuals with a functional gastrointestinal tract when all of the following criteria are met:; - The individual has a documented comprehensive nutritional assessment and dietary counseling; - In spite of enteral nutrition via tube feeding, or adequate oral nutrition, the individual has evidence of protein or energy malnutrition as defined by any of the following:; - o Evidence of protein intake <1.2g/Kg or calories<25 Kcal/Kg; - o Evidence of weight loss 10-20% of usual body weight within 3-6 months; - o Serum Albumin Levels <3.4 g/l (3 months average); - The individual has evidence of adequate dialysis therapy

Abbreviations: BMI=body mass index, ESRD=end stage renal disease, IDPN=intradialytic parenteral nutrition, TPN=total parenteral nutrition

## Appendix C Search Strategy

1. Search for current systematic reviews Date Searched: 10/11/17

Source: | Evidence:
[underlined: AHRQ] | Search: Hemodialysis; Haemodialysis; Parenteral Nutrition Relevant Results: None
[underlined: CADTH] | Search: Hemodialysis; Haemodialysis; Parenteral Nutrition Relevant Results: None
[underlined: NHS Evidence] (NICE) | Search: Hemodialysis and nutrition; Hemodialysis and oral supplement; haemodialysis and nutrition; haemodialysis and oral supplement; Hemodialysis and Parenteral Nutrition; Haemodialysis and Parenteral Nutrition Relevant Results: UK Renal Association. “[underlined: Nutrition in CKD 5^th^ Edition]” (2010)
[underlined: National Library of Medicine] | Search: Hemodialysis and nutrition; Hemodialysis and oral supplement; haemodialysis and nutrition; haemodialysis and oral supplement; Hemodialysis and Parenteral Nutrition; Haemodialysis and Parenteral Nutrition Relevant Results: None
[underlined: ECRI Institute] | Search: Hemodialysis; Hemodialysis Relevant Results: None
Cochrane Database of Systematic Reviews (CDSR) | Database: EBM Reviews - Cochrane Database of Systematic Reviews <2005 to October 5, 2017> Search Strategy: ------------------ 1 (hemodialysis or haemodialysis).mp. [mp=title, abstract, full text, keywords, caption text] (201) 2 (hemodiafiltration or haemodiafiltration).mp. [mp=title, abstract, full text, keywords, caption text] (24) 3 (hemofiltration or haemofiltration).mp. [mp=title, abstract, full text, keywords, caption text] (33) 4 1 or 2 or 3 (211) 5 malnutrition.mp. [mp=title, abstract, full text, keywords, caption text] (294) 6 nutritional supplementation.mp. [mp=title, abstract, full text, keywords, caption text] (65) 7 Nutritional Status.mp. [mp=title, abstract, full text, keywords, caption text] (256) 8 oral nutrition*.mp. [mp=title, abstract, full text, keywords, caption text] (37) 9 Enteral nutrition*.mp. [mp=title, abstract, full text, keywords, caption text] (141) 10 parenteral nutrition*.mp. [mp=title, abstract, full text, keywords, caption text] (207) 11 5 or 6 or 7 or 8 or 9 or 10 (665) 12 4 and 11 (38) ***************************
MEDLINE: Systematic Reviews | Database: Ovid MEDLINE(R) <1946 to September Week 4 2017>, Ovid MEDLINE(R) In-Process & Other Non-lndexed Citations cOctober 10, 2017> Search Strategy: ----------------- 1 (hemodialysis or haemodialysis).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier, synonyms] (72847) 2 (hemodiafiltration or haemodiafiltration).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier, synonyms] (3362) 3 (hemofiltration or haemofiltration).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier, synonyms] (6721) 4 exp Renal Dialysis/ (108964) 5 1 or 2 or 3 or 4 (131024) 6 exp Protein-Energy Malnutrition/ (7509) 7 malnutrition.mp. or exp Malnutrition/ (140928) 8 exp Nutritional Support/ (45694) 9 nutritional supplementation.mp, (1796) 10 Nutritional Status.mp. or exp Nutritional Status/ (55534) 11 oral nutrition*.mp. (1266) 12 exp Enteral Nutrition/or Enteral nutrition*.mp. (22351) 13 exp Parenteral Nutrition, Total/ or exp Parenteral Nutrition/ or parenteral nutrition*.mp. (32162) 14 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 (230196) 15 5 and 14 (6749) 16 11 or 12 or 13 (49606) 17 15 and 16 (818) 18 11 and 13 and 15 (23) 19 meta-analysis.pt. (91059) 20 meta-analysis/ or systematic review/ or meta-analysis as topic/ or “meta analysis (topic)”/ or “systematic review (topic)”/ or exp technology assessment, biomedical/ (117580) 21 ((systematic* adj3 (review* or overview*)) or (méthodologie* adj3 (review* or overview*))).ti,ab. (125288) 22 ((quantitative adj3 (review* or overview* or synthes*)) or (research adj3 (integrati* or overview*))).ti,ab. (8406) 23 ((integrative adj3 (review* or overview*)) or (collaborative adj3 (review* or overview*)) or (pool* adj3 anaiy*)).ti,ab. (19859) 24 (data synthes* or data extraction* or data abstraction*).ti,ab. (20899) 25 (handsearch* or hand search*).ti,ab. (7967) 26 (mantel haenszel or peto or der simonian or dersimonian or fixed effect* or latin square*).ti,ab. (21439) 27 (meta-analy* or metaanaly* or systematic review* or biomedical technology assessment* or bio-medical technology assessment*).mp,hw, (217048) 28 (meta regression* or metaregression*),ti,ab. (5902) 29 (meta-analy* or metaanaly* or systematic review* or biomedical technology assessment* or bio-medical technology assessment*).mp,hw, (217048) 30 (medline or cochrane or pubmed or medlars or embase or cinahl).ti,ab,hw. (160185) 31 (cochrane or (health adj2 technology assessment) or evidence report).jw. (18591) 32 (meta-analysis or systematic review).ti.ab. (169828) 33 (comparative adj3 (efficacy or effectiveness)).ti,ab. (10451) 34 (outcomes research or relative effectiveness).ti,ab. (6770) 35 ((indirect or indirect treatment or mixed-treatment) adj comparison*).ti,ab. (1644) 36 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 (353175) 37 17 and 36 (14) ***************************
VA Products - VATAP, PBM and HSR&D publications, VA ART database (Captures HSR&D funded projects) | A. http://www.hsrd.research.va.aov/research/default.cfm Search: Hemodialysis; Haemodiaiysis Relevant Results: Hynes DM, Stroupe KT, Fischer MJ, Reda DJ, Manning W, Browning MM, Huo Z, Saban K, Kaufman JS, for ESRD Cost Study Group. Comparing VA and private sector healthcare costs for end-stage renal disease. Medical care. 2012 Feb 1; 50(2): 161 -70. B. http://www.research.va.aov/researchtopics/ Relevant Results: None C. http://art.Duaet-sound.med.va.aov/default.cfm Search: Hemodialysis; Haemodiaiysis; haemodiaiysis and nutrition; haemodiaiysis and oral supplement Relevant Results: None

2. Search for systematic reviews currently under development (includes forthcoming reviews & protocols) Date Searched: 10/11/17

Source: | Evidence:
AHRQ topics in development (EPC Status Report) | https://www.eDc-src.ora/src/loaon.cfm Emailed Robin.Pavnter@va.aov and she reported no future, onaoina, or completed AHRQ Effective Health Care program reviews on this topic.
PROSPERO (SR registry) | http://www.crd.vork.ac.uk/PROSPERO/ Search: Hemodialysis; haemodialysis Relevant Results: Rana Rizk, Silvia Evers, Mickael Hiligsmann, Mirey Karavetian. Economic evaluations of interventions to manage hyperphosphatemia in adult hemodialysis patients: a systematic review. PROSPERO 2014:CRD42014014631 Available from http://www.crd.york.ac.uk/PROSPERO/display_record.php?ID=CRD42014014631
DoPHER (SR Protocols) | http://eppi.ioe.ac.uk/webdatabases4/Intro.aspx?ID=9 Search: Hemodialysis; haemodialysis Relevant Results: None
Cochrane Methodology Register | Database: EBM Reviews - Cochrane Methodology Register <3rd Quarter 2012> Search Strategy: ---------------- 1 (hemodialysis or haemodialysis).mp. [mp—title, abstract, subject heading word] (12) 2 (hémodiafiltration or haemodiafiitration),mp. [mp=title, abstract, subject heading word] (0) 3 (hemofiltration or haemofiltration).mp. [mp=title, abstract, subject heading word] (0) 4 1 or 2 or 3 (12) 5 malnutrition.mp. [mp=title, abstract, subject heading word] (3) 6 nutritional supplementation.mp. [mp=title, abstract, subject heading word] (4) 7 Nutritional Status.mp. [mp=title, abstract, subject heading word] (1) 8 oral nutrition*.mp. [mp=title, abstract, subject heading word] (1) 9 Enteral nutrition*.mp. [mp=title, abstract, subject heading word] (2) 10 parenteral nutrition*.mp. [mp=title, abstract, subject heading word] (3) 11 5 or 6 or 7 or 8 or 9 or 10 (11) 12 4 and 11(0) ***************************

3. Current Guidelines Date Searched: 9/11/17

Source: | Evidence:
[underlined: National Guideline Clearinahouse] | Search: Hemodialysis; haemodialysis Relevant Results: McClave, Stephen A., et al. “[underlined: Guidelines for the provision and assessment of nutrition suooort theraDV in the adult critically ill patient: Society of Critical Care Medicine (SCCM) and American Society for Parenteral and Enteral Nutrition (ASPEN).]” Journal of Parenteral and Enteral Nutrition 40.2 (2016): 159-211.
[underlined: VA/DOD Clinical Practice Guidelines] | Relevant Results: The Management of Chronic Kidney Disease Working Group (2014). “VA/DoD clinical practice guideline for the management of chronic kidney disease in primary care.”
[underlined: The Renal Association] | Relevant Results: None
[underlined: Gooale Scholar] | Search: IDPN guideline; intradialytic parenteral nutrition guideline; Hemodialysis and parenteral nutrition; Haemodialysis and parenteral nutrition Relevant Results: Cano, N. J., et al. (2007). “Intradialytic parenteral nutrition does not improve survival in malnourished hemodialysis patients: a 2-year multicenter, prospective, randomized study.” [underlined: J Am Soc Nephrol] 18(9):2583-2591. Carrero, J. J., et ai. (2013). “Etiology of the protein-energy wasting syndrome in chronic kidney disease: a consensus statement from the International Society of Renal Nutrition and Metabolism (ISRNM).” J Ren Nutr 23(2): 77-90. Corbello, Jesse, and Mitchell H. Rosner. “Intradialytic total parenteral nutrition (IDPN): evidence-based recommendations.” Practical gastroenterology (2009): 13. Cranford, W. “Cost effectiveness of IDPN therapy measured by hospitalizations and length of stay.” Nephrology news & issues12.9 (1998): 33-5.
[underlined: Google] | Search: IDPN guideline; intradialytic parenteral nutrition guideline; Hemodialysis and parenteral nutrition; Haemodialysis and parenteral nutrition Relevant Results: Brown RO, Compher C, Parenteral ASf, Directors ENBo. ASPEN clinical guidelines: nutrition support in adult acute and chronic renal failure. Journal of Parenteral and Enteral Nutrition. 2010;34(4):366-377. Department of Veterans Affairs. VHA Handbook 1109.05: Nutrition Therapy. In: Administration VH, ed. Washington D.C.: Department of Veterans Affairs; 2013. Nottingham University Hospitals, Mafrici B. Guideline for the use and administration of intradialytic parenteral nutrition (IDPN) in adult haemodialysis patients. In: Hospitals NU, ed: Nottingham University; 2016. The National Kidney Foundation Kidney Disease Outcomes Quality Initiative (NKF KDOQI). KDOQI Clinical Practice Guidelines for Nutrition in Chronic Renal Failure Guideline 19: Indications for Nutritional Support. In:2000. Worthington P, Balint J, Bechtold M, et al. When Is Parenteral Nutrition Appropriate? Journal of Parenteral and Enteral Nutrition. 2017;41(3):324-377.

4. Search for current primary literature (limited to 2009 forward) Date Searched: 10/11/17

Source: | Evidence:
MEDLINE | Database: Ovid MEDLINE(R) <1946 to September Week 4 2017>. Ovid MEDLINE(R) In-Process & Other Non-lndexed Citations cOctober 10, 2017> Search Strategy: ---------------------------------------------------------------- 1 (hemodialysis or haemodialysis).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier, synonyms] (72847) 2 (hemodiafiltration or haemodiafiltration).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier, synonyms] (3362) 3 (hemofiltration or haemofiltration).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier, synonyms] (6721) 4 exp Renal Dialysis/ (108964) 5 1 or 2 or 3 or 4 (131024) 6 exp Protein-Energy Malnutrition/ (7509) 7 malnutrition,mp. or exp Malnutrition/ (140928) 8 exp Nutritional Support/ (45694) 9 nutritional supplementation.mp. (1796) 10 Nutritional Status.mp. or exp Nutritional Status/ (55534) 11 oral nutrition*.mp. (1266) 12 exp Enteral Nutrition/or Enteral nutrition*.mp. (22351) 13 exp Parenteral Nutrition, Total/ or exp Parenteral Nutrition/ or parenteral nutrition*.mp. (32162) 14 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 (230196) 15 5 and 14 (6749) 16 11 or 12 or 13 (49606) 17 15 and 16 (818) 18 limit 17 to yr=“2009 -Current” (188) 19 limit 18 to humans (167) 20 limit 19 to english language (144) 21 remove duplicates from 20 (131) ***************************
CCRCT | Database: EBM Reviews - Cochrane Central Register of Controlled Trials <September 2017> Search Strategy: ----------------------------------------------------- 1 (hemodialysis or haemodialysis).mp. [mp=titie, original title, abstract, mesh headings, heading words, keyword] (7053) 2 (hemodiafiltration or haemodiafiltration).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (463) 3 (hemofiltration or haemofiltration).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (651) 4 exp Renal Dialysis/ (4567) 5 1 or 2 or 3 or 4 (8873) 6 exp Protein-Energy Malnutrition/ (235) 7 malnutrition.mp. or exp Malnutrition/ (3945) 8 exp Nutritional Support/ (2945) 9 nutritional supplementation.mp. (540) 10 Nutritional Status.mp. or exp Nutritional Status/ (3955) 11 oral nutrition*.mp. (389) 12 exp Enteral Nutrition/or Enteral nutrition*.mp. (3155) 13 exp Parenteral Nutrition, Total/ or exp Parenteral Nutrition/ or parenteral nutrition*.mp. (2987) 14 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 (12223) 15 5 and 14 (538) 16 11 or 12 or 13 (5747) 17 15 and 16 (65) 18 limit 17 to yr=“2009 -Current” (24) 19 limit 18 to humans [Limit not valid; records were retained] (24) 20 limit 19 to english language (21) 21 remove duplicates from 20 (20) ***************************
CINAHL | Database: EBSCOhost CINAHL Pius with Full Text Search Strategy: ---------------------------------------------------------------- 1 (MH “Hemodialysis+”) OR “hemodialysis or haemodialysis” (12152) 2 (MH “Hemodiafiltration”) OR “hemodiafiltration or haemodiafiltration” (258) 3 hemofiltration or haemofiltration (932) 4 (MH “Dialysis Patients”) OR “Renal Dialysis” (3800) 5 1 or 2 or 3 or 4 (15223) 6 (MH “Protein-Energy Malnutrition+”) (837) 7 (MH “Malnutrition”) OR “Malnutrition” (10550) 8 (MH “Nutritional Support+”) OR “Nutritional Support” (27967) 9 nutritional supplementation (544) 10 (MH “Nutritional Status”) OR “Nutritional Status” (13633) 11 “oral nutrition*” (513) 12 (MH “Enteral Nutrition”) OR “Enteral nutrition*” (8129) 13 (MH “Parenteral Nutrition+”) OR (MH “Peripheral Parenteral Nutrition”) OR “parenteral nutrition*” OR (MH “Intradialytic Parenteral Nutrition”) (6596) 14 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 (48508) 15 5 and 14 (776) 16 11 or 12 or 13 (13387) 17 15 and 16 (130) 18 limit 17 to yr=“2009 -Current” (55) ***************************

5. Search for ongoing primary research Date Searched : 10/11/17

Source: | Evidence:
Clinicaltrials.gov | Search: Hemodialysis and nutrition; Haemodialysis and nutrition; hemodialysis AND parenteral; haemodialysis AND parenteral Results: Lacson, Eduardo, et al. “Potential impact of nutritional intervention on end-stage renal disease hospitalization, death, and treatment costs.” Journal of Renal Nutrition 17.6 (2007): 363-371. Marsen, Tobias A., et al. “Intradialytic parenteral nutrition in maintenance hemodialysis patients suffering from protein-energy wasting. Results of a multicenter, open, prospective, randomized trial.” Clinical Nutrition (2015). Effects of Nutritional Supplementation on Protein and Energy Homeostasis in Malnourished Chronic Hemodialvsis Patients. [underlined: NCT00244075]. (Comoleted, no results)
[underlined: HSRProi] (Health Services Research Projects in Progress) | Search: Hemodialysis; Haemodialysis Results: None

## Appendix D List of Excluded Studies

Exclude reasons: B=Relevant for background information only, 1=Ineligible population, 2=Ineligible intervention, 3=Ineligible comparator, 4=Ineligible outcome, 5=Ineligible timing, 6=Ineligible study design, 7=Ineligible publication type 8=Outdated or ineligible systematic review, 9=non-English language, 10=Full text not available

# | Citation | Exclude reason
1. | Intradialytic Parenteral Nutrition (IDPN) for End-Stage Renal Disease in Adults. Hayes Brief. 2008. | B
2. | Intradialytic Parenteral Nutrition (IDPN) for End-Stage Renal Disease in Adults. Hayes Annual Review. 2010. | B
3. | Intradialytic Parenteral Nutrition for End-Stage Renal Disease in Adults. Hayes Search & Summary. 2017. | B
4. | Ash S, Campbell KL, Bogard J, Millichamp A. Nutrition prescription to achieve positive outcomes in chronic kidney disease: a systematic review. Nutrients. 2014;6(1):416-451. | B
5. | Avery-Lynch M. Intradialytic parenteral nutrition in hemodialysis patients: Acute and chronic intervention. CANNT journal = Journal ACITN. 2006;16(2):30-33. | E6
6. | Baltz PS, Shuster M. Intradialytic parenteral nutrition as a therapy for malnourished hemodialysis patients. ANNA journal. 1992;19(1):72-73. | E6
7. | Basic-Jukic N, Racki S, Kes P, et al. [How to prevent protein-energy wasting in patients with chronic kidney disease--position statement of the Croatian Society of Nephrology, Dialysis and Transplantation]. Acta Medica Croatica. 2014;68(2):191-199. | E9
8. | Basic-Jukic N, Radic J, Klaric D, et al. [Croatian guidelines for screening, prevention and treatment of protein-energy wasting in chronic kidney disease patients]. Lijecnicki Vjesnik. 2015;137(1-2):1-8. | E9
9. | Berneis K, Iseli-Schaub J, Garbani E, Meier R, Kiss D. Effects of intradialytic parenteral nutrition in chronic haemodialysis patients with malnutrition: a pilot study. Wiener klinische Wochenschrift. 1999;111(21):876-881. | E6
10. | Bilbrey G. Is intradialytic parenteral nutrition of benefit in hemodialysis patients? Semin Dialysis. 1993;6:168-170. | E6
11. | Bilbrey G, Cohen T. Identification and treatment of protein calorie malnutrition in chronic hemodialysis patients. Dialysis & transplantation. 1989;18(12):669-700. | E6
12. | Bossola M, Giungi S, Luciani G, Tazza L. Interventions to counteract anorexia in dialysis patients. Journal of Renal Nutrition. 2011;21(1):16-19. | E7
13. | Bossola M, Tazza L, Giungi S, Rosa F, Luciani G. Artificial nutritional support in chronic hemodialysis patients: a narrative review. Journal of Renal Nutrition. 2010;20(4):213-223. | B
14. | Bossola M, Tazza L, Vulpio C, et al. [Malnutrition in patients on chronic hemodialysis: prevalence, pathogenesis, and treatment]. Giornale Italiano di Nefrologia. 2009;26(2):201-214. | E9
15. | Bozzoli L, Sabatino A, Regolisti G, et al. [Protein-energy wasting and nutritional supplementation in chronic hemodialysis]. Giornale Italiano di Nefrologia. 2015;32(5):Sep-Oct. | E9
16. | Brown RO, Compher C, Parenteral ASf, Directors ENBo. ASPEN clinical guidelines: nutrition support in adult acute and chronic renal failure. Journal of Parenteral and Enteral Nutrition. 2010;34(4):366-377. | G
17. | CADTH. Guidelines for Renal Care and Dialysis for Adults with Renal Disease. 2007. | E7
18. | Cano NJ, Aparicio M, Brunori G, et al. ESPEN Guidelines on Parenteral Nutrition: adult renal failure. Clinical Nutrition. 2009;28(4):401-414. | G
19. | Cano NJ, Saingra Y, Dupuy AM, et al. Intradialytic parenteral nutrition: comparison of olive oil versus soybean oil-based lipid emulsions. The British journal of nutrition. 2006;95(1):152-159. | E3
20. | Carrero JJ, Stenvinkel P, Cuppari L, et al. Etiology of the protein-energy wasting syndrome in chronic kidney disease: a consensus statement from the International Society of Renal Nutrition and Metabolism (ISRNM). J Ren Nutr. 2013;23(2):77-90. | B
21. | Cheenam B, Leena P. Dietary intervention and protein supplementation in chronic kidney disease patients undergoing hemodialysis. Asian Journal of Pharmaceutical and Clinical Research. 2015;8(4):230-232. | E2
22. | Cherry N, Shalansky K. Efficacy of intradialytic parenteral nutrition in malnourished hemodialysis patients. American journal of health-system pharmacy : AJHP : official journal of the American Society of Health-System Pharmacists. 2002;59(18):1736-1741. | E6
23. | Cheu C, Pearson J, Dahlerus C, et al. Association between oral nutritional supplementation and clinical outcomes among patients with ESRD. Clinical Journal of The American Society of Nephrology: CJASN. 2013;8(1):100-107. | E2
24. | Corbello J, Rosner MH. Intradialytic total parenteral nutrition (IDPN): evidence-based recommendations. Practical gastroenterology. 2009:13. | B
25. | Czekalski S, Hozejowski R. Intradialytic amino acids supplementation in hemodialysis patients with malnutrition: results of a multicenter cohort study. J Ren Nutr. 2004;14(2):82-88. | E6
26. | Dahlan R, Biyani M, McCormick BB. High mortality following gastrostomy tube insertion in adult peritoneal dialysis patients: case report and literature review. Endoscopy. 2013;45 Suppl 2 UCTN:E313-314. | E1
27. | Department of Veterans Affairs. VHA Handbook 1109.05: Nutrition Therapy. In: Administration VH, ed. Washington D.C.: Department of Veterans Affairs; 2013. | G
28. | Dezfuli A, Scholl D, Lindenfeld SM, et al. Severity of hypoalbuminemia predicts response to intradialytic parenteral nutrition in hemodialysis patients. Journal of Renal Nutrition. 2009;19(4):291-297. | E6
29. | Downs J. Nutritional management of acute kidney injury in the critically ill: a focus on enteral feeding. South African Journal of Clinical Nutrition. 2014;27(4):187-193. | E7
30. | Druml W, Kierdorf HP, Working group for developing the guidelines for parenteral nutrition of The German Association for Nutritional M. Parenteral nutrition in patients with renal failure - Guidelines on Parenteral Nutrition, Chapter 17. German Medical Science. 2009;7:Doc11. | G
31. | Dukkipati R, Kalantar-Zadeh K, Kopple JD. Is there a role for intradialytic parenteral nutrition? A review of the evidence. American Journal of Kidney Diseases. 2010;55(2):352-364. | E7
32. | Fausz C, Sostaric B. Diabetic ESRD patient supported with intradialytic parenteral nutrition. ANNA journal. 1992;19(5):485-486. | E6
33. | Fernandez-Reyes MJ, Sanchez R, Garcia L, et al. Acute responses of gastrointestinal hormones to both oral and parenteral intradialytic nutrition. American Journal of Nephrology. 2010;32(3):272-278. | E4
34. | Fleet M, Osman F, Komaragiri R, Fritz A. Protein catabolism in advanced renal disease: role of cytokines. Clinical Nephrology. 2008;70(2):91-100. | E4
35 | Fuhrman MP. Intradialytic parenteral nutrition and intraperitoneal nutrition. Nutrition in Clinical Practice. 2009;24(4):470-480. | E7
36. | Foulks CJ. The effect of intradialytic parenteral nutrition on hospitalization rate and mortality in malnourished hemodialysis patients. Journal of Renal Nutrition. 1994;4(1):5-10. | E6
37. | Fuhrman T, Parker M. Intradialytic Parenteral Nutrition. Support Line. 2015;37(1):3-7. | B
38. | Garcia de Lorenzo A, Arrieta J, Ayucar A, et al. [Intra-dialysis parenteral nutrition in chronic renal patients: consensus SEN-SENPE]. Nutricion Hospitalaria. 2010;25(3):375-377. | E9
39. | Grzegorzewska AE. The role of nutritional status in the outcome of peritoneal dialysis patients. Panminerva Medica. 2009;51(3):163-173. | E7
40. | Guarnieri G, Faccini L, Lipartiti T, et al. Simple methods for nutritional assessment in hemodialyzed patients. The American journal of clinical nutrition. 1980;33(7):1598-1607. | B
41. | Hecking E, Port FK, Brehm H, et al. A controlled study on the value of oral supplementation with essential amino acids and keto analogues in chronic hemodialysis. Proceedings of the Clinical Dialysis and Transplant Forum. 1977;7:157-161. | E2
42. | Heidland A, Kult J. Long-term effects of essential amino acids supplementation in patients on regular dialysis treatment. Clin Nephrol. 1975;3(6):234-239. | E3
43. | Hynes DM, Stroupe KT, Fischer MJ, et al. Comparing VA and private sector healthcare costs for end-stage renal disease. Medical care. 2012;50(2):161-170. | B
44. | Ikizler TA. Nutrition support for the chronically wasted or acutely catabolic chronic kidney disease patient. Seminars in Nephrology. 2009;29(1):75-84. | B
45. | Ikizler TA. A patient with CKD and poor nutritional status. Clinical Journal of The American Society of Nephrology: CJASN. 2013;8(12):2174-2182. | B
46. | Ikizler TA. Optimal nutrition in hemodialysis patients. Advances in Chronic Kidney Disease. 2013;20(2):181-189. | E6
47. | Ikizler TA, Cano NJ, Franch H, et al. Prevention and treatment of protein energy wasting in chronic kidney disease patients: a consensus statement by the International Society of Renal Nutrition and Metabolism. Kidney International. 2013;84(6):1096-1107. | G
48. | Ikizler TA, Wingard RL, Hakim RM. Interventions to treat malnutrition in dialysis patients: the role of the dose of dialysis, intradialytic parenteral nutrition, and growth hormone. American journal of kidney diseases : the official journal of the National Kidney Foundation. 1995;26(1):256-265. | E7
49. | Jones SA, Bushman M, Cohen R. Intradialytic parenteral nutrition after small bowel resection. Nutrition in clinical practice : official publication of the American Society for Parenteral and Enteral Nutrition. 1996;11(1):12-15. | E6
50. | Juillard L, Guebre-Egziabher F, Fouque D. [What is the benefit of the new European nutritional guidelines for dialysis?]. Nephrologie et Therapeutique. 2010;6 Suppl 1 :S2-6. | E9
51. | Kalantar-Zadeh K, Ikizler TA. Let them eat during dialysis: an overlooked opportunity to improve outcomes in maintenance hemodialysis patients. Journal of Renal Nutrition. 2013;23(3):157-163. | E7
52. | Kalim S, Ortiz G, Trottier CA, et al. The Effects of Parenteral Amino Acid Therapy on Protein Carbamylation in Maintenance Hemodialysis Patients. Journal of Renal Nutrition. 2015;25(4):388-392. | E2
53. | Kallen AJ, Patel PR, O'Grady NP. Preventing catheter-related bloodstream infections outside the intensive care unit: expanding prevention to new settings. Clinical Infectious Diseases. 2010;51(3):335-341. | E2
54. | Kistler BM, Fitschen PJ, Ikizler TA, Wilund KR. Rethinking the restriction on nutrition during hemodialysis treatment. Journal of Renal Nutrition. 2015;25(2):81-87. | E7
55. | Koppe L, Fouque D. Nutrition: Intradialytic oral nutrition--the ultimate conviction. Nature Reviews Nephrology. 2014;10(1):11-12. | E7
56. | Kopple JD. Therapeutic approaches to malnutrition in chronic dialysis patients: the different modalities of nutritional support. American journal of kidney diseases : the official journal of the National Kidney Foundation. 1999;33(1):180-185. | E7
57. | Korzets A, Azoulay O, Ori Y, et al. The use of intradialytic parenteral nutrition in acutely ill haemodialysed patients. Journal of renal care. 2008;34(1):14-18. | E6
58. | Kriel J, Esau N. Nutritional management of encapsulating peritoneal sclerosis with intradialytic parenteral nutrition. South African Journal of Clinical Nutrition. 2014;27(1):38-43. | E6
59. | Lacson E, Jr., Ikizler TA, Lazarus JM, Teng M, Hakim RM. Potential impact of nutritional intervention on end-stage renal disease hospitalization, death, and treatment costs. J Ren Nutr. 2007;17(6):363-371. | B
60. | Lacson E, Jr., Wang W, Zebrowski B, Wingard R, Hakim RM. Outcomes associated with intradialytic oral nutritional supplements in patients undergoing maintenance hemodialysis: a quality improvement report. American Journal of Kidney Diseases. 2012;60(4):591-600. | E2
61. | Lau MT. Parenteral nutrition in the malnourished: dialysis, cancer, obese, and hyperemesis gravidarum patients. Journal of Infusion Nursing. 2011;34(5):315-318. | B
62. | Madigan KM, Olshan A, Yingling DJ. Effectiveness of intradialytic parenteral nutrition in diabetic patients with end-stage renal disease. J Am Diet Assoc. 1990;90(6):861-863. | E6
63. | McCann L, Feldman C, Hornberger J, et al. Effect of intradialytic parenteral nutrition on delivered Kt/V. American journal of kidney diseases : the official journal of the National Kidney Foundation. 1999;33(6):1131-1135. | E4
64. | McKnight K, Farmer A, Zuberbuhler L, Mager D. Identification and treatment of protein-energy malnutrition in renal disease. Canadian Journal of Dietetic Practice & Research. 2010;71(1):27-32. | E6
65. | Moore L, Acchiardo S. Aggressive nutritional supplementation in chronic hemodialysis patients. CRN Q. 1987;11:13-14. | E11
66. | Mortelmans AK, Duym P, Vandenbroucke J, et al. Intradialytic parenteral nutrition in malnourished hemodialysis patients: a prospective long-term study. JPEN Journal of parenteral and enteral nutrition. 1999;23(2):90-95. | E6
67. | Mpio I, Cleaud C, Arkouche W, Laville M. [Results of therapeutics strategy of protein-energy wasting in chronic hemodialysis: a prospective study during 12 months]. Nephrologie et Therapeutique. 2015;11 (2):97-103. | E9
68. | Muscaritoli M, Molfino A, Bollea MR, Rossi Fanelli F. Malnutrition and wasting in renal disease. Current Opinion in Clinical Nutrition & Metabolic Care. 2009;12(4):378-383. | E7
69. | Navarro JF, Mora C, Leon C, et al. Amino acid losses during hemodialysis with polyacrylonitrile membranes: effect of intradialytic amino acid supplementation on plasma amino acid concentrations and nutritional variables in nondiabetic patients. The American journal of clinical nutrition. 2000;71(3):765-773. | E4
70. | Noè D, Lanzi P, Spiti R, et al. Effects of intradialytic parenteral nutrition on the nutritional status of malnourished uremic patients. Nutritional Therapy & Metabolism. 2013;31(4):176-181. | E6
71. | Norton PA. Affect of serum leptin on nutritional status in renal disease. Journal of the American Dietetic Association. 2002;102(8):1119-1125. | E7
72. | Nottingham University Hospitals, Mafrici B. Guideline for the use and administration of intradialytic parenteral nutrition (IDPN) in adult haemodialysis patients. In: Hospitals NU, ed: Nottingham University; 2016. | G
73. | Olshan A, Bruce J, Schwartz A. INTRADIALYTIC PARENTERAL-NUTRITION ADMINISTRATION DURING OUTPATIENT HEMODIALYSIS. Dialysis & Transplantation. 1987;16(9):495-496. | E6
74. | Phillips S. Intra-Dialytic Parenteral Nutrition Elcacy and Albumin: A Review of the Literature. Renal Nutrition Forum. 2013;32(3):1-7. | B
75. | Pillai U, Kahlon R, Sondheimer J, Cadnapaphorncai P, Bhat Z. A rare case of hyperammonemia complication of high-protein parenteral nutrition. Jpen: Journal of Parenteral & Enteral Nutrition. 2013;37(1):134-137. | E1
76. | Polidoro M. [IDPN: effects on the treatment of CKD-MBD]. Giornale Italiano di Nefrologia. 2015;32(4):Jul-Aug. | E9
77. | Powers DV, Jackson A, Piraino AJ. Prolonged intradialysis hyperalimentation in chronic hemodialysis patients with an amino acid solution (RenAmin Amino Acid Injection) formulated for renal failure. Perspectives in Clinical Nutrition Baltimore, MD: Urban & Schwarzenberg. 1989:191-205. | E6
78. | Price CA, Towns M. The value of IDPN as a supplemental therapy when elderly patients fail to thrive--two case studies. ANNA journal. 1997;24(2):276-278. | E6
79. | Pupim LB, Flakoll PJ, Brouillette JR, Levenhagen DK, Hakim RM, Ikizler TA. Intradialytic parenteral nutrition improves protein and energy homeostasis in chronic hemodialysis patients. The Journal of clinical investigation. 2002;110(4):483-492. | E4
80. | Pupim LB, Flakoll PJ, Levenhagen DK, Ikizler TA. Exercise augments the acute anabolic effects of intradialytic parenteral nutrition in chronic hemodialysis patients. American journal of physiology Endocrinology and metabolism. 2004;286(4):E589-597. | E4
81. | Pupim LB, Majchrzak KM, Flakoll PJ, Ikizler TA. Intradialytic oral nutrition improves protein homeostasis in chronic hemodialysis patients with deranged nutritional status. Journal of the American Society of Nephrology: JASN. 2006;17(11):3149-3157. | E4
82. | Riobo Servan P, Ortiz Arduan A. [Efficacy of oral supplementation during dialysis in patients with chronic renal failure]. Endocrinologia y Nutricion. 2011;58(5):236-242. | E9
83. | Sabatino A, Regolisti G, Antonucci E, Cabassi A, Morabito S, Fiaccadori E. Intradialytic parenteral nutrition in end-stage renal disease: practical aspects, indications and limits. Journal of Nephrology. 2014;27(4):377-383. | B
84. | Sabatino A, Regolisti G, Karupaiah T, et al. Protein-energy wasting and nutritional supplementation in patients with end-stage renal disease on hemodialysis. Clinical Nutrition. 2017;36(3):663-671. | B
85. | Schulman G, Wingard RL, Hutchison RL, Lawrence P, Hakim RM. The effects of recombinant human growth hormone and intradialytic parenteral nutrition in malnourished hemodialysis patients. American journal of kidney diseases : the official journal of the National Kidney Foundation. 1993;21(5):527-534. | E6
86. | Sezer S, Bal Z, Tutal E, Uyar ME, Acar NO. Long-term oral nutrition supplementation improves outcomes in malnourished patients with chronic kidney disease on hemodialysis. Jpen: Journal of Parenteral & Enteral Nutrition. 2014;38(8):960-965. | E2
87. | Siskind MS, Lien YH. Effect of intradialytic parenteral nutrition on quality of life in hemodialysis patients. The International journal of artificial organs. 1993;16(8):599-603. | E6
88. | Smolle KH, Kaufmann P, Holzer H, Druml W. Intradialytic parenteral nutrition in malnourished patients on chronic haemodialysis therapy. Nephrology, dialysis, transplantation : official publication of the European Dialysis and Transplant Association - European Renal Association. 1995;10(8):1411-1416. | E6
89. | Snyder S, Bergen C, Sigler MH, Teehan BP. Intradialytic parenteral nutrition in chronic hemodialysis patients. ASAIO transactions. 1991;37(3):M373-375. | E6
90. | Su VC, Shalansky K, Jastrzebski J, et al. Parenteral vitamin B12 in macrocytic hemodialysis patients reduced MMA levels but did not change mean red ceil volume or hemoglobin. Clinical Nephrology. 2011;75(4):336-345. | E4
91. | Szklarek-Kubicka M, Fijalkowska-Morawska J, Zaremba-Drobnik D, Ucinski A, Czekalski S, Nowicki M. Effect of Intradialytic Intravenous Administration of omega-3 Fatty Acids on Nutritional Status and Inflammatory Response in Hemodialysis Patients: A Pilot Study. Journal of Renal Nutrition. 2009;19(6):487-493. | E6
92. | The National Kidney Foundation Kidney Disease Outcomes Quality Initiative (NKF KDOQI). KDOQI Clinical Practice Guidelines for Nutrition in Chronic Renal Failure Guideline 19: Indications for Nutritional Support. In:2000. | G
93. | Thunberg B, Jain VK, Patterson PG, Cestero RV, Swamy AP. Nutritional measurements and urea kinetics to guide intradialytic hyperalimentation. Proceedings of the Clinical Dialysis and Transplant Forum. 1980;10:22-28. | E6
94. | Tsunoda M, Ikee R, Sasaki N, Hashimoto N. Beneficial effects of combination therapy of intradialytic parenteral nutrition and oral L-carnitine administration. International Urology & Nephrology. 2013;45(4):1235-1237. | E3
95. | Veronesi M, Mancini E, Valente F, Righetti F, Brunori G, Santoro A. [The effect of intradialytic parenteral nutrition (IDPN) on the amino acid pool, a kinetic study]. Giornale Italiano di Nefrologia. 2013;30(2):Mar-Apr. | E9
96. | Weiner DE, Kapoian T, Johnson DS. Nutrition, vitamin D, and health outcomes in hemodialysis: time for a feeding frenzy? Current Opinion in Nephrology & Hypertension. 2015;24(6):546-556. | B
97. | Weiner DE, Tighiouart H, Ladik V, Meyer KB, Zager PG, Johnson DS. Oral Intradialytic nutritional supplement use and mortality in hemodialysis patients. American Journal of Kidney Diseases. 2014;63(2):276-285. | B
98. | Wolfson M. Use of intradialytic parenteral nutrition in hemodialysis patients. American journal of kidney diseases : the official journal of the National Kidney Foundation. 1994;23(6):856-858. | E6
99. | Wolfson M, Jones MR, Kopple JD. Amino acid losses during hemodialysis with infusion of amino acids and glucose. Kidney Int. 1982;21(3):500-506. | E4
100. | Wong P, Smith P, Rodger D. The use of intradialytic parenteral nutrition to treat malnutrition: a case study. CANNT journal = Journal ACITN. 2003;13(2):31-46; quiz 37-39,46-38. | E6
101. | Worthington P, Balint J, Bechtold M, et al. When Is Parenteral Nutrition Appropriate? Journal of Parenteral and Enteral Nutrition. 2017;41(3):324-377. | G
102. | Wright M, Jones C. Nutrition in CKD 5th Edition. UK Renal Association, 2010.; 2010. | G

## Appendix E Evidence Tables

### DATA ABSTRACTION OF INCLUDED PRIMARY STUDIES

#### Data Abstraction of Included Studies (IDPN vs Comparator)

Author Year N | Study Design, Setting, Follow-up Duration | Baseline patient characteristics | IDPN characteristics Dialysis timing and duration of treatment Comparator | Criteria for malnutrition | Patient Health Outcomes | Biochemical Outcomes | Anthropometric Outcomes | Nutritional Score Outcomes
Cano 1990^10^ N=26 | RCT, Single center, 12 wks | Mean age: 58 yr %male: 58% %white: NR BW (%): 88.7% SA (g/dL): 3.7 SGA: NR | IDPN (Lipid/AA) Dialysis 3x/wk 12 wks Usual recommended diet | PA < 300 mg/L | NR | Mean change: SA (g/L):0.95 vs -0.43, P < .05 PA (mg/L): 20 vs -18, P < .05 | Mean change: BW (%): 2.0 vs -1.5, P < .01 MAC: 3.67 vs -0.36, P < .025 TSF: 2.00 vs -3.14, P = NS | NR
Cano 2007^11^ N=186 | RCT, Multicenter, 2 years | Mean age: 68 yr %male: 47% %white: NR BMI: 22.8 SA (g/dL): 3.16 SGA: NR Karnofsky score: 65.5 | IDPN (Protein/Lipid/Glucose/AA) + oral supplements Dialysis timing per patient usual dialysis schedule Treatment over 1 yr Oral supplements | 2 of the following: BMI <20, BW loss > 10%, SA < 3.5 g/dL, PA < 300 mg/L | Mortality: 43% vs 39%, P = NS Hospitalization rate (#days hosp./days follow-up): 0.08 vs 0.06 (month 12 to 24) P = NS No change in Karnofsy score in either group | No difference in change in SA or PA (data NR) | No difference in change in BMI (data NR) | NR
Capelli 1994^12^ N=81 | RC, Single center, 1 yr | Mean age: 60 yr %male: 51% %white: 42% BW/BMI: NR SA (g/dL): 3.02 SGA: NR | IDPN (Protien/Lipid/Dextrose) Dialysis 3x/wk for 9 months (avg.) Usual recommended diet + oral supplements (dependent on SA) | SA < 3.5 g/dL and BW < 10% of ideal or > 10% weight loss | Survival: RR = 1.34, P < .01 (Cox) Time to death (mo) for nonsurvivors: 16.9 vs 7.5, P < .01 | Mean change: SA (g/dL) Survivors: 0.53 (P = NS) vs 0.57 (P = NS) Nonsurvivors: -0.11 (P = NS) vs 0.22 (P = NS) | Mean change: BW (lb) Survivors: 26 (P = .01) vs -2 (P = NS) Nonsurvivors: 6.1 (P = NS) vs 1.3 (P = NS) | NR
Chertow 1994^13^ N= 24,196 | RC, Multicenter, 1 yr | Mean age: 58 yr %male: 49% %white: 48% BW.BMI: NR SA (g/dL): 3.74 SGA: NR | IDPN (details NR) Usual recommended diet | NR | OR death: (SA ≥ 4.0 g/dL & CRE > 8.0 mg/dL) = 2.6 (95% CI 1.34 -5.04) SA ≤ 3.3 =0.72^*^ (P< .01) SA ≤ 3.0 g/dL = 0.57 (95% CI 0.44 - 0.77) | NR | NR | NR
Hiroshige 1998^14^ N= 28 | PC, Single center, 1 yr | Mean age: 77 yr %male: 57% %white: NR BMI: 19.2 SA (g/dL): 3.41 SGA: NR | IDPN (Dextrose/Lipids/AA) Dialysis 3x/wk for 1 yr Usual recommended diet | Nutritional assessment (details NR) | Mortality: 0% vs 27.8%, (P < .02) | Mean change: SA (g/dL) 0.2 (P < .01) vs -0.2 (P< .01)^*^ | Mean change: BMI (kg/m2): 1.0 (P< .05) vs -1.5 (P < .05)^*^ BW (kg): 3 (P < .05) vs -2.5 (P < .05)^*^ MAC: -0.06 (P < 0.05) vs 0.07 (P < .05) TSF: -0.05 (P < 0.05) vs 0.2 (P < .01)^*^ | NR
Joannidis 2008^15^ N= 12 | PC, Multicenter, 6 months | Mean age: 80 yr %male: 50% %white: NR BMI: 22.4 SA (g/dL): 3.57 SGA: NR | IDPN (AA/Glucose/Lipids) During normal dialysis schedule for 6 mo Usual recommended diet | nPCR < 1g/kg/day, hs-CRP ≥ 0.5mg, SA ≤ 4 g/dL and BMI < 26 | Mortality: 0% vs 17% (P NR) | Mean change: SA (g/dL):-0.02 (P = NS) vs 0.23 (P = .03) | Mean change: BW (kg) 1.2 (P = 0.03) vs 0 (P = NS) BMI: 0.9 (P = 0.03) vs 0 (P = NS | NR
Liu 2016^16^ N= 32 | RCT, Single center, 9 months | Mean age: 72 % male: 44 % white: 0% BMI: 21.4 SA (g/dL): 3.74 SGA: Grade B=31.3%, Grade C=0.09% | IDPN (AA+glucose OR glucose only) Dialysis 3x/wk for 9 mo Nutrition counseling and oral supplements | 1 or more of: SA < 3.5 g/dL, PA < 200 mg/dL, PCR 1.1 g/kg/day | NR | Mean change: SA (g/L): AA Group = -0.30 vs Glucose Group = -2.25 vs Control = -1.45 P = 0.554 PA (mg/L): AA group = 9.25 vs Glucose Group = 32.5 vs Control = -13.30 P = 0.427 | NR | Mean change: SGA (level B) AA Group = -8.3% vs Glucose Group = 0% vs Control = 20%, P value NR; (level C): AA Group = 0% vs Glucose Group = -10% vs Control = 0%, P value NR
Marsen 2017^17^ N= 107 | RCT, Multicenter, 28 weeks | Mean age: 74 % male: 47% %white: NR BMI: 22.6 SA(g/dL): 3.44 SGA: Grade B= 75.9%; Grade C= 24% | IDPN Dialysis 3x/wk for 16 wks Nutritional counseling | SA < 3.5 g/dL, PA < 250 mg/dL, SGA level B or C | Mortality: 26.4% (14/53) vs 12.9% (7/54) (P = NR) Hospitalization: 59.0% vs 43.2%, P = .1509 Health related QoL (SF-12) score change from baseline at 16 wks. -2.74 vs 0.34, P = .1175 | Positive response to IDPN (≥ 30mg/L increase in PA) 48.7% vs 31.8% at week 16 (P = .1164) Patients achieving > 15% increase from baseline at week 4, PA (mg/L): 41% vs 20.5%, P = .0415 | NR | Improved SGA score by one grade: 20.5% vs 13.6%, P = .4037
Oguz 2001^18^ N= 20 | PC, Single center, 4 months | Mean age: NR %male: NR %white: NR BMI: 23.4 SA (g/dL): 3.8 SGA: NR | AA only Dialysis 3x/wk for 4 mo Oral AA | SA < 4 g/dL, total cholesterol < 150 mg/dL, PA < 200 mg/dL | NR | Mean change: SA (g/dl): 0.18 (P = .048) vs 0.28 (P = .17) | Mean change: BMI: -0.10 (P = 0.87) vs -0.10(P = .69) MAC: -1 (P = .09) vs 0.47 (P = .35) TSF: -0.43 (P = 0.5) vs 0.42 (P = .66) | NR
Piraino 1981^19^ N= 46 | PC, Single center, 20 weeks | NR | IDPN (EAA + NEAA + glucose OR EAA + glucose) Dialysis 3-4x/wk for 20 weeks Weight stable chronic HD patients | ≥ 10 or 15% loss of dry weight | NR | No significant difference in SA before or after treatment compared to control (data NR) | NR | NR
Thabet 2017^20^ N= 40 | RCT, Single center, 6 months | Mean age: 37 yr %male: 58% %white: NR BMI: 19.41 SA (g/dL): 3.02 SGA: NR | IDPN + erythropoietin + IV iron dextran + folic acid + vitamin B12 3x/wk for 6 mo Usual care + erythropoietin + IV iron dextran + folic acid + vitamin B12 | BMI <23, positive MIS, SA < 3.5 g/dL | No improvement in functional capacity (data NR) | Mean change: SA (g/dL) 0.93 (P = .001) vs-0.14 (P = 0.316) | Mean change: BMI 2.8 (P = .001) vs 0.03 (P = .981) | Mean change: MIS -8.75 (P = .001) vs 0.25 (P = .716)_

* Estimated from Figure; Table does not include Cranford 1998, only included for cost-effectiveness outcomes

Abbreviations: AA=amino acids, MAC=mid-arm circumference, BMI=body mass index, BW=body weight, CRE=creatinine, EAA=essential amino acids, IDPN=intradialytic parenteral nutrition. NEAA=non-essential amino acids, NS=not significant, NR=not reported. PA=serum pre-albumin, SA=serum albumin, SGA=subjective global assessment (Grade A: well-nourished, B: mild to moderately malnourished. C: severely malnourished), TSF=triceps skinfold, RC=retrospective cohor.; PC=prospective cohort; MIS=malnutrition inflammation score, nPCR=normalized protein catabolic rate, hs-CRP=high-sensitive C-reactive protein

### Quality Assessment of Included Studies

#### Quality Assessment of Included RCTs

Author Year | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Masked outcome assessor, Care provider, Patient? | Outcome measurement equal, reliable, and valid? | Intention-to-treat (ITT) analysis | Acceptable levels of crossovers, adherence, and contamination? | Acceptable levels of overall attrition and between-group differences in attrition? | Quality Rating (Good, Fair, Poor)
Cano 1990^10^ | Unclear | Unclear | Yes NS differences in demographic or nutritional information | Unclear No No | Yes | Unclear No mention of missing data or crossovers | Unclear No mention of missing data or crossovers | Unclear No mention of missing data or crossovers | Fair
Cano 2007^11^ | Unclear Sequence generation not described | No Opaque sealed envelopes; QA guidance states opaque envelopes as an Inadequate approach | Yes NS differences in demographic, nutritional indices at baseline | Unclear No No | Yes | Yes | No IDPN group: 26% discont. oral supp, 24% discont. IDPN Control: 19% discont. oral supp | Yes No patients lost to follow-up | Fair
Liu 2016^16^ | Yes Used random numbers table | Unclear | Yes NS differences in demographic or nutrition information | Unclear No No | Yes | No 11% (4/36) of study population were not included in the final analysis due to transfer to another hospital | Yes | No Attrition: 17% control vs 17% glucose vs 0% AA; < 20%, but >10% difference between groups. | Fair
Marsen 2017^17^ | Unclear Consecutively randomized in blocks of 4 based on a generated randomization schedule; cannot verify comparability at baseline of randomized group | Yes Contract research organization controlled randomization; “centralized” randomization | Yes NS differences in demographic information; report analyzed groups but not randomized groups | Unclear No | Yes No | No 16% (17/107) of the study population were not included in the final ITT analysis due to missing data | Yes 14% (15/107, excluding deaths) discontinued therapy overall, only one crossover and no contamination reported | Yes 17% vs 15% | Fair
Thabet 2017^20^ | Unclear Sequence generation not described; randomized in blocks of 4 as determined by researcher | Unclear Not described | No Intervention group had significantly lower baseline BMI and creatinine, higher MIS score | Unclear No No | Yes | Yes No dropout | Unclear Adherence not described | Yes No dropout | Fair

Abbreviations: AA=amino acids, BMI=body mass index, discont=discontinued, IDPN=intradialytic parenteral nutrition, NS=not significant, QA=quality analysis, slip.=supplement

#### Quality Assessment of Included Observational Studies

Author Year | Risk of selection bias? (yes/no/unclear) | Risk of performance bias? (yes/no/unclear) | Risk of detection bias? (yes/no/unclear) | Risk of bias due to confounding? (yes/no/unclear) | Risk of Attrition bias? (yes/no/unclear) | Risk of reporting bias? (yes/no/unclear) | Overall Quality (Good/Fair/Poor)
Capelli 1994^12^ | Unclear No information about number of exclusions | No All patients followed same algorithm for treatment protocol | No Objective outcomes | Unclear Patients similar at baseline, but did not include serum albumin, weight, etcetera, which may have been unbalanced (Table 5). Adjusted for demographic and dialysis factors, potential for residual confounding if IDPN group was more malnourished | Unclear No description of handling of missing data | Unclear | Fair
Chertow 1994^13^ | No Every patient in a national database receiving hemodialysis at the centers during the study period were included | Unclear No info on other interventions received in IDPN or control groups | No Objective outcomes | Unclear Differences at baseline (serum albumin, creatinine, urea reduction ratio, etc),adjusted for differences, potential for residual confounding if IDPN group was more malnourished (ie, higher weight loss) | Unclear No description of handling of missing data | Unclear | Fair
Hiroshige 1998^14^ | Unclear No information about number of exclusions | No All patients prescribed renal diet, followed same treatment protocol | No Objective outcomes | Unclear Control group consisted of those refusing IDPN (reasons not given – potentially related to disease status). IDPN group significantly older (81 vs 74 yrs) at baseline. No adjustment for potential confounders. | Unclear No description of handling of missing data | Unclear | Poor
Joannidis 2008^15^ | Unclear No information about number of exclusions | No | No | Unclear Controls matched for age, sex, BMI, and comorbidity. Similar at baseline except nPCR significantly lower in controls, no adjustment | No | Unclear | Fair
Oguz 2001^18^ | Unclear Unclear how intervention and control groups were chosen | Unclear 40% transferred from oral group to IDPN due to non-compliance and did not get first week of IDPN | No | Unclear State no differences between groups, but no data given and do not mention nutritional indicators (serum albumin, etc). No adjustment for potential confounders. | No | Unclear | Poor
Piraino 1981^19^ | Yes No information on exclusions; unclear how different intervention groups were chosen, unclear if there were other groups (4-13?) not included in analysis | Unclear Treatment unbalanced between intervention groups; no information on control group | No | Yes Group 2 (combined amino acid and glucose solution) may have had worse prognosis due to hyperparathyroidism and related issues; no information on demographics or comorbidities at baseline. No adjustment for potential confounders | No | Unclear Potential suppression of patient groups 4 to 13 | Poor

Abbreviations: BMI=body mass index, IDPN=intradialytic parenteral nutrition, nPCR=normalized Protein Catabolic Rate

### Strength of Evidence for Included Studies

SOE Grade (High, moderate, low) | No. Studies Study Design (N) | Study Limitations (High, medium, low) | Directness (Direct or indirect) | Consistency (Consistent, inconsistent, unknown for single study) | Precision (precise or imprecise) | Reporting Bias (Suspected, undetected) | Other Issues (None or describe) | Finding (Results – describe direction in words (greater or lower risk or no difference) and provide data
Mortality
IDPN vs oral supplements: Low | 1 RCT^11^ (186) | Medium | Direct | Unknown | Imprecise | Undetected | None | No difference in mortality: 43% (IDPN) vs 39% (control) (P = NS)
IDPN vs dietary counseling: Insufficient | 1 RCT^17^ (107) | Medium | Indirect | Unknown | Imprecise | Suspected: Main threshold outcome not listed in protocol | None | 26.4% (IDPN) vs 15.9% (control) (P = NR)
IDPN vs usual care*: SA ≤ 3.3 g/dL Low | 2 Cohorts^12,13^ (24,277) | Medium | Indirect | Consistent | Precise | Undetected | None | Lower mortality/improved survival with IDPN (OR death range 0.57** to 0.72**, P < .01),^13^ RR survival = 1.34 (P < .01)^12^
IDPN vs usual care*: SA > 3.3 g/dL Low | 3 Cohorts^13,14^ (24,224) | Medium | Indirect | Inconsistent | Precise | Undetected | None | Higher mortality with IDPN in subgroup of patients with SA ≥ 3.5 g/dL (OR death for SA ≥ 4.0 g/dl and CRE ≥ 8 mg/dL = 2.6 (1.34 to 5.04)).^13^; No difference in mortality with IDPN in subgroup of patients with SA ≤ 3.5 (OR = 1.0**) or SA ≤ 3.4 (OR = 0.86**)^13^; With baseline SA = 3.41 lower mortality with IDPN 0% vs 28% (P < .02)^14^
Hospitalization
IDPN vs oral supplements: Low | 1 RCT^11^ (186) | Medium | Direct | Unknown | Imprecise | Undetected | None | No difference in hospitalization rate (# days hospitalization/ follow-up): .008 (IDPN) vs 0.06 (control) (P = NS)
IDPN vs dietary counseling: Insufficient | 1 RCT^17^ (107) | Medium | Indirect | Unknown | Imprecise | Suspected: Main threshold outcome not listed in protocol | None | No difference in hospitalization: 59% (IDPN) vs 43.2% (control) (P = .15)
Quality of Life/Functional Impairment
IDPN vs oral supplements: Low | 1 RCT^11^ (186) | Medium | Direct | Unknown | Imprecise | Undetected | None | No difference in function as measured by Karnofsky score (data NR)
IDPN vs dietary counseling: Insufficient | 1 RCT^17^ (107) | Medium | Indirect | Unknown | Imprecise | Suspected: Main threshold outcome not listed in protocol | None | No difference QoL as measured by SF-12:- 2.74 (IDPN) vs 0.34 (control), P = .1175
IDPN vs usual care*:Low | 1 RCT^20^ (40) | Medium | Indirect | Unknown | Imprecise | Undetected | None | No improvement in functional capacity in either group (data NR)
% meeting threshold for nutritional improvement
IDPN vs dietary counseling: Insufficient | 1 RCT^17^ (107) | Medium | Indirect | Unknown | Imprecise | Suspected: Main threshold outcome not listed in protocol | None | More patients receiving IDPN reached a 15% improvement in serum prealbumin at 4 weeks compared to control (41 % IDPN vs 20.5% control, P = .0415)

Abbreviations: IDPN=intradialytic parenteral nutrition, NR=not reported, NS=not significant, SA=serum albumin, QoL=quality of life; CRE=creatinine

## Appendix F Peer Review

Comment Number | Reviewer Number | Comment | Author Response
Are the objectives, scope, and methods for this review clearly described?
1. | 1 | Yes | None
2. | 2 | Yes | None
3. | 3 | Yes | None
4. | 4 | Yes | None
5. | 5 | Yes | None
6. | 6 | Yes | None
Is there any indication of bias in our synthesis of the evidence ?
7. | 1 | No | None
8. | 2 | Yes - Portland VA Health Care prpares for VHA and clearly has intenlon to reduce costs due to early therapy application | The ESP CC’s purpose in developing this evidence brief is to aid the VA Renal Field Advisory Committee in understanding the effectiveness and harms of IDPN for malnourished hemodialysis patients so they may establish national recommendations for its use in VA. Just because something is expensive, doesn't mean that an investigation of its benefits and harms are inherently biased. We investigate a wide range of health care topics with a wide range of costs. We use the same prespecified, transparent, and reproducible methods to critically evaluate all topics regardless of their cost.
9. | 3 | No | None
10. | 4 | No | None
11. | 5 | No | None
12. | 6 | No | None
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
13. | 1 | No | None
14. | 2 | No | None
15. | 3 | No | None
16. | 4 | No | None
17. | 5 | No | None
18. | 6 | No | None
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
19. | 2 | The review strives to develop a chain of evidence from the very heterogeneous and sparse literature of only 11 RCTs and cohort studies on the subject of IDRN and to ultimately take a position on whether its use is justified and when it should be started in this population. The reviewers come to completely contrary results compared to the ESPEN recommendation on IDPN in adult renal failure, published in Clin Nutr 2009. This is especially surprising in view of the fact that since 2009 only 3 additional studies on the subject, all of them are RCTs, have been published, and which have found their way into the review process. Of these 3 RCTs, one did not administer IDPN but Aminoacids alone or in addition with Glucose, one made the comparison to vitamins as controls and none addressed the issue of survival. It is therefore surprising that the vote in this review comes to a completely different conclusion about the benefits of IDPN and therefore is more than questionable. | We disagree with this reviewer that our report comes to a different conclusion than the 2009 ESPEN or the 2017 ASPEN guidelines. We state that IDPN may be used for hemodialysis patients who do not respond to dietary counseling, oral, and/or enteral supplementation. The 2009 ESPEN guidelines recommend IDPN “...if nutritional counseling and oral nutritional supplements (ONS) are unsuccessful” (pg. 409)^4^ Additionally, the 2017 American Society for Parenteral and Enteral Nutrition (ASPEN) guidelines recommend use of IDPN for patients who are “unable to tolerate adequate oral intake or [enteral nutrition]” (pg. 327)^1^ which agree with the findings of our report. We have added clarification that we agree with these existing guidelines to our discussion and conclusion. We agree that the published literature is heterogeneous in nature and have added further discussion of this to the limitations section of the report.
20. | 2 | One major problem of a general recommendation on the use of IDPN begins with the population being studied. In this VHA population malnutrition is not the consequence of ESRD, i.e. to be assigned to a single cause, but multifactorial and has to be discriminated from the different underlying diseases, the various secondary diseases, the diverse dialysis therapy modalities etc. Accordingly, an evaluation may only come to a general recommendation, if all these causes are excluded or standardized. To my knowledge, this has not been ensured in any of the studies conducted, even if the most recent investigation has endeavored to do so [4]. | We agree that the causes of malnutrition are multifactorial. We attempted to explore whether IDPN has differential effects in subgroups of patients based on patient characteristics (disease severity, comorbidities, etc), but were unable to due to limitations of the evidence (heterogeneity, lack of sufficient detail on patient characteristics, etc). We agree that this is a limitation of the evidence and have added further detail on this to the discussion section.
21. | 2 | Additionally, the dialysis treatment itself is so heterogeneous that it can affect outcome to varying degrees (fully synthetic vs polysulfone dialyzers, ultra pure dialysate vs. normal dialysate, HDF vs HD). Non of the studies cited has done so. | We agree that dialysis treatment regimen may affect outcome. Studies lacked sufficient detail to assess the differential effect of IDPN based on these differences and we have added discussion of this to our limitations section.
22. | 2 | IDPN therapy is at minimum able to improve nutritional parameters and is reported cost neutral compared to the alternative hospitalization and hospital costs. | We agree with this chain of logic, but available evidence is yet insufficient to support this.
| | Assuming that nutritional parameters predict morbidity and /or mortality, it seems reasonable to speak of not-inferiority of IDPN. Therefore, in the individual case, it should be left to the discretion of the physician to initiate such therapy. | Although studies have shown improvement in mean changes in some nutritional parameters, mean improvements in biochemical markers do not always translate into clinically significant benefits. A single study reported % of patients reaching a threshold of improvement in a single biochemical parameter (15% improvement in serum prealbumin)^17^, but the meaningfulness of this improvement is unclear as clinical justification for the threshold was not provided, and we are not aware of evidence linking this threshold to reduced mortality. IDPN resulted in no improvement in a separate clinically-relevant threshold directly linked to mortality (> 30 mg/L improvement in serum prealbumin).^11^ Further, our confidence is low in the evidence supporting this reviewer’s statement that IDPN is “cost-neutral” due to its imprecision N-45). indirectness (outdated, lack of information on patient characteristics, dialysis type, and IDPN characteristics), unknown consistency (single study) and methodological limitations (no concurrent non-IDPN comparator)
23. | 2 | The authors use the title of an “evidence brief”, which is misleading and not justified, if any it should be avoided. | Because there is no widely-agreed definition for “evidence brief” and this reviewer did not suggest an alternative, we are unclear of this reviewer’s intentions with suggesting avoiding use of the title. Because this reviewer made this statement in introduction to comments 25-31, which include claims that we have misinterpreted the evidence, we can only assume this reviewer made this suggestion in relation to these claims. Below we have provided detailed responses refuting each of this reviewer’s claims that we have misinterpreted the evidence.
24. | 2 | The authors do not mention the problem of comparability in relation to the age of the population studied in the RCTs, which varies from a mean of 37 to a mean of 80 years. In their review the authors either intentionally or forgetfully omit data about the age of the VHA population for which the review is created and which should ultimately serve as a comparison. It must be assumed that the VHA population is over 65 years old, this however would exclude several RCTs for comparison. | We disagree as the overall mean patient age of the included studies was 65 years, which is comparable to the median Veteran age in 2015 of 64 years.^21^ We discuss the comparability of the age of the studied patient populations to the Veteran population in our “Limitations” section on page 19 of our report. Although mean patient age varied among studies, the majority of studies had mean patient age between 58 and 80 years (with one study reporting a mean patient age of 37 years).
25. | 2 | The authors come to a recommendation for the non-superority of IDPN versus ONS by regard of three RCTs in their review. However, one of which examined 2-year mortality, hospitalization and quality of life, a second one BMI, albumin, prealbumin and SGA, and a third only improvement in albumin. The attempt to compare these RCTs must be regarded as questionable, since the incomparable of the study structures excludes a similarity in principle. Therefore the concluision on page 18 lines21-24 is incorrect. | We disagree that we are incorrect to conclude that IDPN has not been shown to improve clinically important outcomes overall oral supplements, which agrees with the current ASPEN guidelines.^1^ We include two RCTs and one prospective cohort study compared to oral supplements. Regardless of the numerous types of outcomes measured, none found a clinically important benefit with IDPN. We discuss the heterogeneity of the studies a limitation of the evidence.
26. | 2 | Comparison of IDPN vs dietary counselling was investigated for changes in prealbumin in yet another RCT cited. The results demonstrate significant improvement of prealbumin, a surrogate marker for outcome and survival in hemodialysis patients suffering from PEW. It remains unclear why the authors of this review claim that “ IDPN has not demonstrated to improve .... nutritional outcomes” (page 18 line 22). Today several parameters are defined as markers for and discriminate on malnutrition. None of them is superior to the other therefore the data is to be interpreted as a clear advantage of IDPN over dietary counselling. | As we prespecified, our review sought the evidence that would best demonstrate a clinically important benefit of IDPN over recommended treatment, which would be direct evidence of how IDPN compared to other treatments on “clinically-relevart” nutritional status indicators and health outcomes (httD://www.crd. vork.ac.uk/PROSPERO/: registration number CRD42017074001). We identified the threshold of > 30mg/L increase in serum prealbumin as the strongest nutritional marker because it is the only marker that is supported by prospectively measured nutritional data with identification of a threshold of improvement associated with mortality.^11^ On page 18 line 22 we concluded that IDPN has not been demonstrated to improve patient health or nutritional outcomes better than current guideline recommended treatment, including dietary counseling, because a single small RCT (Marsen 2017) provided preliminary evidence that IDPN does not significantly increase > 30mg/L improvements. Although we agree that in Marsen 2017, IDPN improved the percentage of patients reaching a 15% improvement in serum prealbumin at 4 weeks, no clinical justification was given for this threshold and we are not aware of evidence linking this threshold to reduced mortality. For this and other reasons outlined in the report, we disagree that demonstration of IDPN improving a single nutritional marker with unknown clinical significance, shows a “clear advantage” of IDPN.
27. | 2 | The comparison of IDPN vs usual care improperly attempts an argumentative weakening of IDPN by mentioning that “usual recommended diet... may have included dietary recommendations and/or oral supplementation” (page 15, line 20-21), which is purely speculative by the authors and misleadingly weakens the comparator. Such personal speculation should be omitted. | Our discussion of the insufficient characterization of “usual care” is not meant to weaken IDPN. We discuss this lack of detail to point out the limited applicability of these studies and difficulty in assessing applicability to specific clinical circumstances. We have removed the language that usual care may have included dietary recommendations and/or oral supplementation, as we agree it is unclear and not crucial to our main point.
28. | 2 | Moreover the review misstates results from three essential RCTs. In the Chertow publication Albumin is discriminated at ≤3.4g/dl. The fact that patients with Alb>3,4g/dl received IDPN should be mentioned with all due caution and may not be interpreted in this context, as Alb cut-off for malnutrition is 3,5g/dl. These patients therefor cannot be considered to be malnourished without additional parameters specific for PEW, eg. BMI or prealbumin. | We agree that patients with higher baseline serum albumin levels may not have been considered malnourished and the findings should be interpreted with caution. Since this cohort study (Chertow 1994) used a large retrospective database and assigned intervention and control groups based on receipt of IDPN alone, we do not have information about why patients with serum albumin above 3.5 were treated with IDPN and if they had other nutritional parameters of malnutrition. This lack of information about the intervention and control groups is discussed as a limitation of these findings. We include 2 RCTs compared to oral supplements and 1 RCT compared to dietary counseling. Please see our responses to comments #26 and #27 for our detailed rebuttal about the misstated results from the “three essential RCTs”.
29. | 2 | Furthermore the results should not be weakened just because there is a lack of information on control interventions, quality of life etc. Undoubtedly, as well as for the Capelli study [5], a survival advantage for IDPN could be shown. | We disagree and believe the lack of information on control group does limit the interpretation of findings. Without this information, we cannot judge intervention adherence or potential co-interventions in this study and thus cannot determine if the mortality benefit observed can be attributed specifically to IDPN and not differences between intervention and control groups in concomitant treatments, disease state, level of malnutrition, or other potentially confounding factors. Additionally, for a treatment to best demonstrate a clinically-important benefit over recommended treatments, it should not only reduce the risk of mortality, but also improve the functional status and quality of life of the survivors.
30. | 2 | Furthermore, it remains unclear why the authors conclude with regard to Thabet’s work that “nutritionally related functional capacity is not improved”, as both BMI and Alb increase. | We concluded that “nutritionally related functional capacity is not improved” based on the finding of “no patient had improvement of functional capacity [nutritionally related functional impairment]” (pg 187).^20^ We agree with and reported that BMI and serum albumin increased, but those are not measures of functional capacity.
31. | 2 | It is speculative if RCTs analyzed will be suitable to answer questions on survival benefit. It seems inappropriate, considering the duration of RCTs between 12 weeks and 1 year, to address this question of a survival benefit compared to a usual diet or diatetic counseling. Even 2 years may be still too short to measure for a survival advantage. | We agree that longer follow-up duration is ideal. However, as hemodialysis patients currently only have 57% 3-year survival,^22^ improvement in 2-year survival would be a substantial benefit.
32. | 2 | Of course, tube feeding would be the most efficient measure apart from TPN, but for a population that is ambulatory, tube feeding is closer to non-ambulatory therapy than IDPN or ONS. Therefore the recommendation to comply IDPN with tube feeding fails because of the acceptance. | We agree that appearance and logistics of tube feeding may be barriers to acceptance, as discussed in the introduction section. Despite this, ambulatory feeding tubes are available and thus a comparison of IDPN to enteral tube feeding is feasible.
33. | 2 | Last but not least, longer study duration is not feasible considering the study costs, sponsors from the industry will not approve for funding because of missing innovation and patent protection. It remains only the longitudinal observation and to burden the health insurance companies as payers themselves. | We have modified our recommendations to not be limited to RCTs due to their higher cost.
34. | 2 | An additional Key Question 1.1 is missing and should be addressed. Despite speculation on IDPN in non-diabetics, ineffectiveness of IDPN in diabetics with ESRD has been proven on various times but is not mentioned [1,4,5]. | We attempted to address diabetics (and other subgroups) with Key Question 4, but the evidence was insufficient as subgroup analysis by diabetes status was only reported in a single, small, non-randomized, retrospective study.^12^
35. | 3 | This is an excellent report. Very well conducted, comprehensive and the conclusions and recommendations are fair and appropriate. | Thank you.
36. | 4 | P.1; Lines 31 -33: “Intradialytic parenteral nutrition (IDPN) is the infusion of an intravenous nutritional formula during regularly scheduled dialysis sessions.”. Suggest to modify the statement so that non-specialists would not misinterpret the sentences. Suggested revision “Intradialytic PN (IDPN) is a form of partial parenteral nutrition administered during hemodialysis session. It is not intended to provide the total daily nutrient requirements for the patient.” | The sentence has been modified as suggested for clarity.
37. | 4 | p.4 line 60 - p.5 line: Consider replacing the definition of malnutrition. Reference 25 is an outdated paper. There is currently an international workgroup comprising researchers and policy makers from Asia, Europe, US, Canada, South American, and Australia to come up with a standardized definition of malnutrition. This workgroup has been meeting for 5 years and the initial report in due to be published. Consider reviewing (and including) these 2 papers in this document as they are the basis and framework for revise definition. It is important to point out that serum protein is not a preferred marker of nutritional status. (Cederholm T et al, Clin Nutr 2015 Jun;34(3):335-4; Malone A, Hamilton C. Nutr Clin Pract. 2013 Dec;28(6):639-50) | We added a figure detailing the new ASPEN consensus recommendations for diagnosing malnutrition in addition to the discussion of the varying diagnostic criteria in current guidelines for treatment of malnutrition in hemodialysis patients. We have also added a discussion around serum protein levels no longer being a preferred marker of nutritional status.
38. | 4 | p.5 line 21: There seems to be an over-emphasis of the use of specialized oral nutritional supplement (i.e., Nepro). It may be misleading as patients on HD receiving a potassium-restricted diet may also tolerate standard nutritional supplement. And there is no published data to my knowledge that showed better clinical outcomes with specialized oral supplement (e.g., Nepro) over standard supplemental products. This may also affect the cost-estimation on p.6 | We mentioned Nepro as it used in the VA, but reference to standard nutritional supplements has been added to this section as well as information on cost of standard nutritional supplements on page 6.
39. | 4 | p.5. Lines 53-54: Total parenteral nutrition (TPN) is an old term. Currently, we call it parenteral nutrition (PN). This is especially important because IDPN is a form of PN, but not TPN as it only provide PARTIAL nutrition but not total daily needs. Please refer to ASPEN and ESPEN documents for details. | We have removed the reference to TPN and revised this paragraph to discuss PN overall and IDPN as partial PN. “PN is the infusion of an intravenous nutritional formula into the blood stream, and is commonly used among hospitalized patients. Intradialytic PN (IDPN), is a form of partial parenteral nutrition administered during regularly scheduled dialysis sessions as a supplement (commonly 3 times per week), and requires the patient to get some of their nutrients orally outside of dialysis time”
40. | 4 | p.5 line 60: Please change “i.e.” to “e.g.,” it is important the ingredients in the brand name products may change over time. So, it would be potentially misleading to use the term Kabiven and premixed solution interchangeably. I would suggest to call these product “commercially available standardized multichamber PN solution” (see https://www.nutritioncare.org/Guidelines_and_Clinical_Resources/Toolkits/Parenter al_Nutrition_Safety_Toolkit/Multi-Chamber_PN_Standardized,_Commercial_Products_Tools_and_Resources/) | Wording has been changed from ie to eg, and the wording around the products has been changed as suggested to “commercially available standardized multi-chamber PN solution”. The reference to NutriRite has been removed to avoid confusion as it is an individualized solution. A reference to a systematic review of multi-chamber bags has been added to this section from the listed resources.
41. | 4 | p.17- Key Question 2- It is also worth mentioning that the goal for the “treatment of malnutrition” varied significantly amongst the published studies. Therefore, it is almost impossible to objectively compare the treatment outcomes and the adverse effect associated with IDPN. There is also a potential treatment bias - patients receiving iDPNs likely have received more frequent laboratory monitoring and symptomatic assessment for fluid and electrolyte disoders. Thus, the actual incidence of adverse events might have been artificially lowered. | A discussion of the limitations in the evidence of adverse effects has been expanded under Key Question 2 and in the discussion, including a discussion of the potential for lower adverse events amongst patients receiving IDPN due to increased monitoring.
42. | 4 | p.17, Key Question 4- I am concerned about the conclusion anchoring lower serum albumin as a the “potential best candidates for IDPN”. As mentioned, as a field, we are moving away from using serum album as a sole indicator for nutritional intervention or assessment of treatment efficiacy. The paper (ref .6) cited is based on older concept. More importantly, the clinical response to protein provision depends on the patient’s inflammatory status, concurrent oral intake, as well as the amount of protein provision in the IDPN. The range of protein provision in published studies using IDP varies and the oral nitrogen/protein intake is rarely characterized. Therefore, I think using the serum albumin as a screening criterion or treatment outcome assessment can be very misleading. | We have reframed this section to highlight that we cannot draw conclusions based on the evidence available. We have added discussion of the limitations of serum protein levels in screening and outcome assessment of malnutrition to this section as well as to the introduction and discussion sections.
43. | 4 | p.19- Lines 26-27: Please revise to “No studies compared IDPN to patient receiving enteral nutrition or enteral tube feeding”. Note that orally administered nutritional supplements such as Ensure or Nepro are, indeed, enteral supplements. So, the original statement is incorrect. | We have revised this wording to “no studies compared IDPN to enteral tube feeding” for clarification.
44. | 4 | Finally, it is worth mentioning that the outcomes of untreated malnutrition is poor and costs associated with subsequent hospitalization for managing malnutrition is high. Therefore, the priority should be on improving/reversing malnutrition in patients with CKD requiring HD. Every attempt should be made to first increase oral intake or the use of enteral nutrition in reversing malnutrition in patients with CKD. | We have added this context to the beginning of the discussion section to highlight the need for treatment of malnutrition in hemodialysis patients.
45. | 5 | Page 6 Evidence Brief: 2nd paragraph potential for risk for harms (infection, fluid overload, chemical imbalance, add hyperglycemia). | We have added hyperglycemia as a potential harm, and also listed it in the adverse events section of the results. As hyperglycemia is a concern among diabetic patients, we have added a discussion of the prevalence of diabetes among Veterans as a potential limitation in the applicability of the studies.

## References

1. Worthington P, Balint J, Bechtold M, et al. When is parenteral nutrition appropriate? Journal of Parenteral and Enteral Nutrition. 2017;41(3):324-377.28333597
2. British Columbia Provincial Renal Agency. Intradialytic parenteral nutrition (IDPN): Provincial standards and guidelines. 2007. http://www.bcrenalagency.ca/resource-gallery/Documents/Intradialytic%20Parenteral%20Nutrition%20(IDPN).pdf. Accessed January 9th, 2018.
3. Department of Veterans Affairs. VHA handbook 1109.05: Nutrition therapy. In: Veterans Health Administration, ed. Washington D.C.: Department of Veterans Affairs; 2013.
4. Cano NJ, Aparicio M, Brunori G, et al. ESPEN guidelines on parenteral nutrition: Adult renal failure. Clinical Nutrition. 2009;28(4):401-414.19535181
5. Druml W, Kierdorf HP, Working group for developing the guidelines for parenteral nutrition of The German Association for Nutritional Medicine. Parenteral nutrition in patients with renal failure - guidelines on parenteral nutrition, chapter 17. German Medical Science. 2009;7:Doc11.
6. Ikizler TA, Cano NJ, Franch H, et al. Prevention and treatment of protein energy wasting in chronic kidney disease patients: A consensus statement by the international society of renal nutrition and metabolism. Kidney International. 2013;84(6):1096-1107.23698226
7. The National Kidney Foundation Kidney Disease Outcomes Quality Initiative (NKF KDOQI). KDOQI clinical practice guidelines for nutrition in chronic renal failure guideline 19: Indications for nutritional support. 2000; http://www2.kidney.org/professionals/kdoqi/guidelines_nutrition/doqi_nut.html. Accessed January 9th, 2018.
8. Nottingham University Hospitals, Mafrici B. Guideline for the use and administration of intradialytic parenteral nutrition (IDPN) in adult haemodialysis patients. In: Nottingham University Hospitals, ed: Nottingham University; 2016.
9. Wright M, Jones C. Nutrition in CKD 5th edition. UK Renal Association; 2010.
10. Cano N, Labastie-Coeyrehourq J, Lacombe P, et al. Perdialytic parenteral nutrition with lipids and amino acids in malnourished hemodialysis patients. Am J Clin Nutr. Oct 1990;52(4):726-730.2119558
11. Cano NJ, Fouque D, Roth H, et al. Intradialytic parenteral nutrition does not improve survival in malnourished hemodialysis patients: A 2-year multicenter, prospective, randomized study. J Am Soc Nephrol. Sep 2007;18(9):2583-2591.17656473
12. Capelli JP, Kushner H, Camiscioli TC, Chen SM, Torres MA. Effect of intradialytic parenteral nutrition on mortality rates in end-stage renal disease care. Am J Kidney Dis. Jun 1994;23(6):808-816.8203363
13. Chertow GM, Ling J, Lew NL, Lazarus JM, Lowrie EG. The association of intradialytic parenteral nutrition administration with survival in hemodialysis patients. Am J Kidney Dis. Dec 1994;24(6):912-920.7985668
14. Hiroshige K, Iwamoto M, Kabashima N, Mutoh Y, Yuu K, Ohtani A. Prolonged use of intradialysis parenteral nutrition in elderly malnourished chronic haemodialysis patients. Nephrology, dialysis, transplantation: official publication of the European Dialysis and Transplant Association-European Renal Association. 1998;13(8):2081-2087.9719170
15. Joannidis M, Rauchenzauner M, Leiner B, et al. Effect of intradialytic parenteral nutrition in patients with malnutrition-inflammation complex syndrome on body weight, inflammation, serum lipids and adipocytokines: Results from a pilot study. Eur J Clin Nutr. Jun 2008;62(6):789-795.17522619
16. Liu Y, Xiao X, Qin DP, et al. Comparison of intradialytic parenteral nutrition with glucose or amino acid mixtures in maintenance hemodialysis patients. Nutrients. 2016;8(6):02.
17. Marsen TA, Beer J, Mann H. Intradialytic parenteral nutrition in maintenance hemodialysis patients suffering from protein-energy wasting. Results of a multicenter, open, prospective, randomized trial. Clin Nutr. Feb 2017;36(1):107-117.26708726
18. Oguz Y, Bulucu F, Vural A. Oral and parenteral essential amino acid therapy in malnourished hemodialysis patients. Nephron. Oct 2001;89(2):224-227.11549907
19. Piraino AJ, Firpo JJ, Powers DV. Prolonged hyperalimentation in catabolic chronic dialysis therapy patients. J Parenter Enteral Nutr. Nov-Dec 1981;5(6):463-477.
20. Thabet AF, Moeen SM, Labiqe MO, Saleh MA. Could intradialytic nutrition improve refractory anaemia in patients undergoing haemodialysis? Journal of Renal Care. 2017;43(3):183-191.28636166
21. National Center for Veterans Analysis and Statistics. Profile of veterans: 2015, data from the American community survey. US Department of Veterans Affairs; 2017.
22. United States Renal Data System. 2017 USRDS annual data report: Epidemiology of kidney disease in the United States. Bethesda, MD: National Institutes of Health, National Institute of Diabetes and Digestive and Kidney Diseases; 2017.