# Evidence Brief: Hyperbaric Oxygen Therapy (HBOT) for Traumatic Brain Injury and/or Post-traumatic Stress Disorder

## PREFACE

The VA Evidence-based Synthesis Program (ESP) was established in 2007 to provide timely and accurate syntheses of targeted healthcare topics of particular importance to clinicians, managers, and policymakers as they work to improve the health and healthcare of Veterans. QUERI provides funding for four ESP Centers, and each Center has an active University affiliation. Center Directors are recognized leaders in the field of evidence synthesis with close ties to the AHRQ Evidence-based Practice Centers. The ESP is governed by a Steering Committee comprised of participants from VHA Policy, Program, and Operations Offices, VISN leadership, field-based investigators, and others as designated appropriate by QUERI/HSR&D.

The ESP Centers generate evidence syntheses on important clinical practice topics. These reports help:

Develop clinical policies informed by evidence;

Implement effective services to improve patient outcomes and to support VA clinical practice guidelines and performance measures; and

Set the direction for future research to address gaps in clinical knowledge.

The ESP disseminates these reports throughout VA and in the published literature; some evidence syntheses have informed the clinical guidelines of large professional organizations.

The ESP Coordinating Center (ESP CC), located in Portland, Oregon, was created in 2009 to expand the capacity of QUERI/HSR&D and is charged with oversight of national ESP program operations, program development and evaluation, and dissemination efforts. The ESP CC establishes standard operating procedures for the production of evidence synthesis reports; facilitates a national topic nomination, prioritization, and selection process; manages the research portfolio of each Center; facilitates editorial review processes; ensures methodological consistency and quality of products; produces “rapid response evidence briefs” at the request of VHA senior leadership; collaborates with HSR&D Center for Information Dissemination and Education Resources (CIDER) to develop a national dissemination strategy for all ESP products; and interfaces with stakeholders to effectively engage the program.

Comments on this evidence report are welcome and can be sent to Nicole Floyd, ESP CC Program Manager, at Nicole.Floyd@va.gov.

## EXECUTIVE SUMMARY

Hyperbaric oxygen therapy (HBOT) is designed to increase the supply of oxygen to our blood and tissues and is thought to have osmotic and angiogenesis effects. In normal air, the oxygen level is only around 21% and the atmospheric absolute (ATA) pressure at sea level is 760 mmHg. HBOT delivers 100% medical grade oxygen inside a chamber where the air pressure is raised at least 1.4 times greater than normal. HBOT has been described as a high-tech, high-touch treatment that can require daily 2-hour sessions for 8 to 10 weeks in which participants are assisted by one or more specially-trained HBOT technicians and are sometimes accompanied by other patients in ‘multiplace’ chambers.

#### Background

The ESP Coordinating Center (ESP CC) is responding to a request from the Center for Compassionate Innovation (CCI) for an evidence brief on the use of hyperbaric oxygen therapy (HBOT) for the treatment of traumatic brain injury (TBI), post-traumatic stress disorder (PTSD), or their co-occurrence. Findings from this evidence brief will be used to inform considerations of clinical use of HBOT in Veterans with TBI and/or PTSD.

#### Methods

To identify studies, we searched MEDLINE®, Cochrane Database of Systematic Reviews, Cochrane Central Register of Controlled Trials, and other sources up to September 2017. We used prespecified criteria for study selection, data abstraction, and rating internal validity and strength of the evidence.

Following certain types of injuries, our bodies may demand more oxygen than is available in the normal air we breathe to supply our cells with the fuel necessary for healing processes (eg, metabolism, cellular growth and repair). The FDA has cleared HBOT, commonly at 100% oxygen delivered between 1.5 and 3.0 ATA, as a combination treatment of increased oxygen (hyperoxia) at increased hydrostatic pressure for several types of injury indications such as wound healing, necrotizing infections, burns, radiation injury, and carbon monoxide poisoning.

Given the microscopic and macroscopic wounds to the white matter of the brain that have been attributed to traumatic brain injury (TBI) and post-traumatic stress disorder (PTSD), HBOT has also been explored as a therapy for these conditions. It has been used anywhere from between 3 to 71 months post-injury for mild TBI and within 24 hours for moderate to severe TBI. Among people who sustain mild TBI, up to 85% report persistent post-concussion symptoms (PPCS). Of those with PPCS, at least 90% have at least one co-occurring behavioral health condition, such as PTSD, and together these conditions have been labeled ‘post-deployment syndrome’. Among people with PPCS, mild TBI, PTSD, and post-deployment syndrome, many do not achieve remission with recommended treatments; thus, there remains a great need for innovative therapies.

In case series of TBI and/or PTSD populations, HBOT, mostly at 1.5 ATA, has statistically significantly improved cerebral blood flow and mean scores on post-concussion symptoms (PCS), PTSD, depression, and anxiety symptom checklists, as well as cognitive functioning and quality of life. Statistically significant mean improvement on physiological outcomes and checklists does not always equal clinically significant symptom benefits. To best demonstrate a net benefit, ideally HBOT would significantly improve clinically significant symptom response, function, and quality of life over a control group in randomized controlled trials (RCTs) of patients with mild to severe TBI and/or PTSD, without increasing risk of serious harm.

Available RCT evidence on using HBOT for TBI and/or PTSD has been controversial, widely debated, and potentially confusing. Department of Veterans Affairs/Department of Defense (VA/DoD)-affiliated researchers, a 2015 US Government Accountability Office report, and a June 2017 independent systematic review have concluded that HBOT is no better than sham. HBOT proponents have raised concerns that (1) HBOT's lack of effectiveness is due to use of a mischaracterized sham in the control groups – shams that were not true shams, but were actually therapeutic treatments and (2) bias against HBOT in VA/DoD RCT investigators that has led to flaws in the design and interpretation of HBOT research. Our independent and objective re-analysis of 16 RCTs found inconclusive evidence of HBOT's benefits at least for mild TBI and PTSD, no obvious indication that bias led to flaws in VA/DoD RCTs, and that current evidence does not clearly support any one argument over another for or against HBOT.

For mild TBI, in the most recent fully published VA/DoD-funded RCT (HOPPS – ‘Hyperbaric Oxygen Therapy for Persistent Post-concussive Symptoms After Mild Traumatic Brain Injury’), neither HBOT at 1.5 ATA nor room air at 1.2 ATA (sham) significantly improved the proportion of military service members with a clinically relevant improvement in post-concussive symptoms after 8 to 10 weeks (≥ 2-point improvement in Rivermead Post-Concussion Symptoms Questionnaire (RPQ—3)) compared to a no-chamber group – which an HBOT proponent described as the “only acceptable control group” (52% vs 33% vs 25%; P=0.24) because it lacks the potentially bioactive components of pressure and hyperoxia. Although this finding would seem to negate the ‘mischaracterized sham’ argument, we cannot rule out that the lack of improvement was due to a lack of adequate statistical power in the HOPPS RCT. Compared to sham (10.5% oxygen [O_2_] at 2.0 ATA, room air at 1.2-1.3 ATA), HBOT given at 1.5 ATA or 2.4 ATA for mild TBI has also not significantly improved mean scores on other post-concussive symptom checklists or quality of life outcomes in other fully published VA/DoD RCTs. Although an Israeli civilian RCT had more positive findings, we have more doubt about its reliability due to its greater methodological limitations.

HBOT also did not significantly improve PTSD symptoms compared to sham in 2 VA/DoD RCTs with concomitant mild TBI and PTSD (mean difference in PTSD score change, -1.49 points, 95% CI -5.79 to 2.80), but interpretation of these findings is limited by imprecision, as only 37% to 65% of study participants had documented PTSD.

In patients with moderate to severe TBI, to best demonstrate a clinically important benefit over usual care, ideally (1) HBOT would significantly reduce risk of mortality, (2) improve the functional status and quality of life of the survivors, and (3) these benefits could be attributed specifically to HBOT and not between-group differences in the intensity level of medical care and decisions about life-sustaining treatment. Per the most recent and comprehensive systematic reviews, only one of these conditions has been met.

HBOT may increase risk of some serious harms when used in moderate to severe TBI. In patients with moderate to severe TBI, HBOT increased risk of severe pulmonary complications, but not seizures or ear barotrauma, compared to sham. In mild TBI, no serious adverse effects were reported and there were no significant differences between HBOT and control groups in specific adverse events

Proponents of HBOT for mild TBI and/or PTSD claim that the main confusion in interpreting the findings of HBOT RCTs is that the control groups of 1.2 to 1.3 ATA have been mischaracterized as sham. Although the Hyperbaric Oxygen Committee of the Undersea and Hyperbaric Medical Society (UHMS) defines HBOT treatment pressure as at least 1.4 times higher than sea level, proponents of the ‘mischaracterized sham’ argument have suggested that lower pressures are actually active treatments with documented physiological and clinical effects. But the reliability of this claim is unclear because the documentation the proponents provide is not directly from patients with TBI and/or PTSD, but is from in vitro samples or patients with different conditions whose experiences with 1.2 to 1.3 ATA may or may not be comparable to TBI and/or PTSD, including chronic toxic encephalopathy, autism, cerebrovascular injury, epilepsy, or migraine.

Opponents claim HBOT has consistently shown no significant differences compared to sham, and thus is no more than a high-tech, high-touch ritual with “powerful nonspecific placebo effects”. We find 2 factors that preclude interpreting these findings as consistent evidence of no effect: (1) heterogeneity in HBOT protocol (1.5 ATA to 2.4 ATA), outcome assessment methods, timing (immediately following therapy, up to 6 weeks after discontinuation), and patient populations (most recent TBI ranged from 3 to 71 months) and (2) important methodological limitations.

In summary, the large treatment benefits demonstrated for HBOT in uncontrolled case series have not been easily replicated in well-controlled RCTs. Potential explanations for this include that the potential benefits are subtle and demonstration requires larger RCTs, HBOT is in fact ineffective, and/or the sham design has indeed been problematic. We disagree with both sides of the ongoing debate that the current evidence clearly points to one explanation over another. We simply still don't know. Pooling data from the HOPPS trial and the yet unpublished BIMA trial – both of which compared HBOT 1.5 ATA to room air at 1.2 ATA, and used the RPQ to measure PCS symptoms – could shed light on the debate. Broad usage of HBOT as an initial treatment for mild or moderate to severe TBI and/or PTSD in lieu of conventional treatments still does not appear warranted. When patients do not respond to and/or do not tolerate adequate trials of multiple conventional therapy options and are considering emerging treatment options, offering HBOT to Veterans with mild or moderate to severe TBI and/or PTSD is reasonable. Prior to HBOT use, clinicians and patients should consider its potential increased risk of barotrauma and/or pulmonary complications. A small-scale clinical demonstration may provide the opportunity to improve data collection on comorbidities, clinically relevant patient outcomes, patient expectations, and documentation of the types and durations of previous and ongoing treatments.

## PURPOSE

The ESP Coordinating Center (ESP CC) is responding to a request from the Center for Compassionate Innovation (CCI) for an evidence brief on the use of hyperbaric oxygen therapy (HBOT) to treat Veterans with traumatic brain injury (TBI) and post-traumatic stress disorder (PTSD) in whom other treatments have not been successful. Findings from this evidence brief will be used to inform considerations of clinical use of HBOT in Veterans with TBI and/or PTSD.

## BACKGROUND

### WHAT IS HBOT?

Hyperbaric oxygen therapy (HBOT) is designed to increase the supply of oxygen to our blood and tissues and is thought to have osmotic and angiogenesis effects. In the normal air we breathe, the level of oxygen is only around 21% and the atmospheric absolute (ATA) pressure at sea level is 760 mmHg. According to the Hyperbaric Oxygen Committee of the Undersea and Hyperbaric Medical Society (UHMS),^1^ HBOT involves breathing 100% oxygen while inside a chamber where the air pressure is at least 1.4 times greater than normal.

Certain types of injuries that damage our cells, impair blood flow, and dysregulate our metabolism can result in a deficiency in the amount of oxygen reaching our tissues (‘hypoxia’). Our bodies may demand more oxygen than is available in the normal air we breathe to supply our cells with the fuel for the necessary healing processes (eg, producing stem cells, inhibiting inflammation, reducing swelling, protecting cells from dying, promoting new blood vessel growth, regulating cellular metabolism, and promoting cellular growth and repair). The enhanced oxygen availability provided by HBOT has been associated with some of these healing mechanisms. As a medical device, hyperbaric chambers require 510(K) clearance from the United States Food & Drug Administration (FDA).^2^ As of 2/1/18, HBOT - commonly delivered at 100% oxygen between 1.5 and 3.0 ATA, and defined as a combination treatment of increased oxygen (hyperoxia) at increased hydrostatic pressure - currently has 13 FDA-cleared indications, including treatment of air or gas embolism, carbon monoxide poisoning, decompression sickness (‘the bends’), and soft tissue necrosis (see Appendix A in the supplemental materials for entire list) – none of which are PTSD or TBI.^3^

There are many types of hyperbaric chambers available that vary in features such as whether they are constructed of steel (‘hard’) or made of acrylic or urethane (‘soft’), or accommodate only one patient (‘monoplace’) or more than one patient (‘multiplace’) at a time. HBOT chambers involve the use of medical-grade oxygen and are ideally operated by specially trained technicians who work under the supervision of a clinician.^4^ Depending on initial condition, tolerability of treatment, and treatment response, HBOT duration and frequency can vary from a few sessions to multiple sessions a day, 5 days a week, for 6 to 10 weeks. HBOT can be a highly social experience. Depending on the treatment plan, patients may have daily interactions with a team of nurses and hyperbaric technicians, and may interact with other participants in multiplace chambers.

### WHY HBOT FOR TBI/PTSD?

Whether traumatic brain injury is mild or severe, patients can experience persistent and sometimes lifelong physical, cognitive, and emotional changes. Significant overlap exists among symptoms of TBI, persistent post-concussion symptoms (PPCS), and PTSD. In cases of moderate to severe TBI, defined as Glasgow Coma Scale (GCS) < 13 (plus normal or abnormal structural imaging, alteration of consciousness of > 24 hours, loss of consciousness of > 30 minutes, and posttraumatic amnesia of > 1 day), care is centered around life-saving measures as necessary, such as decompressive craniectomy, barbiturate administration, and seizure prophylaxis.^5^ However, mortality rates are still 19% to 36%^6^ and many survivors (> 50%) experience some degree of disability, cognitive impairment, behavioral changes, and are at increased risk for a multitude of neurological diseases that can result in moderate to severe functional impairment.^7,8^

Among people who sustain a mild TBI (loss of consciousness of 0 to 30 minutes, normal structural imaging, alteration of consciousness, posttraumatic amnesia ≤ 24 hours, and GCS of 13 to 15), cognitive deficits in the first 2 weeks post-injury are common, but many recover within 30 days.^9^ However, many report persistent post-concussion symptoms (PPCS) including physical (ie, headache, dizziness, vision), cognitive (ie, memory, focus, judgment), and emotional (ie, depression, anger, anxiety) changes that last longer than 3 months following their injury and may take 6 months to a year to completely resolve.^10-12^ Of those with PPCS, at least 90% have at least one co-occurring behavioral health condition such as depression, substance use disorder, or posttraumatic stress disorder, as well as chronic pain, sensory amplification, and medically unexplained symptoms, and together these conditions have been labeled ‘post-deployment multisymptom disorder’ or ‘post-deployment syndrome’.^13,14^ Reasons for lack of expected improvement can be complex and multidimensional, including failure to receive evidence-based interventions due to variability in clinician judgment and patients' barriers to access and adherence, or presence of confounding prognostic factors, including medical and/or psychiatric comorbidities, premorbid personality traits, injury characteristics, biological and psychosocial factors, and/or inadequate psychoeducation.^15,16^ Many PPCS symptoms are similar to those of PTSD, and there is a high prevalence (50-80%) of PTSD among those diagnosed with PPCS or mild TBI.^14,17^ It has been hypothesized that neuronal damage following TBI may be involved in the development of neuropsychiatric disorders such as PTSD.^17^ In those with no history of physical head trauma, exposure to a life-threatening event or traumatic emotional experience can lead to abnormal activation of certain brain regions, such as the amygdala, which may also be involved in the development of PTSD. Discussion exists about the relationship between PTSD and TBI, whether PTSD-like symptoms in TBI should be classified as PTSD or a TBI symptom,^18^ or whether PTSD with and without a history of physical head trauma may have different mechanisms and/or should be classified as different subtypes (Appendix G – peer review disposition document).

Although the evidence base is limited,^19,20^ VA/DoD Clinical Practice Guidelines (VA/DoD CPG) for concussion-mild TBI recommend optimizing symptom improvement, functioning, well-being, and quality of life through a primary care, symptom-driven, personalized, and collaborative stepped-care approach including psychoeducation, cognitive rehabilitation, nonpharmacologic interventions such as sleep hygiene, education, dietary modification, physical therapy, relaxation, behavioral health treatments, and/or pharmacologic interventions (see Appendix B in supplemental materials for full list of related guidelines).^21^ VA/DoD guidelines for PTSD recommend individual, manualized, trauma-focused psychotherapy over pharmacologic and other non-pharmacologic interventions as primary treatment.^22^

Although some patients diagnosed with PPCS, mild TBI, PTSD, or post-deployment syndrome may not receive appropriate guideline-recommended treatments, among those that do, a large proportion have refractory symptoms, highlighting the great need for innovative treatments that can improve the health and well-being of this patient population. HBOT is one innovative treatment being explored for these difficult-to-treat conditions, given the potential for HBOT to promote healing of the microscopic and macroscopic wounds to the white matter of the brain that have been attributed to traumatic brain injury (TBI) and post-traumatic stress disorder (PTSD) (eg, shearing of axonal pathways and small blood vessels,^23-25^ including the common secondary injuries of cerebral hypoxia, increased cranial pressure, disruption of brain tissue and cellular metabolism, and inflammation).^26^ In animal models of TBI, HBOT 1.5 ATA to 3 ATA has increased tissue oxygenation and neuronal stem cell proliferation and reduced inflammation, pressure in the brain and cellular death.^27^ In TBI patients, HBOT 1.5 ATA to 2.5 ATA improved cerebral blood flow^23,28^ and glucose metabolism.^29^ Gene array analyses have demonstrated positive impacts on gene expression.^27,30^

### DEBATE ON HBOT FOR TBI/PTSD

Although RCTs are available, HBOT for TBI and/or PTSD continues to be promoted largely based on case series and anecdotal testimonials. For example, in a few small military cohorts of 45 service members with chronic blast-induced mild to moderate TBI, PPCS, and PTSD, forty 60-minute sessions of HBOT 1.5 ATA resulted in 36% to 96% increases in perceived quality of life and percentage back to normal cognitive, physical, and emotional function reported.^28,31^ There are also many testimonials and anecdotal reports of HBOT as a “miracle cure” for TBI and/or PTSD that is “giving people back their lives.”^32,33^ Based on such anecdotal reports, HBOT has gained some political advocacy, such as from Congressman Walter B. Jones in North Carolina and other lawmakers, which has resulted in Oklahoma, Texas, and Indiana passing legislation establishing funding to provide eligible Veterans with TBI and/or PTSD with access to HBOT.^34^ To address anecdotal reports, on 8/22/2013 FDA issued a Consumer Update statement that “HBOT has not, however, been proven to be the kind of universal treatment it has been touted to be on some internet sites” and listed brain injury as one of the conditions for which “the safety and effectiveness of HBOT has not been established.”^35^

Available RCT evidence on using HBOT for TBI and/or PTSD has been controversial, widely debated, and potentially confusing. Skeptics have described HBOT as no more than a high-tech, high-touch ritual^36^ with “powerful nonspecific placebo effects”^37^ due to the “act of engaging in daily HBO treatment sessions for more than one month,”^37^ that is often accompanied by “greatly reduced duty schedules” and “enhanced access to leisure time.”^24^ HBOT for TBI and/or PTSD has not yet been endorsed for broad use or coverage in practice guidelines and payer policies (Appendix B).

Proponents of HBOT have stated that the main confusion in interpreting the findings of HBOT RCTs is that the control groups of 1.2 to 1.3 ATA have been mischaracterized as “sham”, when they are actually active treatments that are effective in their own rights. The suggestion that the low-pressure control groups are therapeutic is based on the premise that the slight increase in air pressure and/or the minor increases in oxygen partial pressure are biologically and physiologically active.^38,39^ HBOT proponents have also raised concerns about bias against HBOT in VA/DoD RCT investigators that has led to flaws in the design and interpretation of HBOT research.^40-46^

### CONSIDERATIONS FOR EVALUATING HBOT AS AN EMERGING TREATMENT FOR TBI/PTSD

The high prevalence and burden of TBI and/or PTSD combined with the lack of broadly effective treatments has created a definite need to identify additional therapeutic options. If the types of clinical ritualistic components that characterize HBOT are of interest (ie, high-tech, high-touch, mental break), other innovative treatments for TBI and/or PTSD that might be reasonable to explore or to compare HBOT to include HBNO2 (mild hyperbaric pressure of 1.3 ATA and regular air) and float therapy. For example, with float therapy, also known as sensory deprivation and restricted environmental stimulus therapy (REST), people can experience a “nearly 100 percent stimuli-free environment” by effortlessly floating in a futuristic pod filled with 150 gallons of skin temperature water and 1,000 pounds of Epsom salt where there is absolutely no light and sound and all “routine environmental and physical stimulation, such as light, sound, and gravity” are removed.^47,48^ The theory behind REST is that the sensory deprivation could stimulate reparative synaptic changes in the brain (‘rewiring’ or ‘neuroplasticity’) and some preliminary functional MRI case reports have shown REST has increased activity in brain regions commonly affected by TBI.^47^ Also, some have suggested exploring the use of regular air delivered at mild hyperbaric pressure of 1.3 ATA (HBNO2), as it has shown some clinical improvement and is “significantly less expensive and logistically simpler treatment” than HBOT.^23^

Regardless of the innovative intervention, to best assess the impact, the ideal evidence would include individuals with well-documented TBI and/or PTSD, would document their existing comorbidities and baseline severity and duration of symptoms, and would evaluate the treatment effects on clinically important benefits as recommended by the VA/DoD CPG (including functioning, well-being, and quality of life). At least for HBOT, to help add meaning to why any such improvements occur, and potentially shed light on the sham debate, clinical evaluation should be done in tandem with neuroimaging and assessment of the role of potentially exaggerated patient expectations that may have resulted due to publicized reports of HBOT as a “miracle cure”. As any positive effects of HBOT should not come at the expense of increased risk of serious harm, assessment of the adverse effects of HBOT is also important. To best assess the generalizability of available evidence on HBOT to Veterans with TBI and/or PTSD in whom other treatments have been unsuccessful, ideally the types and durations of previous and ongoing treatments would be well-documented.

The aim of this evidence brief is to evaluate the potential impact of HBOT on TBI and/or PTSD on certain clinically important benefits and harms and evaluate whether they differ based on patient characteristics and variation in HBOT protocol.

## SCOPE

Objective: To synthesize the evidence regarding the potential benefits and risks of hyperbaric oxygen therapy (HBOT) for traumatic brain injury (TBI), post-traumatic stress disorder (PTSD), or their co-occurrence.

### KEY QUESTIONS

KQ1: What are the potential benefits of HBOT for the treatment of TBI and/or PTSD?

KQ2: What are the potential risks of using HBOT for the treatment of TBI and/or PTSD?

KQ3: Do the benefits or risks of HBOT differ per patient characteristics (eg, patient demographics, comorbidities, disease severity)?

KQ4: Do the benefits or risks of HBOT differ per treatment protocol (eg, number of sessions, amount of pressure, inpatient vs outpatient treatment)?

### ANALYTIC FRAMEWORK

The analytic framework below (Figure 1) illustrates the [underlined: P]opulation, [underlined: I]nterventions, [underlined: C]omparators, [underlined: O]utcomes, [underlined: T]iming, [underlined: S]etting, and [underlined: S]tudy designs (PICOTSS) of interest that guided this review and their relationship to the key questions. This evidence brief addresses the evidence evaluating the direct link between HBOT and health and clinically significant outcomes (Key Question 1) and potential risks (Key Question 2). Key Questions 3 and 4 examines whether the benefits and/or risks of HBOT differ per patient characteristics (eg, patient demographics, comorbidities, disease severity) or per treatment protocol (eg, number of sessions, amount of pressure, inpatient vs outpatient treatment).

Figure 1 Analytic Framework

### ELIGIBILITY CRITERIA

The ESP included studies that met the following criteria:

- [underlined: P]opulation: Patients with TBI, PTSD, or the co-occurrence of TBI and PTSD
- [underlined: I]ntervention: HBOT, any protocol
- [underlined: C]omparator: Any. Regardless of the debate over whether or not the comparator groups of room air at < 1.5 ATA have been mischaracterized as ‘sham’ and are actually a therapeutic dose of HBOT (described above), for the sake of describing the included study results, we will refer to them as sham.
- [underlined: O]utcomes:
  ○ [underlined: Benefits]: Mortality, morbidity, quality of life, functional capacity (eg, social, employment, activities of daily living, etc), clinically significant TBI and PTSD clinical symptom response (eg, global, physical, behavioral, cognitive and and/or psychological symptoms), and duration of clinical symptom response or improvement. An example of clinically significant clinical symptom response is the proportion of patients with ≥ 2-point change in Rivermead Post-Concussion Symptoms Questionnaire. We will accept any definition of clinically significant clinical symptom response. We will consider measures of mean change in clinical symptoms to address gaps in clinical response measures. We will exclude intermediate physiologic measures, such as intracranial pressure, cerebrospinal fluid lactate levels, or changes in cerebral blood flow that patients may not subjectively experience.
  ○ [underlined: Harms:] Any (ear problems, pulmonary complications, headache, nausea, etc)
- [underlined: T]iming: Any
- [underlined: S]etting: Any
- [underlined: S]tudy design: Systematic reviews (prioritized based on Robinson et al^49^), randomized controlled trials, and concurrently controlled cohort studies. We will consider case series (N>1) only to address gaps in evidence from studies with control groups. We will exclude case reports (N=1).

## METHODS

We followed the steps in the systematic review process outlined below. For complete search strategies, see Appendix C in supplemental materials. A draft version of this report was reviewed by peer reviewers as well as clinical leadership. Their comments and our responses are presented in the Supplemental Materials, Appendix G.

Figure 2 Review Methods

1 Robinson . Twelve recommendations for integrating existing systematic reviews into new reviews: EPC guidance. J Clin Epidemiol. 2016 ;

2 Whiting . ROBIS: A new tool to assess risk of bias in systematic reviews was developed. J Clin Epidemiol. 2016 ;

3 McDonagh . Methods for the drug effectiveness review project. BMC Med Res Methodol. 2012 ;

4 Berkman . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: Agency for Healthcare Research and Quality;2013 .

## RESULTS

The literature flow diagram (Figure 1) summarizes the results of the search and study selection processes. See Appendix D in supplemental materials for full list of excluded studies.

### LITERATURE FLOW

Figure 3 Literature Flowchart

### LITERATURE OVERVIEW

Our search identified 282 unique, potentially relevant articles. We included 3 good-quality systematic reviews^26,50,51^ which included 15 RCTs (in 19 publications),^23-25,29,52-68^ and one subsequently published RCT (in 4 publications),^69,70^ for a total of 26 publications (Table 1; see supplemental materials Appendix E for full evidence tables). Five RCTs^23-25,53-55,63,66,67,69,70^ reported outcomes for patients with mild TBI with or without PTSD, 10 RCTs^29,52,57-62,64,65,68^ reported outcomes for patients with moderate to severe TBI, and 1 RCT^56^ failed to report on TBI severity. No studies focused exclusively on patients with PTSD or separately analyzed PTSD subgroups, and the prevalence of PTSD in these studies was 36%^66^ to 65%.^63^ The majority of studies were in mostly male populations with a mean age range from 20 to 44 years. The number of HBOT sessions ranged from 3 to 84 and exposure lasted from 1 to 2 hours. We generally concurred with the ratings from previous systematic reviews that most studies had ‘few’ or acceptable levels of methodological limitations. The majority of RCTs were short-term (≤ 10 weeks) and none evaluated durability of effects.

Table 1 Characteristics of Included Studies

Population | Evidence | Patient Characteristics | HBOT Characteristics | Sham Characteristics | Methodological limitations
Mild TBI with or without PTSD | 5 RCTs^23-25,53-55,63,66,67,69,70^ N= 320 | Service members or Veterans: 0 to 100% % male: 39 to 100% Mean age range: 21 to 53 years Time from TBI to HBOT initiation: 3 to 71 months | # sessions: 30 to 40 Exposure: 60 to 117 minutes Duration: 8 to 12 weeks ATA: 1.3 to 2.4 % O_2_: 100% | # RCTs with sham: 3^24,25,53-55,63,66,67,69,70^ # sessions: 30 to 40 Exposure: 60 to 117 minutes Duration: 8 to 12 weeks ATA: 1.2 to 1.3 % O_2_: 10.5 to 75% | 4/5 had few^*^ or acceptable^† 50,51^ 1/5 not assessed^69,70^
Moderate to severe TBI | 10 RCTs^29,52,57-62,64,65,68^ N= 747 | Service members or Veterans: 0% % male: 62 to 100% Mean age range: 23 to 40 years Time from TBI to HBOT initiation: ASAP, ≤24 hours to 10 days | # sessions: 3 to 84 Exposure: 40 to 120 minutes Duration: 3 to 52 days ATA: 1.5 to 2.55 % O_2_: 100% | # RCTs with sham: 1^57^ # sessions: 3 Exposure: 180 minutes Duration: 3 days ATA: 1.0 % O_2_: 100 % | 6/10 had few^*^ or acceptable^† 50,51^ 3/10 had few^† 51^ 1/10 had unacceptable levels^*,26^

* Cochrane Collaboration's Risk Assessment Tool

† SIGN 50 tool

One RCT^56^ did not report TBI severity was omitted from this table.

Abbreviations: ATA=atmosphere absolute (pressure), ASAP=as soon as possible, HBOT=hyperbaric oxygen therapy, O_2_=oxygen, TBI=traumatic brain injury, SIGN= Scottish Intercollegiate Guidelines Network

We identified one potentially relevant study on mild TBI (BIMA) that is pending publication, and additional ongoing studies (see Appendix F in supplemental materials for details).^71^ None of the ongoing studies are expected to address important gaps in the literature. We sent requests for scientific information to 20 HBOT chamber manufacturers to identify additional published, unpublished, and supplemental data on published studies, but did not receive any submissions.

### KQ1 WHAT ARE THE POTENTIAL BENEFITS OF HBOT FOR THE TREATMENT OF TBI AND/OR PTSD?

#### Mild TBI

The 39% to 96% increase in perceived quality of life and percentage back to normal cognitive, physical, and emotional function reported in case series^28^ have not been easily replicated in the most well-controlled RCTs with the greatest relevance to Veterans, which were conducted by the VA/DoD (Table 2). HBOT has not significantly led to a clinically important improvement in TBI and/or PTSD symptoms, function, or quality of life compared to an adequate control group, and RCTs have not shown that any such improvements are durable beyond the few weeks following therapy discontinuation.^23-25,63^ Neither has HBOT been shown to be consistently ineffective. Although HBOT given at 1.5 ATA to 2.4 ATA generally did not significantly improve post-concussive symptom or quality of life outcomes compared to control groups of 1.2-1.3 ATA in the 3 published VA/DoD RCTs, heterogeneity in HBOT protocol (1.5 ATA to 2.4 ATA), outcome assessment methods and timing (immediately following therapy, up to 6 weeks after discontinuation), and patient populations (most recent TBI ranged from 3 to 71 months), and important methodological limitations preclude interpreting findings as consistent evidence of no effect. Although an Israeli civilian RCT had more positive findings, we have more doubt about its reliability due to its greater methodological limitations.

Table 2 Post-concussive Symptom and Quality of Life Outcomes for HBOT versus Sham in VA/DoD RCTs

Author Year Size | Time of most recent TBI occurrence before randomization | % with PTSD | HBOT protocol | Sham protocol | Post-concussive symptom outcomes | QOL outcomes | Comments
Wolf 2012-2015^25,35,53,54^ N=50 | NR, range of 3-71 months | Mean baseline PCL-M: 49-50 pts | 100% O_2_ at 2.4 ATA | Room air at 1.3 ATA | PCL-M composite mean score at baseline/6 weeks post-exposure/change: 50.0/41.6/-8.4 vs 48.9/40.6/-8.3 (P=0.28) | NR | Highest dose; possible “overdose” Outcomes measured 6 weeks after completion
Cifu/Walker 2014^24,55,66,67,73^ N=60 | 8.5 months | % with PCL ≥ 50 pts: 36.5% | 75% O_2_ at 2.0 ATA (1.5 ATA equivalent), 100% 0_2_ at 2.0 ATA (2.0 ATA equivalent) | 10.5% O_2_ at 2.0 ATA | RPQ total score pre/post-compression/change^†^ for 1.5 ATA vs 2.0 ATA vs sham: 29.33/30.57/+1.24 vs 30.44/26.67/-3.77 vs 32.81/32.86/+0.05; P=0.19 for post-compression | NR | Most recent TBI Unique protocol of 2.0 ATA for all groups and varying O_2_ levels
Miller 2015^63^ N=72 | 23 months | 65% | 100% O_2_ at 1.5 ATA | Room air at 1.2 ATA; no chamber | % patients ≥ 2-pt RPQ-3 improvement for HBOT vs sham vs no chamber: 52% vs 33% vs 25%; P=0.24 | SF-36: Results favored sham on 7 of 8 domains | Underpowered; needed 72, only evaluated 64
Weaver 2016 / 2017^*,70,71^ N=71 | Mean NR, 72% were 1-5 years from their most recent TBI | 49% | 100% O_2_ at 1.5 ATA | Room air at 1.2 ATA | RPQ-3 mean change difference: - 1.5, P=0.01 | NR | Unpublished

* Conference Proceeding

† EPC-calculated: increase=worsening, decrease=improvement

Abbreviations: ATA=atmosphere absolute, PCL-M=Post-traumatic Disorder Check List-Military Version, O_2_=oxygen, RPQ-3=Rivermead Post-Concussion Symptoms Questionnaire-3 subscale, SF-36=(Rand) 36-Item Short Form Health Survey, TBI=traumatic brain injury

##### VA/DOD Studies

Four VA/DoD RCTs have compared HBOT to conditions characterized as sham in which room air was delivered at low-pressure ATA (1.2 to 1.3)^25,63,71^ or low oxygen (10.5%) was delivered at 2.0 ATA^24^ to simulate “middle ear pressure effects and adiabatic heating and cooling effects of pressurization and depressurization”. In the most recent fully published DoD-funded RCT (HOPPS), neither HBOT 1.5 ATA nor room air at 1.2 ATA (sham) significantly improved the proportion of military service members with a clinically relevant improvement in post-concussive symptoms after 8 to 10 weeks (≥ 2-point improvement in Rivermead Post-Concussion Symptoms Questionnaire (RPQ—3)) compared to a no-chamber group – which an HBOT proponent described as the “only acceptable control group because it is the only control group which lacks the potential bioactive components of pressure and hyperoxia”^72^ (52% vs 33% vs 25%; P=0.24). Although this finding would seem to negate the ‘mischaracterized sham’ argument, we cannot rule out that the lack of improvement was due to a lack of adequate statistical power in the HOPPS RCT. Although this study required 72 patients for adequate statistical power, only 64 were included in their analysis. No significant differences between HBOT, low-pressure, and no-chamber groups were found in various quality of life SF-36 subscales, but results generally favored the low-pressure group over the HBOT group. Otherwise, compared to the low-pressure 1.2 to 1.3 ATA control groups in the other VA/DoD RCTs, HBOT significantly improved post-concussion symptoms only when delivered as 100% oxygen at 1.5 ATA, as described in the most recent VA/DoD RCT, which has not yet been fully published in a peer-reviewed journal (BIMA, Brain Injury and Mechanisms of Action study).^71^ According to the RPQ-3 2-point threshold used in the Miller 2015 RCT, though, this 1.5 difference in BIMA, while statistically significant, may not be clinically relevant. In the 3 other VA/DoD RCTs,^24,25,63^ 1.5 ATA, 2.0 ATA, and 2.4 ATA HBOT did not significantly improve PCS symptom response or quality of life. Factors including (1) heterogeneity in HBOT protocol (1.5 ATA to 2.4 ATA), outcome assessment methods and timing (immediately following therapy, up to 6 weeks after discontinuation), and patient populations (most recent TBI ranged from 3 to 71 months), and (2) important methodological limitations preclude interpreting these findings as consistent evidence of no effect. Also, the generalizability of the VA/DoD RCT findings to Veteran population is unclear, as the majority of participants in the VA/DoD studies were active-duty service members who were receiving paid travel, greatly reduced duty schedules, and enhanced access to leisure time during their participation the in the RCTs.^24^

Perhaps most important is that HBOT still lacks evidence from RCTs on the durability of its potential benefits. HBOT's improvements in the RPQ-3 compared with sham in the unpublished BIMA have been reported to “regress” at 6 and 12 months.^71^

##### Israeli Civilian RCT

HBOT has shown promise in Israeli civilians at the late chronic stage of mild TBI (mean of 33 months post-injury) after a protocol of 40 sessions, 5 days a week, 60 minutes each, with 100% oxygen at 1.5 ATA.^23^ This HBOT protocol improved quality of life compared to a control group of ‘no treatment’ (-17.7% vs +4.7%; P=not reported; baseline = 7.70 to 7.87 on European Quality of Life-5 Dimensions (EQ-5D), score of 5 = no problems; score 25 = extreme difficulties).^23^ This same HBOT protocol also improved quality of life in the ‘no treatment’ control group when they crossed over to HBOT (-16.3% vs +4.7%; P=not reported). While encouraging, this RCT has several methodological limitations, the greatest of which is that we can't rule out the ‘participation effect’, as the only comparison was to an unblinded, no-treatment control group. Second, this is a single, underpowered study. The number of patients analyzed in the control group was lower than the N=31 needed to detect a 10% or greater improvement on the neurocognitive test score, and it is unclear how that power calculation applies to the EQ-5D. Finally, the analysis excluded more patients in the control group overall (22% vs 11%), the majority of which were due to “technical performance problems in their cognitive tests” (16% vs 5%), which could have been related to poorer neurocognitive and quality of life outcomes. Additionally, the applicability of the findings from these studies to Veterans with mild TBI is unclear because this study included 57% women with a higher mean age than the VA/DoD populations, and the comparability of the potential cumulative effects of multiple TBIs, their concomitant secondary diagnoses (ie, PTSD), or other previous or concurrent TBI treatment are unknown because they were not reported.

#### Moderate to Severe TBI

In patients with moderate to severe TBI, to best demonstrate a clinically important benefit over usual care, ideally (1) HBOT would significantly reduce risk of mortality, (2) improve the functional status and quality of life of the survivors, and (3) these benefits could be attributed specifically to HBOT and not between-group differences in the intensity level of medical care and decisions about life-sustaining treatment. According to the 3 good-quality systematic reviews, only one of these conditions has been met.^26,50,51^ HBOT (1.5 to 2.55 ATA) consistently reduced odds of death in 2 meta-analyses.^26,50^ HBOT reduced the relative risk of mortality in the earlier meta-analysis of 3 RCTs published between 1974 and 1992 (0.69, 95% CI 0.54 to 0.88, P = 0.003).^26^ In the 2016 review by Wang et al of 3 newer RCTs published between 1992 and 2013, HBOT reduced the odds of mortality by 68% (OR=0.32, 95% CI 0.18 to 0.57)^50^ and improved Glasgow Coma Scale (GOS) by 278% (OR=3.78, 95% CI 1.23 to 11.63) compared to the control groups based on 3 overall good-quality RCTs.^50^ The GOS improvement was driven by a single study^65^ performed in China with a control group where the mortality rate was almost double that observed in other included studies.^50^ A sensitivity analysis after removal of this study^65^ found no significant difference in GOS improvement (OR [random effects]=2.18, 95% CI 0.92 to 5.17).^50^

The applicability of these results to Veterans is likely low because none of these studies included current service members or Veterans or those with blast-induced TBI. Furthermore, the majority of TBIs in Veterans are mild – moderate to severe TBIs only make up 9.4% and 1.1%, respectively, of TBIs sustained by service members since 2000.^74^

#### PTSD

Little is known about the benefits of HBOT in patients with PTSD. While no studies focused exclusively on patients with PTSD, several studies included patients with concomitant TBI and PTSD. None of these studies did a responder analysis of clinically important PTSD improvements. A meta-analysis of the 2 RCTs^24,25,53,66,67^ by Cifu et al and Wolf et al that reported complete pre- and post-treatment PTSD score data showed no significant difference in PTSD score change between HBOT and control groups (pooled difference in means (fixed effects) = -1.45, 95% CI -5.79 to 2.80).^50^ The applicability of these findings to patients with PTSD is unclear because the prevalence of PTSD in these studies was only 36%^66^ to 65%^63^ and PTSD subgroups were not separately analyzed. HBOT also did not significantly improve PTSD symptoms compared to sham in the most recent HOPPS trial, which was not included in the meta-analysis.^63^

### KQ2 WHAT ARE THE POTENTIAL RISKS OF USING HBOT FOR THE TREATMENT OF TBI AND/OR PTSD?

Minor ear problems, such as ear pain and barotrauma, appear to be the most common adverse effects of HBOT. Serious harms of HBOT appear limited to use in moderate to severe TBI, in which HBOT increased risk of severe pulmonary complications, but not seizures or ear barotrauma. In mild TBI, no serious adverse effects were reported and there were no significant differences between HBOT and control groups in specific adverse events. Substantial uncertainty remains, as evidence was likely underpowered to detect serious but rare adverse effects.

In mild TBI, HBOT did not lead to any serious adverse events and there were no significant differences in withdrawals due to adverse events compared with sham (2% vs 2%). There was a numerically higher rate of ear barotrauma for HBOT compared to sham when given at higher dosages (42% vs 16%, P = 0.57 at 2.4 ATA for 90-minute sessions,^54^ 8% vs 0% at 1.5 ATA for 60-minute sessions^63^), but the difference was not statistically significant. The second most common adverse event was headache, reported in 4 HBOT patients (16.7%) and 3 sham patients (12.5%).^63^ Only 2 of 4 mild TBI studies, involving only 95 participants, reported harms.^25,53,54,63^

In moderate to severe TBI, HBOT significantly increased risk of severe pulmonary complications (13% vs 0%, RR=15.57, 95% CI 2.11 to 114.72, N=228),^59,68^ but not seizures (2.3% vs 0%, RR=5.0, 95% CI 0.24 to 102.6, N=168)^59^ or haemotympanum (2.3% vs 0%, RR=5.0; 95% CI 0.24 to 102.6, N=168) compared to the control groups.^26,59^ The consistency of these effects is unclear, though, as adverse effects were only reported in 3 studies, of 272 patients.^59,65,68^ Reported minor adverse effects include: polypnea (rapid breathing), expiratory dyspnea (difficulty breathing), tinnitus (ringing in the ear), aural fullness (pressure in the ear), disequilibrium, vertigo, and nausea.^59,65,68^

Because evidence on harms from RCTs of HBOT for TBI and PTSD is likely limited by imprecision, we also considered evidence on harms from other populations. HBOT is generally believed to be safe when used as directed for FDA-cleared indications, none of which include TBI or PTSD.^3,75^ Per the Undersea and Hyperbaric Medical Society, middle ear barotrauma and sinus squeeze are the 2 most common side effects of hyperbaric oxygen in other populations, with an incidence of approximately 2%.^76^ In RCTs of mild TBI, rate of inner ear barotrauma was 8% and 5.91% for “ear barotrauma”.^25,53,54,63^ HBOT 1.5 ATA to 2.4 ATA was associated with a 0.3% rate of seizures based on the most recent and one of the largest retrospective cohorts of 2,334 patients treated for a wide variety of conditions at the Sagol Center of Hyperbaric Medicine and Research in Israel between June 2010 to December 2014.^77^ In 168 patients with moderate to severe TBI, rates of seizures were higher for HBOT 1.5 ATA (2.3%).^59^ Although this may reflect a greater baseline seizure risk in patients with moderate to severe TBI compared to the likely stable outpatient status of the study by Hardanny et al,^77^ this is still higher than critically ill carbon monoxide poisoned patients who were treated with higher pressures of 2.45 ATA (0.3%) or 3.00 ATA (2.0%), but not 2.80 ATA (3.0%).^78^ Therefore, the magnitude of seizure risk in patients with TBI and/or PTSD remains uncertain due to imprecision and inconsistency.

### KQ3 & 4 Do the benefits or risks of HBOT differ per patient characteristics (eg, patient demographics, comorbidities, disease severity) or treatment protocol (eg, number of sessions, amount of pressure, inpatient vs outpatient treatment)?

Because of heterogeneity in patient populations and outcome assessment methods, we could not assess if or how benefits and risks of HBOT may differ per patient characteristics or treatment protocol.

## SUMMARY AND DISCUSSION

HBOT has the potential to fill a great need by improving the health and well-being of the many patients with TBI and/or PTSD who are refractory to recommended treatments. Interpretation of evidence on using HBOT for TBI/PTSD has been controversial, widely debated, and potentially confusing. Our independent and objective examination of 16 RCTs found that the large treatment benefits demonstrated for HBOT in uncontrolled case series have not been easily replicated in well-controlled RCTs. Potential explanations for this include that the potential benefits are subtle and demonstration requires larger RCTs, HBOT is in fact ineffective, and/or the sham design has indeed been problematic. We are unconvinced that the current evidence clearly points to one explanation over another. We simply still don't know.

For mild TBI, in the most recent fully published VA/DoD-funded RCT (HOPPS), neither HBOT 1.5 ATA nor room air at 1.2 ATA (sham) significantly improved the proportion of military service members with a clinically relevant improvement in post-concussive symptoms after 8 to 10 weeks (≥ 2-point improvement in Rivermead Post-Concussion Symptoms Questionnaire [RPQ—3]) compared to a no-chamber group (52% vs 33% vs 25%, P=0.24). Although the lack of difference between sham and no chamber had the potential to negate the ‘mischaracterized sham’ argument, the imprecision in HOPPS RCT precluded any conclusions. Compared to sham (10.5% O_2_ at 2.0 ATA, room air at 1.2-1.3 ATA) HBOT given at 1.5 ATA to 2.4 ATA for mild TBI also has not significantly improved mean scores on other post-concussive symptom checklists or quality of life outcomes in other fully published VA/DoD RCTs.^24,25,63^ HBOT also did not significantly improve PTSD symptoms compared to sham in 2 VA/DoD studies with concomitant mild TBI and PTSD (mean difference in PTSD score change, -1.49 points (95% CI -5.79 to 2.80)), but interpretation of these findings is limited by imprecision, as only 37% to 65% of study participants had documented PTSD. In patients with moderate to severe TBI, although HBOT may significantly reduce risk of mortality, it is unclear whether the reduction is due to HBOT and not differences in intensity level of medical care and decisions about life-sustaining treatment, or whether functional status and quality of life is meaningfully improved in survivors. Serious harms of HBOT appear limited to use in moderate to severe TBI, in which HBOT increased risk of severe pulmonary complications (13% vs 0%, RR=15.57, 95% CI 2.11 to 114.72, N=228), but not seizures or ear barotrauma. In mild TBI, no serious adverse effects were reported and there were no significant differences between HBOT and control groups in specific adverse events.

Proponents of HBOT for mild TBI and/or PTSD suggest that the main confusion in interpreting the findings of controlled HBOT trials is that the 1.2 to 1.3 ATA control groups have been mischaracterized as sham. Although the Hyperbaric Oxygen Committee of the Undersea and Hyperbaric Medical Society defines HBOT treatment pressure as at least 1.4 times higher than sea level,^1,24^ proponents of the ‘mischaracterized sham’ argument have suggested that lower pressures are actually active treatments with documented physiological and clinical effects. The evidence of increased blood flow effects of the low-pressure room air conditions that support the ‘mischaracterized sham’ argument are from samples with chronic toxic encephalopathy, autism, cerebrovascular injury, epilepsy, or migraine and not specific to TBI, and also have the potential to be the result of participation effects.^79^

HBOT proponents have also claimed that VA/DoD RCT investigators (and the medical field in general) are biased against HBOT (and other emerging treatments)^43,44^ and that this bias has led to flaws in the design and interpretation of the VA/DoD RCTs that intentionally or unintentionally underestimate HBOT's effects.^41^ In order to be complete, any systematic review needs to investigate and address any concerns about the quality, relevance, and integrity of its included studies. One claim is that a VA/DoD investigator bias against HBOT led to a design that intentionally underestimated HBOT's effects in the Cifu RCT^24,55,66,67^ because it didn't match the HBOT parameters used in the prior Wolf RCT.^25,53,54^ We disagree with the claim that HBOT parameters used in Cifu RCT clearly reflect levels known to be sub- or supra-therapeutic. First, as HBOT parameter best practices for TBI have not yet been identified, some variability among RCTs is inevitable. Second, as the HBOT parameters used in the Wolf RCT did not produce clinically relevant improvement, replication is not clearly warranted. Finally, we interpret the selection of the pressures for the Cifu RCT (2.0 and 1.5 ATA equivalent) as reflecting an attempt to improve the chances of HBOT's effectiveness. This is because the pressure levels used in the Cifu RCT were closer than in the Wolf RCT to the levels that the HBOT proponent also identified as “the ideal pressure that proponents of HBOT normally use for neurological treatments” (≤ 1.5 ATA). We also identified the claim that VA/DoD bias against HBOT led to misinterpretation of the Cifu RCT results: “The conclusion of Cifu et al. that HBOT is ineffective on mTBI is not supported by the data they acquired.”^41^ To refute the Cifu RCT conclusion and demonstrate HBOT's effectiveness, this claim provides data on within-group, uncontrolled changes from before to after in the HBOT arms from both Cifu and Wolf and from another uncontrolled series of HBOT patients.^28^ We disagree that these within-group data demonstrate a misinterpretation of results in the Cifu RCT. In fact, in the Cifu RCT publication, the investigators' interpretation of the within-group changes is identical to those of this HBOT proponent, as noted by this quote from the abstract: “Within-group testing of pre- and postintervention means revealed significant differences on several individual items for each group and difference in the Posttraumatic Disorder Checklist—Military Version total score for the 2.0 ATA HBO2 group.” The difference is that the conclusion from the Cifu RCT that HBOT is ineffective is based on a between-group's comparison of HBOT versus sham, which we agree was not statistically significant. The problem with relying on within-group changes is that – as even noted by a HBOT proponent – without a control group, placebo or participation effects “cannot be entirely ruled out”^28^ and “need confirmation with larger numbers of subjects or with a stronger design such as a randomized or Bayesian study.”^28^

Skeptics claim HBOT has consistently shown no significant differences compared to sham and is no more than a high-tech, high-touch ritual^36^ with “powerful nonspecific placebo effects.”^37^ Factors such as (1) heterogeneity in HBOT protocol (1.5 ATA to 2.4 ATA), outcome assessment methods, timing (immediately following therapy, up to 6 weeks after discontinuation), and patient populations (most recent TBI ranged from 3 to 71 months) and (2) important methodological limitations preclude interpreting these findings as consistent evidence of no effect. We are not suggesting that it is incumbent on the skeptics to prove ineffectiveness. We are only noting the limitations that preclude clear interpretation of the VA/DoD RCTs as demonstrating consistent evidence of no effect.

### LIMITATIONS

The evidence base included in this review has several important limitations. First, applicability to Veterans is unclear, as the majority of the RCT participants were active service members who were temporarily reassigned for study participation, often with greatly reduced duty schedules and enhanced access to leisure time and activities – sometimes in a noncombat, semitropical beach environment. Second, for considering use of HBOT for patients in whom other treatments have been unsuccessful, evidence is insufficient to support recommendations about specifically when to initiate HBOT in the order of recommended conventional pharmacotherapies and psychotherapies. How much failed conventional therapy is “enough” before trying HBOT? Although it is likely that many study participants had already failed “gold standard” therapy, available studies' lack of specific criteria for establishing “failure” of conventional therapy, and/or dose and duration and order of conventional therapies, limits applicability to specific patients. Third, heterogeneity in patient populations and outcome assessment methods prevented assessment of whether and how benefits and risks of HBOT may differ per patient characteristics or treatment protocol. Finally, the most significant limitation of the current literature base is a lack of assessment of clinically relevant outcomes and durability of HBOT beyond immediately after or in the few weeks after HBOT completion. Among the 5 RCTs of HBOT for TBI, PTSD and/or PPCS currently in progress – 4 in the US and 1 in China – none appear to sufficiently address these gaps in the existing evidence (See Appendix F for a complete table of Research in Progress).

In terms of our review methods, limitations include our literature search with exclusion of non-English studies and our scope. Although we focused on the most clinically relevant outcomes of mortality, morbidity, quality of life, functional capacity, and clinically significant symptom response, we recognize this may limit the applicability of our findings to a broader range of intermediate outcomes, including physiological measures, patient expectations, and mean changes in symptom scale scores.

### CLINICAL AND FUTURE RESEARCH IMPLICATIONS

Due to the lack of compelling evidence of effectiveness, guidelines and policies discouraging broad coverage of HBOT for mild TBI appear reasonable. Due to the lack of consistent evidence of ineffectiveness and no clear red flags for serious harms, we agree with the option suggested by proponent Paul Harch, MD of further evidence development on HBOT for TBI and/or PTSD of “an economical Civilian/DoD/Veterans Affairs (VA) off-label networked hyperbaric treatment program using a Medicare-like Coverage with Evidence Development pathway”^79^ for Veterans in whom other treatments have not been successful. Because reasons for lack of expected improvement can be complex and multidimensional, including failure to receive evidence-based interventions due to variability in clinician judgment and patients' barriers to access and adherence, to avoid potential further delay of evidence-based treatments, we suggest careful documentation of previous treatments prior to HBOT initiation. To best contribute to further HBOT evidence development, ideally TBI and/or PTSD, comorbidities, and baseline severity and duration of symptoms should be well-documented, and assessment of effects on clinically important benefits as recommended by the VA/DoD CPG, including functioning, well-being, and quality of life, should be prioritized. Although likely not possible for a small clinical demonstration, clinical evaluation should be done in tandem with neuroimaging and assessment of the role of potentially exaggerated patient expectations that may have resulted due to publicized reports of HBOT as a “miracle cure”. As any positive effects of HBOT should not come at the expense of increased risk of serious harm, assessment of the adverse effects of HBOT is also important. To best consider the use of add-on HBOT for Veterans with TBI and/or PTSD in whom other treatments have been unsuccessful, documentation of the types and durations of previous and ongoing treatments would also be informative in assessing the generalizability of available evidence. Additionally, as the most recent VA/DoD RCTs (HOPPS and BIMA) used identical comparison groups of HBOT 1.5 ATA and room air 1.3 ATA and assessment tools and had similar military populations, to increase statistical power we suggest further analysis of their pooled data. Although likely cost-prohibitive, if another RCT is undertaken, we recommend replication of the HOPPS study design with a wait-list usual care no-chamber group, a low-pressure group, and a 1.5 ATA group, but with an adequate sample size to detect a difference on clinically important outcome, done in tandem with neuroimaging and assessment of the role of patient expectations to help add meaning to why any improvements may be occurring and potentially shed light on the sham debate. To improve our knowledge about HBOT's potential to improve clinically meaningful outcomes, we suggest establishment of a set of validated outcome measures including minimally important symptom difference thresholds. To control for potential natural waxing and waning of symptoms and evaluate durability, we suggest outcome assessment at multiple time points during and 6 to 12 months post-treatment. To potentially improve consistency in interpretation of future HBOT RCT results, we suggest that future HBOT investigators consult with and document endorsement from HBOT proponents on RCT design.

## CONCLUSIONS

Current evidence does not clearly point to one explanation over another for why well-controlled RCTs have not easily replicated the large treatment benefits demonstrated for HBOT in uncontrolled case series. Although our independent and objective examination of 16 RCTs found a lack of compelling evidence of effectiveness for mild TBI and PTSD, we disagree that it can be fully explained by potential physiological effects of sham specific to TBI and/or PTSD or consistent evidence of ineffectiveness that points to a nonspecific participation effect. Pooling data from the HOPPS trial and the as-yet-unpublished BIMA trials could shed light on the debate. Broad usage of HBOT as an initial treatment for mild or moderate to severe TBI or PTSD in lieu of conventional treatments still does not appear clearly warranted. When patients do not respond to and/or do not tolerate adequate trials of multiple conventional therapy options and are considering emerging treatment options, offering HBOT to Veterans with mild or moderate to severe TBI and/or PTSD appears reasonable – with careful consideration of potential increased risk of certain harms. A small-scale clinical demonstration may provide the opportunity to improve data collection on comorbidities, clinically relevant patient outcomes, patient expectations, and documentation of the types and durations of previous and ongoing treatments.

## Acknowledgements

We would like to thank Julia Haskin, MA for editorial support and Katherine Mackey, MD, MPP for providing clinical review.

## REFERENCES

1 Weaver L. Hyperbaric oxygen therapy indications: The Hyperbaric Oxygen Therapy Committee report. Undersea and Hyperbaric Medical Society; 2014.
2 U.S. Food & Drug Administration. 510(k) clearances. Medical Devices 2017; overview and general information. Available at: https://www.fda.gov/MedicalDevices/ProductsandMedicalProcedures/DeviceApprovalsandClearances/510kClearances/. Accessed November 14, 2017.
3 Adams E. Hyperbaric oxygen therapy for traumatic brain injury and post traumatic stress disorder. VA Technology Assessment Program. 2010.
4 Lind F. A pro/con review comparing the use of mono- and multiplace hyperbaric chambers for critical care. Diving Hyperb Med. 2015;45(1):56-60.25964041
5 Carney N, Totten AM, O'Reilly C, . Guidelines for the management of severe traumatic brain injury. Neurosurgery. 2017;80(1):6-15.27654000
6 Prabhakaran K, Petrone P, Lombardo G, Stoller C, Policastro A, Marini CP. Mortality rates of severe traumatic brain injury patients: Impact of direct versus nondirect transfers. Journal of Surgical Research. 2017;219:66-71.29078912
7 Stocchetti N, Zanier ER. Chronic impact of traumatic brain injury on outcome and quality of life: A narrative review. Critical Care. 2016;20(1):148.27323708
8 Wilson L, Stewart W, Dams-O'Connor K, . The chronic and evolving neurological consequences of traumatic brain injury. Lancet Neurol. 2017;16(10):813-825.28920887
9 McCrea M, Iverson GL, McAllister TW, . An integrated review of recovery after mild traumatic brain injury (mtbi): Implications for clinical management. The Clinical Neuropsychologist. 2009;23(8):1368-1390.19882476
10 Lew HL, Tun C, Cifu DX. Prevalence of chronic pain, posttraumatic stress disorder, and persistent postconcussive symptoms in OIF/OEF veterans: Polytrauma clinical triad. Journal of Rehabilitation Research and Development. 2009;46(6):697.20104399
11 Morissette SB, Woodward M, Kimbrel NA, . Deployment-related TBI, persistent postconcussive symptoms, PTSD, and depression in OEF/OIF veterans. Rehabilitation Psychology. 2011;56(4):340.22121940
12 Carroll LJ, Cassidy JD, Cancelliere C, . Systematic review of the prognosis after mild traumatic brain injury in adults: Cognitive, psychiatric, and mortality outcomes: Results of the international collaboration on mild traumatic brain injury prognosis. Arch Phys Med Rehabil. 2014;95(3):S152-S173.24581903
13 Cifu DX, Scholten J, Campbell EH. Traumatic brain injury, posttraumatic stress disorder, and pain diagnoses in OIF/OEF/OND veterans. Journal of Rehabilitation Research and Development. 2013;50(9):1169.24458958
14 Taylor BC, Hagel EM, Carlson KF, . Prevalence and costs of co-occurring traumatic brain injury with and without psychiatric disturbance and pain among Afghanistan and Iraq war veteran V.A. users. Med Care. 2012;50(4):342-346.22228249
15 Prince C, Bruhns ME. Evaluation and treatment of mild traumatic brain injury: The role of neuropsychology. Brain Sciences. 2017;7(8):105.
16 Centers for Disease Control and Prevention. Report to congress on traumatic brain injury in the United States: Epidemiology and rehabilitation. Atlanta, GA: National Center for Injury Prevention and Control. 2014:1-72.
17 Chen Y, Garcia GE, Huang W, Constantini S. The involvement of secondary neuronal damage in the development of neuropsychiatric disorders following brain insults. Front Neurol. 2014;5:22.24653712
18 Eve DJ, Steele MR, Sanberg PR, Borlongan CV. Hyperbaric oxygen therapy as a potential treatment for post-traumatic stress disorder associated with traumatic brain injury. Neuropsychiatric Disease & Treatment. 2016;12:2689-2705.27799776
19 Nygren-de Boussard C, Holm LW, Cancelliere C, . Nonsurgical interventions after mild traumatic brain injury: A systematic review. Results of the international collaboration on mild traumatic brain injury prognosis. Arch Phys Med Rehabil. 2014;95(3 Suppl):S257-264.24581911
20 Cooper DB, Bunner AE, Kennedy JE, . Treatment of persistent post-concussive symptoms after mild traumatic brain injury: A systematic review of cognitive rehabilitation and behavioral health interventions in military service members and veterans. Brain Imaging Behav. 2015;9(3):403-420.26330376
21 Veterans Affairs/Department of Defense. Clinical practice guidelines for the management of concussion-mild traumatic brain injury (mTBI). 2016.
22 Veterans Affairs/Department of Defense. Clinical practice guideline for the management of posttraumatic stress disorder and acute stress disorder. 2017.
23 Boussi-Gross R, Golan H, Fishlev G, . Hyperbaric oxygen therapy can improve post concussion syndrome years after mild traumatic brain injury - randomized prospective trial. PLoS One. 2013;8(11):e79995.24260334
24 Cifu DX, Hart BB, West SL, Walker W, Carne W. The effect of hyperbaric oxygen on persistent postconcussion symptoms. Journal of Head Trauma Rehabilitation. 2014;29(1):11-20.24052094
25 Wolf G, Cifu D, Baugh L, Carne W, Profenna L. The effect of hyperbaric oxygen on symptoms after mild traumatic brain injury. J Neurotrauma. 2012;29(17):2606-2612.23031217
26 Bennett MH, Trytko B, Jonker B. Hyperbaric oxygen therapy for the adjunctive treatment of traumatic brain injury. Cochrane Database of Systematic Reviews. 2012;12:CD004609.
27 Hu Q, Manaenko A, Xu T, Guo Z, Tang J, Zhang JH. Hyperbaric oxygen therapy for traumatic brain injury: Bench-to-bedside. Medical Gas Research. 2016;6(2):102-110.27867476
28 Harch PG, Andrews SR, Fogarty EF, . A phase I study of low-pressure hyperbaric oxygen therapy for blast-induced post-concussion syndrome and post-traumatic stress disorder. J Neurotrauma. 2012;29(1):168-185.22026588
29 Holbach K, Wassmann H, Kolberg T. Improved reversibility of the traumatic midbrain syndrome using hyperbaric oxygen. Acta Neurochirurgica. 1974;30(3-4):247-256.4432786
30 Harch PG. Hyperbaric oxygen in chronic traumatic brain injury: Oxygen, pressure, and gene therapy. Medical Gas Research. 2015;5:9.26171141
31 Harch PG, Andrews SR, Fogarty EF, Lucarini J, Van Meter KW. Case control study: Hyperbaric oxygen treatment of mild traumatic brain injury persistent post-concussion syndrome and post-traumatic stress disorder. Medical Gas Research. 2017;7(3):156-174.29152209
32 Bethesda Hyperbaric Oxygen Therapy. Hyperbaric miracles. Hyperbaric Oxygen Therapy News, Military Injuries 2016; https://www.bethesdahbot.com/hyperbaric-miracles/. Accessed November 14, 2017.
33 Scutti S. Oxygen therapy brings ‘remarkable’ turnaround for toddler who fell in pool. Health 2017; http://www.cnn.com/2017/07/21/health/oxygen-therapy-drowning-brain-damage/index.html. Accessed February 21, 2018.
34 Beckman RL. USMC, Indiana, Texas and Oklahoma making hyperbaric oxygen therapy (HBOT) available to service members with TBI/PTSD/concussion. PRWeb [online journal article]. 2017; http://www.prweb.com/releases/2017/05/prweb14356559.htm. Accessed February 21, 2018.
35 U.S. Food & Drug Administration. Hyperbaric oxygen therapy: Don't be misled. 2013; https://www.fda.gov/forconsumers/consumerupdates/ucm364687.htm. Accessed February 21, 2018.
36 Hoge CW, Jonas WB. The ritual of hyperbaric oxygen and lessons for the treatment of persistent postconcussion symptoms in military personnel. JAMA Internal Medicine. 2015;175(1):53-54.25401214
37 Hoge CW, Jonas WB. Hyperbaric oxygen treatment for persistent postconcussion symptoms--reply. JAMA Internal Medicine. 2015;175(7):1241.
38 Heuser G, Heuser S, Rodelander D, Aguilera O, Uszler M. Treatment of neurologically impaired adults and children with “mild” hyperbaric oxygen (1.3 ata and 24% oxygen). Paper presented at: The Proceedings of the 2nd International Symposium on Hyperbaric Oxygenation for Cerebral Palsy and the Brain-Injured Child. JT Joiner (ed). 2002.
39 Kazantseva NV. Mechanisms of curative effect of minimized hyperbaric treatment in cerebral ischemia. Paper presented at: The Proceedings of the 2nd International Symposium on Hyperbaric Oxygenation for Cerebral Palsy and the Brain-Injured Child. JT Joiner (ed). 2002; Flagstaff, AZ.
40 Figueroa XA Déja vu: Delay, deny and wait ’til I die. 2013; http://brainjury.org/blog/2013/11/07/deja-vu-delay-deny-and-wait-til-i-die/. Accessed February 16, 2018.
41 Figueroa XA What the <#$*&!> is wrong with the DoD/VA HBOT studies?!! 2014; http://brainjury.org/blog/2014/07/03/what-the-bleep-is-wrong-with-the-dodva-hbot-studies/. Accessed February 16, 2018.
42 Marois P, Mukherjee A, Ballaz L. Hyperbaric oxygen treatment for persistent postconcussion symptoms--a placebo effect? JAMA Intern Med. 2015;175(7):1239-1240.26146912
43 May R. The case for hyperbaric oxygen. SFTT on Hyperbaric Oxygen Therapy or HBOT 2016; http://sftt.org/case-hyperbaric-oxygen/. Accessed February 16, 2018.
44 May R Meet Dr. David Cifu: VA gatekeeper for PTSD & TBI. SFTT on Hyperbaric Oxygen Therapy or HBOT 2017; http://sftt.org/cifu-va-gatekeeper-for-ptsd-and-tbi/. Accessed February 16, 2018, 2018.
45 Wentling N. VA to offer unproven hyperbaric oxygen therapy to vets with PTSD. 2017; https://www.stripes.com/news/va-to-offer-unproven-hyperbaric-oxygen-therapy-to-vets-with-ptsd-1.500265. Accessed February 16, 2018.
46 Zoroya G Hyperbaric chamber treatments did not help with mild TBI. 2013; https://www.usatoday.com/story/nation/2013/09/21/tbi-treatment-research-military-hyperbaric-oxygen-chamber/2842695/. Accessed February 16, 2018.
47 Berv D The Float Zone 2017; http://www.myfloatzone.com/the-float-blog/2017/3/17/syzf21ykth7hvl9kpjerio6ot7p8lj. Accessed December 5, 2017.
48 Engel R. Float therapy: A new method in PTSD treatment; a veteran explains his passion for float therapy, a sensory deprivation technique that helps alleviate PTSD symptoms. Military 1 2016; https://www.military1.com/ptsd/article/1641000014-float-therapy-a-new-method-in-ptsd-treatment/. Accessed November 14, 2017.
49 Robinson KA, Chou R, Berkman ND, . Twelve recommendations for integrating existing systematic reviews into new reviews: EPC guidance. J Clin Epidemiol. 2016;70:38-44.26261004
50 Wang F, Wang Y, Sun T, Yu HL. Hyperbaric oxygen therapy for the treatment of traumatic brain injury: A meta-analysis. Neurological Sciences. 2016;37(5):693-701.26746238
51 Crawford C, Teo L, Yang E, Isbister C, Berry K. Is hyperbaric oxygen therapy effective for traumatic brain injury? A rapid evidence assessment of the literature and recommendations for the field. Journal of Head Trauma Rehabilitation. 2017;32(3):E27-E37.
52 Xie Z, Zhuang M, Lin L, Xu H, Chen L, Hu L. Changes of plasma c-reactive protein in patients with craniocerebral injury before and after hyperbaric oxygenation. Neural Regeneration Research. 2007;2(5):314-317.
53 Wolf EG, Prye J, Michaelson R, Brower G, Profenna L, Boneta O. Hyperbaric side effects in a traumatic brain injury randomized clinical trial. Undersea Hyperb Med. 2012;39(6):1075-1082.23342764
54 Wolf EG, Baugh LM, Kabban CM, Richards MF, Prye J. Cognitive function in a traumatic brain injury hyperbaric oxygen randomized trial. Undersea & Hyperbaric Medicine. 2015;42(4):313-332.26403017
55 Walker WC, Franke LM, Cifu DX, Hart BB. Randomized, sham-controlled, feasibility trial of hyperbaric oxygen for service members with postconcussion syndrome: Cognitive and psychomotor outcomes 1 week postintervention. Neurorehabilitation & Neural Repair. 2014;28(5):420-432.24370568
56 Shi X, Tang Z, Xiong B, . Cerebral perfusion spect imaging for assessment of the effect of hyperbaric oxygen therapy on patients with postbrain injury neural status. Chinese Journal of Traumatology= Zhonghua Chuang Shang Za Zhi. 2003;6(6):346-349.14642054
57 Rockswold SB, Rockswold GL, Zaun DA, . A prospective, randomized clinical trial to compare the effect of hyperbaric to normobaric hyperoxia on cerebral metabolism, intracranial pressure, and oxygen toxicity in severe traumatic brain injury. Journal of Neurosurgery. 2010;112(5):1080-1094.19852540
58 Rockswold SB, Rockswold GL, Zaun DA, Liu J. A prospective, randomized phase II clinical trial to evaluate the effect of combined hyperbaric and normobaric hyperoxia on cerebral metabolism, intracranial pressure, oxygen toxicity, and clinical outcome in severe traumatic brain injury. Journal of Neurosurgery. 2013;118(6):1317-1328.23510092
59 Rockswold GL, Ford SE, Anderson DC, Bergman TA, Sherman RE. Results of a prospective randomized trial for treatment of severely brain-injured patients with hyperbaric oxygen. Journal of Neurosurgery. 1992;76(6):929-934.1588426
60 Rockswold G, Ford S. Preliminary results of a prospective randomized trial for treatment of severely brain-injured patients with hyperbaric oxygen. Minnesota Medicine. 1985;68(7):533-535.4021969
61 Ren H, Wang W, Ge Z, Zhang J. Clinical, brain electric earth map, endothelin and transcranial ultrasonic doppler findings after hyperbaric oxygen treatment for severe brain injury. Chinese Medical Journal. 2001;114(4):387-390.11780460
62 Ren H, Wang W, Ge Z. Glasgow coma scale, brain electric activity mapping and Glasgow Outcome Scale after hyperbaric oxygen treatment of severe brain injury. Chinese Journal of Traumatology= Zhonghua Chuang Shang Za Zhi. 2001;4(4):239-241.11835741
63 Miller RS, Weaver LK, Bahraini N, . Effects of hyperbaric oxygen on symptoms and quality of life among service members with persistent postconcussion symptoms: A randomized clinical trial. JAMA Internal Medicine. 2015;175(1):43-52.25401463
64 Mao J, Sun Z, Xiang Y. Observation of curative effects of hyperbaric oxygen for treatment on severe craniocerebral injury. J Clin Neurol. 2010;23(5):386-388.
65 Lin J-W, Tsai J-T, Lee L-M, . Effect of hyperbaric oxygen on patients with traumatic brain injury. Reconstructive Neurosurgery. 2008:145-149.
66 Cifu DX, Walker WC, West SL, . Hyperbaric oxygen for blast-related postconcussion syndrome: Three-month outcomes. Annals of Neurology. 2014;75(2):277-286.24255008
67 Cifu DX, Hoke KW, Wetzel PA, Wares JR, Gitchel G, Carne W. Effects of hyperbaric oxygen on eye tracking abnormalities in males after mild traumatic brain injury. Journal of Rehabilitation Research & Development. 2014;51(7):1047-1056.25436771
68 Artru F, Chacornac R, Deleuze R. Hyperbaric oxygenation for severe head injuries. European Neurology. 1976;14(4):310-318.782888
69 Weaver LK, Chhoeu A, Lindblad AS, Churchill S, Wilson SH. Hyperbaric oxygen for mild traumatic brain injury: Design and baseline summary. Undersea & Hyperbaric Medicine. 2016;43(5):491-509.28768069
70 Weaver LK, Chhoeu A, Lindblad AS, Churchill S, Deru K, Wilson SH. Executive summary: The brain injury and mechanism of action of hyperbaric oxygen for persistent post-concussive symptoms after mild traumatic brain injury (mTBI) (BIMA) study. Undersea & Hyperbaric Medicine. 2016;43(5):485-489.28768068
71 Weaver L, Wilson SH, Linbald AS, . A randomized trial of hyperbaric oxygen in U.S. Service members with post-concussive symptoms. Paper presented at: UHMS Annual Scientific Meeting; 2017; Naples, Florida.
72 Harch PG. Department of Defense trials for hyperbaric oxygen and TBI: Issues of study design and questionable conclusions. Undersea Hyperb Med. 2013;40(5):469-470.24224289
73 Yaman O, Yaman B, Aydin F, Var A, Temiz C. Hyperbaric oxygen treatment in the experimental spinal cord injury model. Spine Journal: Official Journal of the North American Spine Society. 2014;14(9):2184-2194.24530437
74 Defense and Veterans Brain Injury Center. DoD worldwide numbers for TBI. 2017; http://dvbic.dcoe.mil/dod-worldwide-numbers-tbi. Accessed December 5, 2017
75 Centers for Medicare & Medicaid Services. National Coverage Determination (NCD) for hyperbaric oxygen therapy (20.29). 2006, https://www.cms.gov/medicare-coverage-database/details/ncd-details.aspx?ncdid=12&ver=3.
76 Camporesi EM. Side effects of hyperbaric oxygen therapy. Undersea Hyperb Med. 2014;41(3):253-257.24984321
77 Hadanny A, Efrati S. The efficacy and safety of hyperbaric oxygen therapy in traumatic brain injury. Expert Review of Neurotherapeutics. 2016;16(4):359-360.26900796
78 Hampson NB, Simonson SG, Kramer CC, Piantadosi CA. Central nervous system oxygen toxicity during hyperbaric treatment of patients with carbon monoxide poisoning. Undersea Hyperb Med. 1996;23(4):215-219.8989851
79 Harch PG. Hyperbaric oxygen therapy for post-concussion syndrome: Contradictory conclusions from a study mischaracterized as sham-controlled. J Neurotrauma. 2013;30(23):1995-1999.24004322

## Supplemental Materials

### APPENDIX A: FDA-CLEARED INDICATIONS FOR HBOT

FDA Clearances^1^
1. Air or Gas Embolism; 2. Carbon Monoxide Poisoning or Carbon Monoxide Poisoning Complicated by Cyanide Poisoning; 3. Clostridal Myositis and Myonecrosis (Gas Gangrene); 4. Crush Injury, Compartment Syndrome, and other Acute Traumatic Ischemias; 5. Decompression Sickness; 6. Enhancement of Healing in Selected Problem Wounds; 7. Exceptional Blood Loss (Anemia); 8. Intracranial Abscess; 9. Necrotizing Soft Tissue Infections; 10. Osteomyelitis (Refractory); 11. Delayed Radiation Injury (Soft Tissue and Bony Necrosis); 12. Skin Grafts & Flaps (Compromised); 13. Thermal Burns

FDA= US Food and Drug Administration

### APPENDIX B: RELATED GUIDELINES

Organization Year | Title | Comments on HBOT in relation to TBI and/or PTSD
VA/DOD 2017^2^ | Clinical Practice Guideline for The Management of Posttraumatic Stress Disorder and Acute Stress Disorder | “There is no conclusive evidence that HBOT is effective for treating PTSD. There have been no RCTs or uncontrolled trials specifically focused on patients with PTSD, and there is disagreement about what constitutes an adequate sham treatment. In a DoD study, 72 soldiers with TBI (66% with PTSD) were randomized to standard care (78%), HBOT (54%), or sham HBOT (64%). Baseline scores on the PCL were less severe than in all-PTSD studies, likely because not everyone had PTSD. Scores were still in the severe range. Based on the evidence to date, and the practical and cost concerns, it does not appear that HBOT is a promising treatment for further study.” “There is insufficient evidence to recommend for or against the following somatic therapies: repetitive transcranial magnetic stimulation (rTMS), electroconvulsive therapy (ECT), hyperbaric oxygen therapy (HBOT), stellate ganglion block (SGB), or vagal nerve stimulation (VNS).”
VA/DOD 2016^3^ | Clinical Practice Guideline for The Management of Concussion-mild Traumatic Brain Injury | NA
TRICARE 2015 | TRICARE Policy Manual 6010.60-M | HBO therapy for Traumatic Brain Injury (TBI) is unproven.
Colorado Division of Workers' Compensation 2012^4^ | Traumatic Brain Injury Medical Treatment Guidelines | “Despite evidence of limited physiological changes with hyperbaric oxygen, there is insufficient evidence to suggest that hyperbaric oxygen would functionally benefit stroke or TBI patients. Complications can occur, including tension pneumothorax. Hyperbaric oxygen is not recommended acutely or chronically. Ongoing studies could affect this recommendation.”
Brain Trauma Foundation 2017^5^ | Guidelines for the Management of Severe Traumatic Brain Injury 4^th^ Edition | Excluded studies on HBOT
Tenth European Consensus Conference on Hyperbaric Medicine 2017^6^ | Tenth European Consensus Conference on Hyperbaric Medicine: recommendations for accepted and non-accepted clinical indications and practice of hyperbaric oxygen treatment | It would be reasonable to consider HBOT in acute moderate-severe traumatic brain injury (TBI) patients and in a highly selected group of patients with chronic TBI who have clear evidence of metabolically dysfunctional brain region(s) (Type 3 recommendation, Grade C level of evidence) We recommend HBOT use in TBI to be used only in the context of an investigational study protocol approved by an ethics committee and performed according to clinical research good practice (Type 1 Recommendation, Grade A level of evidence)
UpToDate 2017 | Hyperbaric Oxygen Therapy | No mention of PTSD or TBI

### APPENDIX C: SEARCH STRATEGIES

1. Search for current systematic reviews (limited to 2012 forward) Date Searched: 9/25/17
Sources: | Evidence:
AHRQ (http://www.ahrq.gov/research/findings/evidence-based-reports/search.html) | Search: hyperbaric; HBOT Relevant Results: None
CADTH (https://www.cadth.ca/) | Search: hyperbaric; HBOT Relevant Results: CADTH. (2014). Hyperbaric Oxygen Therapy for Adults with Mental Illness: A Review of the Clinical Effectiveness (https://www.cadth.ca/hyperbaric-oxygen-therapy-adults-mental-illness-review-clinical-effectiveness) [underlined: Rapid Response]. Ottawa CA.
NICE (http://www.evidence.nhs.uk/default.aspx) | Search: (hyperbaric) AND (post-traumatic stress or PTSD or brain injury or TBI); (HBOT) AND (post-traumatic stress or PTSD or brain injury or TBI) Relevant Results: None
NLM (http://www.ncbi.nlm.nih.gov/pubmedhealth/) | Search: hyperbaric; HBOT Relevant Results: None
ECRI Institute (https://www.ecri.org/Pages/default.aspx) | Search: hyperbaric; HBOT Relevant Results: ECRI Institute. (2016). Hyperbaric Oxygen Therapy for Postconcussion Syndrome. ECRI Institute. (2016). Infusion Pumps to Consider for Use with Hyperbaric Chambers. ECRI Institute. (2016). Procurement Trends: Hyperbaric Chambers. ECRI Institute. (2017). Chambers, Hyperbaric.
VA Products: VATAP, PBM, HSR&D publications, VA ART Database | A. http://www.hsrd.research.va.gov/research/default.cfm Search: hyperbaric; HBOT Relevant Results: None B. http://www.research.va.gov/research_topics/ Relevant Results: None C. http://art.puget-sound.med.va.gov/default.cfm Search: WHERE (dbo.tbl_D_VA_Site_Programs.Program_Code = 4) AND (Abstract LIKE “%hyperbaric%”) OR (Abstract LIKE “%HBOT%”) Relevant Results: None
MEDLINE: Systematic Reviews | Database: Ovid MEDLINE(R) <1946 to September Week 2 2017>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <September 22, 2017> Search Strategy: -------------------------------------------------------------------------------- 1 (hyperbaric or HBOT).mp. (16091) 2 exp Hyperbaric Oxygenation/ (11284) 3 1 or 2 (16091) 4 exp stress disorders, post-traumatic/ (27753) 5 exp combat disorders/ (2995) 6 (post-traumatic stress or posttraumatic stress or PTSD).mp. (28693) 7 exp craniocerebral trauma/ (147504) 8 exp Glasgow Coma Scale/ (8607) 9 exp Glasgow Outcome Scale/ (1673) 10 (mTBI or TBI).mp. (20497) 11 ((brain* or capitis or cerebr* or crani* or hemispher* or inter-crani* or intra-crani* or skull*) adj4 (contusion* or damag* or fractur* or injur* or trauma* or wound* or concuss*)).mp. (161682) 12 concuss*.mp. (9804) 13 diffuse axonal injur*.mp. (1386) 14 (Glasgow adj (coma or outcome) adj (scale* or score*)).mp. (16532) 15 Ranchos Los Amigos Scale.mp. (2) 16 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 (270087) 17 3 and 16 (684) 18 limit 17 to english language (543) 19 limit 18 to yr=”2012 -Current” (223) 20 (systematic review.ti. or meta-analysis.pt. or meta-analysis.ti. or systematic literature review.ti. or this systematic review.tw. or pooling project.tw. or (systematic review.ti,ab. and review.pt.) or meta synthesis.ti. or meta-analy*.ti. or integrative review.tw. or integrative research review.tw. or rapid review.tw. or umbrella review.tw. or consensus development conference.pt. or practice guideline.pt. or drug class reviews.ti. or cochrane database syst rev.jn. or acp journal club.jn. or health technol assess.jn. or evid rep technol assess summ.jn. or jbi database system rev implement rep.jn. or (clinical guideline and management).tw. or ((evidence based.ti. or evidence-based medicine/ or best practice*.ti. or evidence synthesis.ti,ab.) and (((review.pt. or diseases category/ or behavior.mp.) and behavior mechanisms/) or therapeutics/ or evaluation studies.pt. or validation studies.pt. or guideline.pt. or pmcbook.mp.)) or (((systematic or systematically).tw. or critical.ti,ab. or study selection.tw. or ((predetermined or inclusion) and criteri*).tw. or exclusion criteri*.tw. or main outcome measures.tw. or standard of care.tw. or standards of care.tw.) and ((survey or surveys).ti,ab. or overview*.tw. or review.ti,ab. or reviews.ti,ab. or search*.tw. or handsearch.tw. or analysis.ti. or critique.ti,ab. or appraisal.tw. or (reduction.tw. and (risk/ or risk.tw.) and (death or recurrence).mp.)) and ((literature or articles or publications or publication or bibliography or bibliographies or published).ti,ab. or pooled data.tw. or unpublished.tw. or cijntion.tw. or cijntions.tw. or database.ti,ab. or internet.ti,ab. or textbooks.ti,ab. or vaesphbot.references.tw. or scales.tw. or papers.tw. or datasets.tw. or trials.ti,ab. or meta-analy*.tw. or (clinical and studies).ti,ab. or treatment outcome/ or treatment outcome.tw. or pmcbook.mp.))) not (letter or newspaper article).pt. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier, synonyms] (294299) 21 “Review”/ or “Review Literature as Topic”/ (2372150) 22 20 or 21 (2504071) 23 19 and 22 (47) 24 remove duplicates from 23 (44) ***************************
PsycINFO | Database: PsycINFO <1806 to September Week 3 2017> Search Strategy: -------------------------------------------------------------------------------- 1 (hyperbaric or HBOT).mp. (416) 2 exp Posttraumatic Stress Disorder/ (28129) 3 exp COMBAT EXPERIENCE/ (2578) 4 (post-traumatic stress or posttraumatic stress or PTSD).mp. (41382) 5 exp Traumatic Brain Injury/ (16247) 6 exp Brain Damage/ (33167) 7 exp Head Injuries/ (5705) 8 (mTBI or TBI).mp. (9934) 9 ((brain* or capitis or cerebr* or crani* or hemispher* or inter-crani* or intra-crani* or skull*) adj4 (contusion* or damag* or fractur* or injur* or trauma* or wound* or concuss*)).mp. (49649) 10 concuss*.mp. (2864) 11 diffuse axonal injur*.mp. (295) 12 (Glasgow adj (coma or outcome) adj (scale* or score*)).mp. (5322) 13 Ranchos Los Amigos Scale.mp. (11) 14 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 (94430) 15 1 and 14 (85) 16 (systematic review.ti. or meta-analysis.pt. or meta-analysis.ti. or systematic literature review.ti. or this systematic review.tw. or pooling project.tw. or (systematic review.ti,ab. and review.pt.) or meta synthesis.ti. or meta-analy*.ti. or integrative review.tw. or integrative research review.tw. or rapid review.tw. or umbrella review.tw. or consensus development conference.pt. or practice guideline.pt. or drug class reviews.ti. or cochrane database syst rev.jn. or acp journal club.jn. or health technol assess.jn. or evid rep technol assess summ.jn. or jbi database system rev implement rep.jn. or (clinical guideline and management).tw. or ((evidence based.ti. or evidence-based medicine/ or best practice*.ti. or evidence synthesis.ti,ab.) and (((review.pt. or diseases category/ or behavior.mp.) and behavior mechanisms/) or therapeutics/ or evaluation studies.pt. or validation studies.pt. or guideline.pt. or pmcbook.mp.)) or (((systematic or systematically).tw. or critical.ti,ab. or study selection.tw. or ((predetermined or inclusion) and criteri*).tw. or exclusion criteri*.tw. or main outcome measures.tw. or standard of care.tw. or standards of care.tw.) and ((survey or surveys).ti,ab. or overview*.tw. or review.ti,ab. or reviews.ti,ab. or search*.tw. or handsearch.tw. or analysis.ti. or critique.ti,ab. or appraisal.tw. or (reduction.tw. and (risk/ or risk.tw.) and (death or recurrence).mp.)) and ((literature or articles or publications or publication or bibliography or bibliographies or published).ti,ab. or pooled data.tw. or unpublished.tw. or cijntion.tw. or cijntions.tw. or database.ti,ab. or internet.ti,ab. or textbooks.ti,ab. or vaesphbot.references.tw. or scales.tw. or papers.tw. or datasets.tw. or trials.ti,ab. or meta-analy*.tw. or (clinical and studies).ti,ab. or treatment outcome/ or treatment outcome.tw. or pmcbook.mp.))) not (letter or newspaper article).pt. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures] (106761) 17 “Review”/ or “Review Literature as Topic”/ (22334) 18 16 or 17 (126869) 19 15 and 18 (6) 20 limit 19 to english language (5) ***************************
HTA | Database: EBM Reviews - Health Technology Assessment <4th Quarter 2016> Search Strategy: -------------------------------------------------------------------------------- 1 (hyperbaric or HBOT).mp. (54) 2 exp Hyperbaric Oxygenation/ (49) 3 1 or 2 (54) 4 exp stress disorders, post-traumatic/ (28) 5 exp combat disorders/ (2) 6 (post-traumatic stress or posttraumatic stress or PTSD).mp. (31) 7 exp craniocerebral trauma/ (45) 8 exp Glasgow Coma Scale/ (1) 9 exp Glasgow Outcome Scale/ (0) 10 (mTBI or TBI).mp. (12) 11 ((brain* or capitis or cerebr* or crani* or hemispher* or inter-crani* or intra-crani* or skull*) adj4 (contusion* or damag* or fractur* or injur* or trauma* or wound* or concuss*)).mp. (78) 12 concuss*.mp. (5) 13 diffuse axonal injur*.mp. (0) 14 (Glasgow adj (coma or outcome) adj (scale* or score*)).mp. (4) 15 Ranchos Los Amigos Scale.mp. (0) 16 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 (123) 17 3 and 16 (5) 18 limit 17 to english language (5) 19 limit 18 to yr=”2012 -Current” (0) ***************************
Cochrane Database of Systematic Reviews & Cochrane Methodology Register | Database: EBM Reviews - Cochrane Database of Systematic Reviews <2005 to September 20, 2017>, EBM Reviews - Cochrane Methodology Register <3rd Quarter 2012> Search Strategy: -------------------------------------------------------------------------------- 1 (hyperbaric or HBOT).mp. (88) 2 (post-traumatic stress or posttraumatic stress or PTSD).mp. (167) 3 (mTBI or TBI).mp. (72) 4 ((brain* or capitis or cerebr* or crani* or hemispher* or inter-crani* or intra-crani* or skull*) adj4 (contusion* or damag* or fractur* or injur* or trauma* or wound* or concuss*)).mp. (674) 5 concuss*.mp. (43) 6 diffuse axonal injur*.mp. (35) 7 (Glasgow adj (coma or outcome) adj (scale* or score*)).mp. (112) 8 Ranchos Los Amigos Scale.mp. (0) 9 2 or 3 or 4 or 5 or 6 or 7 or 8 (880) 10 1 and 9 (17) 11 limit 10 to yr=”2012 -Current” (13) ***************************
Database of Randomized Controlled Trials in Hyperbaric Medicine (http://hboevidence.unsw.wikispaces.net/) | Search: Posttraumatic; post traumatic; PTSD; TBI; brain injury; head injury Relevant Results: None
Systematic Reviews (Journal) (http://link.springer.com/journal/13643) | Search: hyperbaric; HBOT Relevant Results: None

2. Systematic reviews currently under development (forthcoming reviews & protocols) Date Searched: 9/25/17
Sources: | Evidence:
PROSPERO (SR registry) | http://www.crd.york.ac.uk/PROSPERO/ Search: Hyperbaric; HBOT Relevant Results: Yan Dong. The effect of hyperbaric oxygen therapy on post-concussion syndrome: a systematic review and meta-analysis. PROSPERO 2016:CRD42016032620 Available from http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=CRD42016032620 Miloslav Klugar, Ivana Nytra, Sona Bocková, Jitka Klugarová, Zuzana Kelnarová, Jana Marecková. The effectiveness of hyperbaric oxygen therapy on mortality in adults with craniotrauma: a systematic review protocol. PROSPERO 2015:CRD42015016547 Available from http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=CRD42015016547
DoPHER (http://eppi.ioe.ac.uk/webdatabases4/Intro.aspx?ID=9) (SR Protocols) | Search: Hyperbaric; HBOT Relevant Results: None

3. Current Guidelines Date Searched: 9/22/17
Sources: | Evidence:
VA/DoD Clinical Practice Guidelines (https://www.healthquality.va.gov/) | Relevant Results: VA/DoD. (2016). Clinical Practice Guidelines for The Management of Concussion-mild Traumatic Brain Injury (mTBI). VA/DoD. (2017). Clinical Practice Guideline for The Management of Posttraumatic Stress Disorder and Acute Stress Disorder.
National Guideline Clearinghouse (http://www.guideline.gov/) | Search: hyperbaric; HBOT; traumatic brain injury; TBI; post-traumatic stress syndrome; PTSD Relevant Results: Colorado Division of Workers' Compensation Traumatic Brain Injury Medical Treatment Guidelines (2012)
Google Scholar | Search: “”hyperbaric oxygen therapy” guideline; HBOT guideline Relevant Results: None
Epistemonikos (https://www.epistemonikos.org/) | Search: (title:(hyperbaric or HBOT) OR abstract:(hyperbaric or HBOT)) AND (title:(PTSD) OR abstract:(PTSD)) OR (title:(post-traumatic stress) OR abstract:(post-traumatic stress)) OR (title:(TBI) OR abstract:(TBI)) AND (title:(brain injury) OR abstract:(brain injury)) Relevant Results: None
TRIP (https://www.tripdatabase.com/) | Search: (hyperbaric or HBOT) AND (post-traumatic stress or PTSD or brain injury or TBI) Relevant Results: None
Medline: Guideline Search | Database: Ovid MEDLINE(R) <1946 to September Week 2 2017>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <September 21, 2017> Search Strategy: -------------------------------------------------------------------------------- 1 (hyperbaric or HBOT).mp. (16091) 2 exp Hyperbaric Oxygenation/ (11284) 3 1 or 2 (16091) 4 exp stress disorders, post-traumatic/ (27753) 5 exp combat disorders/ (2995) 6 (post-traumatic stress or posttraumatic stress or PTSD).mp. (28689) 7 exp craniocerebral trauma/ (147504) 8 exp Glasgow Coma Scale/ (8607) 9 exp Glasgow Outcome Scale/ (1673) 10 (mTBI or TBI).mp. (20491) 11 ((brain* or capitis or cerebr* or crani* or hemispher* or inter-crani* or intra-crani* or skull*) adj4 (contusion* or damag* or fractur* or injur* or trauma* or wound* or concuss*)).mp. (161659) 12 concuss*.mp. (9803) 13 diffuse axonal injur*.mp. (1386) 14 (Glasgow adj (coma or outcome) adj (scale* or score*)).mp. (16528) 15 Ranchos Los Amigos Scale.mp. (2) 16 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 (270057) 17 3 and 16 (684) 18 limit 17 to english language (543) 19 exp Guideline/ (30968) 20 guideline*.mp. (381513) 21 19 or 20 (381513) 22 18 and 21 (9) ***************************
UpToDate (https://www.uptodate.com/contents/search) | Search: Hyperbaric; HBOT Relevant Results: https://www.uptodate.com/contents/hyperbaric-oxygen-therapy

4. Current primary literature (limited to 2014 forward) Date Searched: 9/25/17
Sources: | Search Strategy/ Evidence:
Medline | Database: Ovid MEDLINE(R) <1946 to September Week 2 2017>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <September 22, 2017> Search Strategy: -------------------------------------------------------------------------------- 1 (hyperbaric or HBOT).mp. (16091) 2 exp Hyperbaric Oxygenation/ (11284) 3 1 or 2 (16091) 4 exp stress disorders, post-traumatic/ (27753) 5 exp combat disorders/ (2995) 6 (post-traumatic stress or posttraumatic stress or PTSD).mp. (28693) 7 exp craniocerebral trauma/ (147504) 8 exp Glasgow Coma Scale/ (8607) 9 exp Glasgow Outcome Scale/ (1673) 10 (mTBI or TBI).mp. (20497) 11 ((brain* or capitis or cerebr* or crani* or hemispher* or inter-crani* or intra-crani* or skull*) adj4 (contusion* or damag* or fractur* or injur* or trauma* or wound* or concuss*)).mp. (161682) 12 concuss*.mp. (9804) 13 diffuse axonal injur*.mp. (1386) 14 (Glasgow adj (coma or outcome) adj (scale* or score*)).mp. (16532) 15 Ranchos Los Amigos Scale.mp. (2) 16 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 (270087) 17 3 and 16 (684) 18 limit 17 to english language (543) 19 limit 18 to yr=”2014 -Current” (151) 20 remove duplicates from 19 (144) ***************************
Medline: Harms Date searched: 9/26/17 | Database: Ovid MEDLINE(R) <1946 to September Week 2 2017>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <September 25, 2017> Search Strategy: -------------------------------------------------------------------------------- 1 exp Patient Harm/ (103) 2 harm*.mp. (144083) 3 exp Long Term Adverse Effects/ (265) 4 adverse effect*.mp. (135692) 5 1 or 2 or 3 or 4 (276407) 6 (hyperbaric or HBOT).mp. (16093) 7 exp Hyperbaric Oxygenation/ (11284) 8 6 or 7 (16093) 9 exp stress disorders, post-traumatic/ (27753) 10 exp combat disorders/ (2995) 11 (post-traumatic stress or posttraumatic stress or PTSD).mp. (28708) 12 exp craniocerebral trauma/ (147504) 13 exp Glasgow Coma Scale/ (8607) 14 exp Glasgow Outcome Scale/ (1673) 15 (mTBI or TBI).mp. (20505) 16 ((brain* or capitis or cerebr* or crani* or hemispher* or inter-crani* or intra-crani* or skull*) adj4 (contusion* or damag* or fractur* or injur* or trauma* or wound* or concuss*)).mp. (161723) 17 concuss*.mp. (9809) 18 diffuse axonal injur*.mp. (1387) 19 (Glasgow adj (coma or outcome) adj (scale* or score*)).mp. (16533) 20 Ranchos Los Amigos Scale.mp. (2) 21 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 (270148) 22 8 and 21 (684) 23 limit 22 to english language (543) 24 5 and 23 (13) ***************************
PsychINFO | Database: PsycINFO <1806 to September Week 3 2017> Search Strategy: -------------------------------------------------------------------------------- 1 (hyperbaric or HBOT).mp. (416) 2 exp Posttraumatic Stress Disorder/ (28129) 3 exp COMBAT EXPERIENCE/ (2578) 4 (post-traumatic stress or posttraumatic stress or PTSD).mp. (41382) 5 exp Traumatic Brain Injury/ (16247) 6 exp Brain Damage/ (33167) 7 exp Head Injuries/ (5705) 8 (mTBI or TBI).mp. (9934) 9 ((brain* or capitis or cerebr* or crani* or hemispher* or inter-crani* or intra-crani* or skull*) adj4 (contusion* or damag* or fractur* or injur* or trauma* or wound* or concuss*)).mp. (49649) 10 concuss*.mp. (2864) 11 diffuse axonal injur*.mp. (295) 12 (Glasgow adj (coma or outcome) adj (scale* or score*)).mp. (5322) 13 Ranchos Los Amigos Scale.mp. (11) 14 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 (94430) 15 1 and 14 (85) 16 limit 15 to english language (81) 17 limit 16 to yr=”2014 -Current” (29) ***************************
CCRCT | Database: EBM Reviews - Cochrane Central Register of Controlled Trials <August 2017> Search Strategy: -------------------------------------------------------------------------------- 1 (hyperbaric or HBOT).mp. (2071) 2 exp Hyperbaric Oxygenation/ (317) 3 1 or 2 (2071) 4 exp stress disorders, post-traumatic/ (1231) 5 exp combat disorders/ (94) 6 (post-traumatic stress or posttraumatic stress or PTSD).mp. (2807) 7 exp craniocerebral trauma/ (2031) 8 exp Glasgow Coma Scale/ (389) 9 exp Glasgow Outcome Scale/ (122) 10 (mTBI or TBI).mp. (1390) 11 ((brain* or capitis or cerebr* or crani* or hemispher* or inter-crani* or intra-crani* or skull*) adj4 (contusion* or damag* or fractur* or injur* or trauma* or wound* or concuss*)).mp. (5210) 12 concuss*.mp. (311) 13 diffuse axonal injur*.mp. (36) 14 (Glasgow adj (coma or outcome) adj (scale* or score*)).mp. (1554) 15 Ranchos Los Amigos Scale.mp. (0) 16 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 (9822) 17 3 and 16 (65) 18 limit 17 to english language (37) 19 limit 18 to yr=”2014 -Current” (18) 20 remove duplicates from 19 (18) ***************************
Google Scholar | Search: Hyperbaric; HBOT Relevant Results: Hexdall, E., Brave, R., Kraft, K., & Siewers, J. (2016). Diving deep into hyperbaric oxygen therapy. Nursing, 46(10), 28.
Pedro (https://www.pedro.org.au/) | Search: Hyperbaric; HBOT (limited to 2012 forward due to potential for systematic review results) Relevant Results: None
PILOTS (https://search.proquest.com/pilots/index?accountid=28179) | Search: hyperbaric* OR HBOT (limited to 2012 forward due to potential for systematic review results) Relevant Results: None
The Database of Randomised Controlled Trials in Diving and Hyperbaric Medicine (http://hboevidence.unsw.wikispaces.net/) | Relevant Results: None previously uncaptured

5. Primary literature currently under development (forthcoming studies & protocols) Date Searched: 9/26/17
Sources: | Search Strategy/ Evidence:
Clinicaltrials.gov | Search: Hyperbaric or HBOT Relevant Results: NCT01611194 (https://clinicaltrials.gov/ct2/show/NCT01611194?term=hyperbaric&age=12&draw=3&rank=137) (Completed, outcome results not yet published) NCT01847755 (https://clinicaltrials.gov/ct2/show/NCT01847755) (Currently recruiting) NCT02089594 (https://clinicaltrials.gov/ct2/show/NCT02089594) (Currently recruiting) NCT00594503 (https://clinicaltrials.gov/ct2/show/NCT00594503?term=hyperbaric&age=12&draw=3&rank=110) (Currently recruiting) NCT02407028 (https://clinicaltrials.gov/ct2/show/NCT02407028?term=hyperbaric&age=12&draw=3&rank=140) (Not yet recruiting) NCT01105962 (https://clinicaltrials.gov/ct2/show/NCT01105962?cond=PTSD+or+tbi&intr=hyperbaric&rank=2) (Terminated)
UK Clinical Trials Gateway (https://www.ukctg.nihr.ac.uk/) | Search: Hyperbaric; HBOT Relevant results: None
WHO International Clinical Trials Registry Platform (http://apps.who.int/trialsearch/default.aspx) | Search: Hyperbaric or HBOT Relevant results: Magnetic resonance imaging study of hyperbaric oxygen treatment on cognitive dysfunction after traumatic brain injury (http://apps.who.int/trialsearch/Trial2.aspx?TrialID=ChiCTR-IOR-16010091) (Currently recruiting, China)

6. Advocacy Groups (HBOT, PTSD, and TBI) Date Searched: 9/22/17
Sources: | Search Strategy/ Evidence:
Brain Injury Association of America (http://www.biausa.org/) | Search: hyperbaric; HBOT Relevant Results: None
Kesssler Foundation (https://kesslerfoundation.org/search) | Search: hyperbaric; HBOT Relevant Results: None
Concussion Legacy Foundation (https://concussionfoundation.org/) | Search: hyperbaric; HBOT Relevant Results: None
San Diego Brain Injury Foundation (https://sdbif.org/) | Search: hyperbaric; HBOT Relevant Results: None
Neuro-Laser Foundation (http://www.tbi.care/services/hyperbaric-oxygen-treatment/) | Relevant Results: None
PTSD Foundation of America (http://ptsdusa.org/) | Relevant Results: None
National Center for PTSD (https://www.ptsd.va.gov/about/index.asp) | Search: hyperbaric; HBOT Relevant Results: None
The official website of the Military Health System and the Defense Health Agency (https://health.mil/) | Search: hyperbaric; HBOT Relevant Results: HR 3326 5.2.2011
PTSD Alliance (http://www.ptsdalliance.org/) | Relevant Results: None
International Hyperbaric Medical Foundation (http://www.hyperbaricmedicalfoundation.org/) | Relevant Results: None
International Hyperbaric Medical Association (https://www.hyperbaricmedicalassociation.org/) | Relevant Results: None
HBOT2017 Conference & Expo (http://hbot2017.com/) | Relevant Results: None
HBOT.com | Relevant Results: None
HBOT for Vets (http://www.hbotvet.us/home.html) | Relevant Results: None
HBOT in Wound Care (http://hbotinwoundcare.com/) | Relevant Results: None
Undersea & Hyperbaric Medical Society (https://www.uhms.org/) | https://www.uhms.org/resources/hbo-indications.html
Free The Chamber (http://freethechamber.com/?gclid=EAIaIQobChMIpZ_G3cy51gIVHZ7ACh2aoAUnEAAYAiAAEgJEF_D_BwE) | Relevant Results: None
Holistic Hyperbaric (http://holistic-hyperbarics.com/) | Relevant Results: None
Harch Hyperbarics Media (http://harchmedia.com/) | Relevant Results: None
Hyperbaric Link (https://www.hyperbariclink.com/treatment-centers/treatment-centers.aspx#.WckzHmtSxQI) | Relevant Results: None
The American Legion (https://legion.org/) | Relevant Results: None
Treat Now (http://www.treatnow.org/) | Relevant Results: None

7. Update Search Date Searched: 1/4/18
Sources: | Search Strategy/ Evidence:
Medline | Database: Ovid MEDLINE(R) <1946 to December Week 4 2017>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <January 03, 2018> Search Strategy: -------------------------------------------------------------------------------- 1 (hyperbaric or HBOT).mp. (16753) 2 exp Hyperbaric Oxygenation/ (11750) 3 1 or 2 (16753) 4 exp stress disorders, post-traumatic/ (29627) 5 exp combat disorders/ (3096) 6 (post-traumatic stress or posttraumatic stress or PTSD).mp. (30638) 7 exp craniocerebral trauma/ (155026) 8 exp Glasgow Coma Scale/ (9337) 9 exp Glasgow Outcome Scale/ (1913) 10 (mTBI or TBI).mp. (21919) 11 ((brain* or capitis or cerebr* or crani* or hemispher* or inter-crani* or intra-crani* or skull*) adj4 (contusion* or damag* or fractur* or injur* or trauma* or wound* or concuss*)).mp. (171008) 12 concuss*.mp. (10439) 13 diffuse axonal injur*.mp. (1489) 14 (Glasgow adj (coma or outcome) adj (scale* or score*)).mp. (17960) 15 Ranchos Los Amigos Scale.mp. (2) 16 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 (285478) 17 3 and 16 (718) 18 limit 17 to english language (575) 19 limit 18 to yr=”2017 -Current” (27) 20 remove duplicates from 19 (26) *************************** Relevant Results: None
PsychINFO | Database: PsycINFO <1806 to December Week 4 2017> Search Strategy: -------------------------------------------------------------------------------- 1 (hyperbaric or HBOT).mp. (423) 2 exp Posttraumatic Stress Disorder/ (28560) 3 exp COMBAT EXPERIENCE/ (2604) 4 (post-traumatic stress or posttraumatic stress or PTSD).mp. (42204) 5 exp Traumatic Brain Injury/ (16636) 6 exp Brain Damage/ (33600) 7 exp Head Injuries/ (5772) 8 (mTBI or TBI).mp. (10195) 9 ((brain* or capitis or cerebr* or crani* or hemispher* or inter-crani* or intra-crani* or skull*) adj4 (contusion* or damag* or fractur* or injur* or trauma* or wound* or concuss*)).mp. (50355) 10 concuss*.mp. (2979) 11 diffuse axonal injur*.mp. (305) 12 (Glasgow adj (coma or outcome) adj (scale* or score*)).mp. (5435) 13 Ranchos Los Amigos Scale.mp. (11) 14 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 (95998) 15 1 and 14 (88) 16 limit 15 to english language (84) 17 limit 16 to yr=”2017 -Current” (8) *************************** Relevant Results: None
CCRCT | Database: EBM Reviews - Cochrane Central Register of Controlled Trials <November 2017> Search Strategy: -------------------------------------------------------------------------------- 1 (hyperbaric or HBOT).mp. (2096) 2 exp Hyperbaric Oxygenation/ (317) 3 1 or 2 (2096) 4 exp stress disorders, post-traumatic/ (1269) 5 exp combat disorders/ (96) 6 (post-traumatic stress or posttraumatic stress or PTSD).mp. (2919) 7 exp craniocerebral trauma/ (2057) 8 exp Glasgow Coma Scale/ (397) 9 exp Glasgow Outcome Scale/ (124) 10 (mTBI or TBI).mp. (1472) 11 ((brain* or capitis or cerebr* or crani* or hemispher* or inter-crani* or intra-crani* or skull*) adj4 (contusion* or damag* or fractur* or injur* or trauma* or wound* or concuss*)).mp. (5408) 12 concuss*.mp. (328) 13 diffuse axonal injur*.mp. (39) 14 (Glasgow adj (coma or outcome) adj (scale* or score*)).mp. (1608) 15 Ranchos Los Amigos Scale.mp. (0) 16 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 (10162) 17 3 and 16 (66) 18 limit 17 to english language (38) 19 limit 18 to yr=”2017 -Current” (5) 20 remove duplicates from 19 (5) *************************** Relevant Results: None
Database of Randomized Controlled Trials in Hyperbaric Medicine (http://hboevidence.unsw.wikispaces.net/) | Search: Posttraumatic; post traumatic; PTSD; TBI; brain injury; head injury Relevant Results: None
Pedro (https://www.pedro.org.au/) | Search: Hyperbaric; HBOT (limited to 2012 forward due to potential for systematic review results) Relevant Results: None
PILOTS (https://search.proquest.com/pilots/index?accountid=28179) | Search: hyperbaric* OR HBOT (limited to 2012 forward due to potential for systematic review results) Relevant Results: None

### APPENDIX D: LIST OF EXCLUDED STUDIES

Exclude reasons: 1=Ineligible population, 2=Ineligible intervention, 3=Ineligible comparator, 4=Intermediate outcome (ie, stem cell markers, angiogenesis), 5=Ineligible timing, 6=Ineligible study design, 7=Ineligible publication type, 8=Outdated or unclear or high risk of bias SR, 9=Non-English language, 10=Critique or rebuttal of paper, 11=Unable to locate full-text, B=Background, G=Guidelines

# | Citation | Exclude reason
1 | Report to Congress on the Use of Hyperbaric Oxygen for Medical Care and Research in Response to H.R. 3326, the Department of Defense Appropriations Act for Fiscal Year 2010. 2011. | B
2 | Adamides AA, Winter CD, Lewis PM, Cooper DJ, Kossmann T, Rosenfeld JV. Current controversies in the management of patients with severe traumatic brain injury. ANZ Journal of Surgery. 2006;76(3):163-174. | E7
3 | Adams E. Hyperbaric Oxygen Therapy for Traumatic Brain Injury and Post Traumatic Stress Disorder. VA Technology Assessment Program. 2010. | B
4 | Algattas H, Huang JH. Traumatic Brain Injury pathophysiology and treatments: early, intermediate, and late phases post-injury. International Journal of Molecular Sciences. 2013;15(1):309-341. | E7
5 | Algattas H, Huang JH. Neurotrauma and Repair Research: Traumatic Brain Injury (TBI) and its Treatments. Biomedical Engineering & Computational Biology. 2013;5:51-56. | B
6 | Alternative Therapy Evaluation Committee for the Insurance Corporation of British C. A review of the scientific evidence on the treatment of traumatic brain injuries and strokes with hyperbaric oxygen. Brain Injury. 2003;17(3):225-236. | E8
7 | Bennett MH. Hyperbaric medicine and the placebo effect. Diving & Hyperbaric Medicine. 2014;44(4):235-240. | B
8 | Bennett MH, Trytko B, Jonker B. Hyperbaric oxygen therapy for the adjunctive treatment of traumatic brain injury. Cochrane Database of Systematic Reviews. 2004(4):CD004609. | E8
9 | Beynon C, Kiening KL, Orakcioglu B, Unterberg AW, Sakowitz OW. Brain tissue oxygen monitoring and hyperoxic treatment in patients with traumatic brain injury. Journal of Neurotrauma. 2012;29(12):2109-2123. | E7
10 | Brenner L, Bahraini N, Forster J. Neuropsychological outcomes from a Phase II, randomized, sham-controlled trial hyperbaric oxygen for post-concussion syndrome. Brain injury. 2017;Conference: 12th world congress on brain injury of the international brain injury association. United states. 31(6-7):805. | E7
11 | Brenner L, Bahraini N, Weaver L, et al. Effects of hyperbaric oxygen on symptoms and quality-of-life among US Military service members with persistent post-concussion symptoms: a randomized, double-blind, sham-controlled trial. Brain injury. 2016;Conference: 11th world congress on brain injury of the international brain injury association. Netherlands. Conference start:. 20160302. Conference end: 20160305 30(5-6):729. | E7
12 | Canadian Agency for Drugs and Technologies in Health (CADTH). Hyperbaric oxygen therapy for adults with mental illness: a review of the clinical effectiveness. Rapid Response. 2014. | E8
13 | Carney N, Totten AM, O'reilly C, et al. Guidelines for the management of severe traumatic brain injury. Neurosurgery. 2017;80(1):6-15. | G
14 | Churchill S, Miller RS, Deru K, Wilson SH, Weaver LK. Simple and Procedural Reaction Time for Mild Traumatic Brain Injury in a Hyperbaric Oxygen Clinical Trial. Military Medicine. 2016;181(5 Suppl):40-44. | E4
15 | Colorado Division of Workers' Compensation. Traumatic Brain Injury Medical Treatment Guidelines. 2012. | G
16 | Cossu G. Therapeutic options to enhance coma arousal after traumatic brain injury: state of the art of current treatments to improve coma recovery. British Journal of Neurosurgery. 2014;28(2):187-198. | E4
17 | ECRI Institute. Hyperbaric Oxygen Therapy for Postconcussion Syndrome. 2016. | E8
18 | ECRI Institute. Procurement Trends: Hyperbaric Chambers - May, 2016. 2016. | B
19 | ECRI Institute. Infusion Pumps to Consider for Use with Hyperbaric Chambers. 2016. | E2
20 | ECRI Institute. Chambers, Hyperbaric. 2017. | B
21 | Efrati S, Ben-Jacob E. Reflections on the neurotherapeutic effects of hyperbaric oxygen. Expert Review of Neurotherapeutics. 2014;14(3):233-236. | E7
22 | Eve DJ, Steele MR, Sanberg PR, Borlongan CV. Hyperbaric oxygen therapy as a potential treatment for post-traumatic stress disorder associated with traumatic brain injury. Neuropsychiatric Disease & Treatment. 2016;12:2689-2705. | B
23 | Fife CE, Gelly H, Walker D, Eckert KA. Rapid analysis of hyperbaric oxygen therapy registry data for reimbursement purposes: Technical communication. Undersea Hyperb Med. 2016;43(6):633-639. | B
24 | Figueroa XA, Wright JK. Clinical results in brain injury trials using HBO2 therapy: Another perspective. Undersea & Hyperbaric Medicine. 2015;42(4):333-351. | B
25 | Figueroa XA, Wright JK. Hyperbaric oxygen: B-level evidence in mild traumatic brain injury clinical trials. Neurology. 2016;87(13):1400-1406. | B
26 | Figueroa XA, Wright JK. Author response: Hyperbaric oxygen: B-Level evidence in mild traumatic brain injury clinical trials. Neurology. 2017;89(7):750-751. | E10
27 | Figueroa XA, Wright JK. “Hyperbaric oxygen: B-level evidence in mild traumatic brain injury clinical trials”: Author's response. Neurology. 2017;89(7):750-751. | B
28 | Gajewski BJ, Berry SM, Barsan WG, et al. Hyperbaric oxygen brain injury treatment (HOBIT) trial: a multifactor design with response adaptive randomization and longitudinal modeling. Pharmaceutical Statistics. 2016;15(5):396-404. | B
29 | Guedes VA, Song S, Provenzano M, Borlongan CV. Understanding the pathology and treatment of traumatic brain injury and posttraumatic stress disorder: a therapeutic role for hyperbaric oxygen therapy. Expert Review of Neurotherapeutics. 2016;16(1):61-70. | B
30 | Hadanny A, Efrati S. Oxygen--a limiting factor for brain recovery. Critical Care (London, England). 2015;19:307. | E7
31 | Hadanny A, Efrati S. Treatment of persistent post-concussion syndrome due to mild traumatic brain injury: current status and future directions. Expert Review of Neurotherapeutics. 2016;16(8):875-887. | B
32 | Hadanny A, Efrati S. The efficacy and safety of hyperbaric oxygen therapy in traumatic brain injury. Expert Review of Neurotherapeutics. 2016;16(4):359-360. | E10
33 | Hadanny A, Meir O, Bechor Y, Fishlev G, Bergan J, Efrati S. Seizures during hyperbaric oxygen therapy: retrospective analysis of 62,614 treatment sessions. Undersea & Hyperbaric Medicine. 2016;43(1):21-28. | E1
34 | Hampson NB, Holm J. “Hyperbaric oxygen: B-level evidence in mild traumatic brain injury clinical trials”: Comment. Neurology. 2017;89(7):750. | E10
35 | Harch PG. Hyperbaric oxygen therapy for post-concussion syndrome: contradictory conclusions from a study mischaracterized as sham-controlled. J Neurotrauma. 2013;30(23):1995-1999. | E10
36 | Harch PG. Department of Defense trials for hyperbaric oxygen and TBI: issues of study design and questionable conclusions. Undersea Hyperb Med. 2013;40(5):469-470. | E10
37 | Harch PG. Hyperbaric oxygen in chronic traumatic brain injury: oxygen, pressure, and gene therapy. Medical Gas Research. 2015;5:9. | B
38 | Harch PG, Andrews SR, Fogarty EF, et al. A phase I study of low-pressure hyperbaric oxygen therapy for blast-induced post-concussion syndrome and post-traumatic stress disorder. J Neurotrauma. 2012;29(1):168-185. | B
39 | Harch PG, Andrews SR, Fogarty EF, Lucarini J, Van Meter KW. Case control study: hyperbaric oxygen treatment of mild traumatic brain injury persistent post-concussion syndrome and post-traumatic stress disorder. Medical Gas Research. 2017;7(3):156-174. | B
40 | Hawkins JR, Gonzalez KE, Heumann KJ. The Effectiveness of Hyperbaric Oxygen Therapy as a Treatment for Postconcussion Symptoms. Journal of Sport Rehabilitation. 2017;26(3):290-294. | E8
41 | Hexdall E, Brave R, Kraft K, Siewers J. Diving deep into hyperbaric oxygen therapy. Nursing. 2016;46(10):28. | B
42 | Hoge CW, Jonas WB. Hyperbaric Oxygen Treatment for Persistent Postconcussion Symptoms--Reply. JAMA Internal Medicine. 2015;175(7):1241. | E10
43 | Hoge CW, Jonas WB. The ritual of hyperbaric oxygen and lessons for the treatment of persistent postconcussion symptoms in military personnel. JAMA Internal Medicine. 2015;175(1):53-54. | E10
44 | Hooker JS. Hyperbaric Oxygen Therapy: Using Evidence-Based Medicine to Heal Injured Brain Tissue. North Carolina Medical Journal. 2016;77(1):69-70. | B
45 | Hu Q, Manaenko A, Guo Z, Huang L, Tang J, Zhang JH. Hyperbaric oxygen therapy for post concussion symptoms: issues may affect the results. Medical Gas Research. 2015;5:10. | E10
46 | Hu Q, Manaenko A, Xu T, Guo Z, Tang J, Zhang JH. Hyperbaric oxygen therapy for traumatic brain injury: bench-to-bedside. Medical Gas Research. 2016;6(2):102-110. | E7
47 | Indiana State Department of Health. The implementation of a program for the specific treatment of veterans with traumatic brain injury or posttraumatic stress disorder as mandated by SEA 180. 2014. | B
48 | Karam C, Griggs RC. “Hyperbaric oxygen: B-level evidence in mild traumatic brain injury clinical trials”: Editors' note. Neurology. 2017;89(7):750. | E10
49 | Klugar M, Nytra I, Bocková S, Klugarová J, Kelnarová Z, Marecková J. The effectiveness of hyperbaric oxygen therapy on mortality in adults with craniotrauma: a systematic review protocol. JBI Database of Systematic Reviews and Implementation Reports. 2014;12(12):54-66. | E7
50 | Kohlenberg A, Mody K. Hyperbaric oxygen for post-concussion symptoms secondary to mild traumatic brain injury. Clinical journal of sport medicine.24(2):193. | E7
51 | Korley F, Rockswold G, Gajewski B, Martin R, Silbergleit R, Barsan W. The design of the hyperbaric oxygen brain injury treatment (Hobit) trial. Journal of neurotrauma. 2017;Conference: 35th annual national neurotrauma symposium. United states. 34(13):A59-A60. | B
52 | Marois P, Mukherjee A, Ballaz L. Hyperbaric Oxygen Treatment for Persistent Postconcussion Symptoms--A Placebo Effect? JAMA Internal Medicine. 2015;175(7):1239-1240. | E10
53 | Mathieu D, Marroni A, Kot J. Tenth European Consensus Conference on Hyperbaric Medicine: recommendations for accepted and non-accepted clinical indications and practice of hyperbaric oxygen treatment. Diving & Hyperbaric Medicine. 2017;47(1):24-32. | G
54 | McCrary BF, Weaver L, Marrs K, et al. Hyperbaric oxygen (HBO2) for post-concussive syndrome/chronic TBI--product summary. Undersea & Hyperbaric Medicine. 2013;40(5):443-467. | B
55 | McDonagh M, Helfand M, Carson S, Russman BS. Hyperbaric oxygen therapy for traumatic brain injury: a systematic review of the evidence. Archives of Physical Medicine & Rehabilitation. 2004;85(7):1198-1204. | E8
56 | McMonnies CW. Hyperbaric oxygen therapy and the possibility of ocular complications or contraindications. Clinical and Experimental Optometry. 2015;98(2):122-125. | B
57 | Meyer G, Hubbard M, Vonderhaar K, et al. Headache prevalence 30 years after severe traumatic brain injury. Brain injury. 2017;Conference: 12th world congress on brain injury of the international brain injury association. United states. 31(6-7):941. | B
58 | Miller RS, Weaver LK, Brenner LA. Hyperbaric Oxygen Treatment for Persistent Postconcussion Symptoms--Reply. JAMA Internal Medicine. 2015;175(7):1240-1241. | E10
59 | Mitchell SJ, Bennett MH. Unestablished indications for hyperbaric oxygen therapy. Diving & Hyperbaric Medicine. 2014;44(4):228-234. | B
60 | Sawyer Q, Vesci B, McLeod TC. Physical Activity and Intermittent Postconcussion Symptoms After a Period of Symptom-Limited Physical and Cognitive Rest. Journal of Athletic Training. 2016;51(9):739-742. | E2
61 | Schnurr PP, Hermann BA, Mott JM. Clinician's Trauma Update, December 2014. 2014;8:1-3. | E7
62 | Shandley S, Wolf EG, Schubert-Kappan CM, et al. Increased circulating stem cells and better cognitive performance in traumatic brain injury subjects following hyperbaric oxygen therapy. Undersea & Hyperbaric Medicine. 2017;44(3):257-269. | E4
63 | Skipper LD, Churchill S, Wilson SH, Deru K, Labutta RJ, Hart BB. Hyperbaric oxygen for persistent post-concussive symptoms: long-term follow-up. Undersea & Hyperbaric Medicine. 2016;43(5):601-613. | E4
64 | Stoller KP. All the right moves: the need for the timely use of hyperbaric oxygen therapy for treating TBI/CTE/PTSD. Medical Gas Research. 2015;5:7. | B
65 | Tal S, Hadanny A, Berkovitz N, Sasson E, Ben-Jacob E, Efrati S. Hyperbaric oxygen may induce angiogenesis in patients suffering from prolonged post-concussion syndrome due to traumatic brain injury. Restorative Neurology & Neuroscience. 2015;33(6):943-951. | E4
66 | Tal S, Hadanny A, Sasson E, Suzin G, Efrati S. Hyperbaric Oxygen Therapy Can Induce Angiogenesis and Regeneration of Nerve Fibers in Traumatic Brain Injury Patients. Frontiers in Human Neuroscience. 2017;11:508. | E4
67 | The American Legion TBI/PTSD Ad Hoc Committee. The War Within: Treatment of Traumatic Brain Injury and Post Traumatic Stress Disorder. 2013. | E7
68 | TreatNow. HBOT Research and Science. 2017. | B
69 | Tsutsumi Y, Tsutsumi I, Tsujimoto Y, et al. Hyperbaric oxygen therapy for persistent post-concussion syndrome following mild traumatic brain injury. Cochrane Database of Systematic Reviews. 2017(7). | E7
70 | United States Government Accountability Office.Research on Hyperbaric Oxygen Therapy to Treat Traumatic Brain Injury and Post-Traumatic Stress Disorder. 2015. | B
71 | Veterans Affairs/Department of Defense. Clinical Practice Guidelines for The Management of Concussion-mild Traumatic Brain Injury (mTBI). 2016. | G
72 | Veterans Affairs/Department of Defense. Clinical Practice Guideline for The Management of Posttraumatic Stress Disorder and Acute Stress Disorder. 2017. | G
73 | Wang Y, Chen D, Chen G. Hyperbaric oxygen therapy applied research in traumatic brain injury: from mechanisms to clinical investigation. Medical Gas Research. 2014;4:18. | E7
74 | Weaver LK, Cifu D, Hart B, Wolf G, Miller S. Hyperbaric oxygen for post-concussion syndrome: design of Department of Defense clinical trials. Undersea & Hyperbaric Medicine. 2012;39(4):807-814. | B
75 | Williams CS, Spitz MC, Foley JF, Weaver LK, Lindblad AS, Wierzbicki MR. Baseline EEG abnormalities in mild traumatic brain injury from the BIMA study. Undersea & Hyperbaric Medicine. 2016;43(5):521-530. | B
76 | Williams CS, Weaver LK, Lindblad AS, Kumar S, Langford DR. Baseline neurological evaluations in a hyperbaric trial of post-concussive syndrome. Undersea & Hyperbaric Medicine. 2016;43(5):511-519. | E4
77 | Wilson SH, Weaver LK, Lindblad AS. Neuropsychological assessments in a hyperbaric trial of post-concussive symptoms. Undersea & Hyperbaric Medicine. 2016;43(5):585-599. | B
78 | Xu L, Li B, Yang C, Li C, Peng Y. Clinical research on postoperative efficacy and related factors of early simulation hyperbaric oxygen therapy for severe craniocerebral injury. Pakistan Journal of Pharmaceutical Sciences. 2016;29(1 Suppl):273-280. | E4

### APPENDIX E: EVIDENCE TABLES

#### DATA ABSTRACTION OF INCLUDED SYSTEMATIC REVIEWS

Author Year # Studies # Patients | Objective Selection criteria | Search Date Databases searched QA Tool | Patient Characteristics | Overall Mortality Rate (HBOT vs Control) | GOS Improvement Rate (HBOT vs Control) | Change in PTSD Score (HBOT - Control) | Adverse Events
Bennett 2012^7^ # Studies= 7 # Patients= 571 | To assess the effects of adjunctive HBOT for acute traumatic brain injury in persons admitted to an intensive care or intensive neurosurgical facility with an acute TBI following blunt trauma Randomized studies comparing the effect of therapeutic regimens which included HBOT with those that did not, for people with traumatic brain injury. | March 2012 CENTRAL, MEDLINE, EMBASE, CINAHL, Database of Randomized Controlled Trials in Hyperbaric Medicine Cochrane Collaboration's tool for assessing risk of bias in randomized trials | Moderate and Severe TBI with or without PTSD RCTs did not include service members or Veterans Mean age range: NR Sex (male): NR | RR= 0.69 (95% CI= 0.54 to 0.88) | RR= 1.94 (95% CI= 0.92 to 4.08) | NR | Severe pulmonary complications: RR= 15.57 (95% CI= 2.11 to 114.72); NNH= 8 95% CI= 5 to 15) Seizure: RR= 5.0 (95% CI= 0.24 to 102.6) Middle ear barotrauma: RR= 5.0 (95% CI= 0.24 to 102.6)
Crawford 2017^8^ # Studies= 12 # Patients= 1,056 | This systematic review examines the efficacy of hyperbaric oxygen (HBO2) for traumatic brain injury (TBI) to make evidence-based recommendations for its application and future research Peer-reviewed study designs presented in the English language; involving subjects suffering from the consequences of TBI in both military and civilian populations; and HBO2 is being used as the intervention without preexisting conditions. | December 2014 PubMed, CINAHL, PsycInfo, and Cochrane, Database of Randomized Controlled Trials in Hyperbaric Medicine Scottish Intercollegiate Guidelines Network Checklist for RCTs (SIGN 50) | Mild, Moderate, and Severe TBI with or without PTSD Select RCTs included service members and Veterans Mean age range: NR Sex (male): NR | Two low (0) quality RCTs found no statistically significant differences between HBO2 and “standard care” groups. | In 2 acceptable (+) quality RCTs, the HBO2 groups showed statistically significant better scores versus “standard care”, whereas the third RCT found no statistically significant differences. | One acceptable (+) quality RCT reported improvements in mean change scores tended to favor sham vs. HBO2 at post-intervention. P-values not reported. | 3 of 4 RCTs involving mTBI and 3 of 7 RCTs involving moderate-severe TBI populations describe adverse events. These reports describe various ear problems including barotrauma, severe ear pain (resolved by tympanostomy) and hemotympanum; nausea; sinus squeeze and sinus pain; claustrophobia; headache; musculoskeletal chest pain; tooth pain; transient worsening of myopia; pulmonary adverse events; and the occurrence of seizures.
Wang 2016^9^ # Studies= 8 # Patients= 519 | The present meta-analysis evaluated the outcomes of HBOT in patients with traumatic brain injury (TBI). Randomized, controlled trials or two-arm prospective studies comparing normobaric vs hyperbaric oxygen therapy in patients with either severe (GCS score 3–8) or mild (GCS score 13–15) traumatic brain injury with PCS symptoms were included in the current meta-analysis. | December 10, 2014 Medline, Cochrane, EMBASE, Google Scholar Cochrane Collaboration's tool for assessing risk of bias in randomized trials | Mild, Moderate, and Severe TBI with or without PTSD Select RCTs included service members and Veterans Mean age range: 23 to 40 Sex (male): 62% to 100% | OR (FE)= 0.32 (95% CI= 0.18 to 0.57) in moderate-severe TBI from 3 overall good quality RCTs | OR (RE)= 3.78 (95% CI= 1.23 to 11.63) in moderate-severe TBI from 3 overall good quality RCTs* *Significance was driven by a single RCT | Mean change (FE)= -1.49 (95% CI= -5.79 to 2.80) in mTBI from 2 overall good quality RCTs | NR

Abbreviations: GCS=Glasgow Coma Score, Glasgow Outcome Score, HBOT=hyperbaric oxygen therapy, NNH=number needed to heal, PCS=post-concussion syndrome, PTSD=post-traumatic stress disorder, TBI=traumatic brain injury

#### QUALITY ASSESSMENT OF INCLUDED SYSTEMATIC REVIEWS

Bennett 2012^7^
Domain | Concern (Low/High/Unclear) | Rationale for Concern
1. Study eligibility criteria | Low | Review adhered to clearly stated pre-defined objectives and eligibility criteria, which were appropriate for the review question No inappropriate restrictions in eligibility criteria
2. Identification and selection of studies | Low | Appropriate range of databases searched Independent screening by 3 authors Appropriate restrictions regarding dates and language Appropriate methods for identifying additional studies (reviewing article references) and minimizing error (multiple reviewers)
3. Data collection and study appraisal | Low | Collected data using a prespecified template Data extraction was reviewed for accuracy Study quality was assessed using the Cochrane Risk of Bias tool Unclear if quality analysis was dual independent
4. Synthesis and findings | Low | All predefined analyses conducted on eligible studies, heterogeneity described, biases addressed in synthesis Quantitative synthesis was conducted as appropriate
5. Overall Risk of Bias
Did the interpretation of findings address all the concerns identified in Domains 1 to 4? (Y/ N/ NI) | | Y
Was the relevance of identified studies to the review's research question appropriately considered? (Y/ N/ NI) | | Y
Did the reviewers avoid emphasizing results based on their statistical significance? (Y/ N/ NI) | | Y
Risk of bias in the review (Low/ High/ Unclear) | | Low
Rationale for risk | | Clear methods outlined for study eligibility criteria, search, study selection, and data abstraction. Quality assessment performed using a risk of bias tool, but it was unclear if it was reviewed for accuracy. The review conclusions accurately reflect the results.

Crawford 2017^8^
Domain | Concern (Low/High/Unclear) | Rationale for Concern
1. Study eligibility criteria | Low | Review adhered to clearly stated pre-defined objectives and eligibility criteria, which were appropriate for the review question
2. Identification and selection of studies | Low | Multiple databases searched; Appropriate restrictions on dates and language; dual independent screening to minimize error in study selection
3. Data collection and study appraisal | Low | Followed Common Data Element Project's classification of outcomes for data abstraction; unclear if dual review of data abstraction; dual independent quality assessment of RCTs
4. Synthesis and findings | Low | All predefined analyses conducted on eligible studies; Qualitative synthesis was appropriate given the heterogeneity of comparators across studies
5. Overall Risk of Bias
Did the interpretation of findings address all the concerns identified in Domains 1 to 4? (Y/ N/ NI) | | Y
Was the relevance of identified studies to the review's research question appropriately considered? (Y/ N/ NI) | | Y
Did the reviewers avoid emphasizing results based on their statistical significance? (Y/ N/ NI) | | Y
Risk of bias in the review (Low/ High/ Unclear) | | Low
Rationale for risk | | Clear methods outlined for study eligibility criteria, search, study selection, and quality assessment. Data was collected following prespecified criteria, but it was unclear if data abstraction was reviewed for accuracy. The review conclusions accurately reflect the results.

Wang 2016^9^
Domain | Concern (Low/High/Unclear) | Rationale for Concern
1. Study eligibility criteria | Low | Review adhered to clearly stated pre-defined objectives and eligibility criteria, which were appropriate for the review question
2. Identification and selection of studies | Low | Multiple databases searched; reasonable restrictions on study design; dual independent screening to minimize error in study selection
3. Data collection and study appraisal | Low | Quality assessed using pre-specified tool, unclear if dual review of quality assessment; dual independent data collection
4. Synthesis and findings | Low | Synthesis methods pre-specified; Meta-analysis included all studies; Sensitivity and heterogeneity assessed
5. Overall Risk of Bias
Did the interpretation of findings address all the concerns identified in Domains 1 to 4? (Y/ N/ NI) | | Y
Was the relevance of identified studies to the review's research question appropriately considered? (Y/ N/ NI) | | Y
Did the reviewers avoid emphasizing results based on their statistical significance? (Y/ N/ NI) | | Y
Risk of bias in the review (Low/ High/ Unclear) | | Low
Rationale for risk | | Clear methods outlined for study eligibility criteria, search, study selection, data abstraction, and meta-analysis. Study quality assessment was done, but it was unclear if it was reviewed for accuracy. The review conclusions accurately reflect the results.

#### QUALITY ASSESSMENT OF SUBSET OF INCLUDED PRIMARY STUDIES

##### Quality Assessment of RCTs

Author Year | Randomization adequate? Adequate allocation concealment? | Groups similar at baseline? | Outcome assessors, care provider, patient masked? | Outcome measurement equal, reliable, and valid? | Intention-to-treat (ITT) analysis? | Acceptable levels of crossovers, adherence, and contamination? | Acceptable levels of overall attrition and between-group differences in attrition? | Quality
Boussi-Gross 2013^10^ | Unclear; Not described Unclear; Not described | Yes 2 years more education in the treatment group | Yes No No | Yes | No | Unclear Adherence to HBOT protocol not described | No Intervention group= 28.9% Crossover group= 46.7% | Fair
Miller 2015^11^ | Yes; Permutated block method Unclear; Not described | Yes | Yes Yes Yes | Yes | Yes Exclusion of <5% of patients from analysis | Yes All but 2 did not receive intervention | Yes Intervention group= 4% (1/24) Sham group= 16% (4/25) Control group= 13% (3/23) | Fair
Ren 2001^12,13^ | Unclear; Not described Unclear; Not described | Unclear No statistical testing at baseline. Potential differences in CT scan findings | Unclear No No | Yes | Unclear Missing data not described, potential differences in #s used for analyses | Unclear Adherence to HBOT protocol not described | Unclear Not specifically described | Fair
Rockswold 2013^14^ | Unclear; Not described Unclear; Not described | Yes | Yes Unclear No | Yes | Yes Exclusion of <5% of patients from analysis | Unclear Adherence to HBOT protocol not described | Yes Intervention group = 5% (1/20) Crossover group= 4.5% (1/22) | Fair

#### STRENGTH OF EVIDENCE

SOE Grade (High, moderate, low) | Study Design: No. Studies (N) | Study Limitations (High, medium, low) | Directness (Direct or indirect) | Consistency (Consistent, inconsistent, unknown for single study) | Precision (precise or imprecise) | Reporting Bias (Suspected, undetected) | Other Issues (None or describe) | Finding (Results – describe direction in words (greater or lower risk or no difference) and provide data
Mild TBI
Post-concussion symptom response: Low | 1 RCT (72]^11^ | Medium | Direct | Unknown | Imprecise | Undetected | None | No meaningful differences were detected between the HBOT, sham, or control groups (percent of patients with ≥ 2-point RPQ-3 improvement: 52% vs 33% vs 25%; P=0.24)
Quality of life: Low | 1 RCT (72)^11^ | Medium | Direct | Unknown | Imprecise | Undetected | None | Results favored sham over HBOT group for physical functioning, bodily pain, social functioning, and emotional domains on the SF-36
Ear barotrauma at 1.5 ATA: Low | 1 RCT (72)^11^ | Medium | Direct | Unknown | Imprecise | Undetected | None | HBOT led to more ear barotrauma compared to sham when given at higher dosages (8% vs 0% at 1.5 ATA for 60 minute sessions)^11^).
Ear barotrauma at 2.4 ATA: Low | 1 RCT (50)^15^ | Medium | Direct | Unknown | Imprecise | Undetected | None | HBOT led to more ear barotrauma compared to sham when given at higher dosages (42% vs 16%, P = 0.57 at 2.4 ATA for 90 minute sessions)^15^
Moderate to Severe TBI
Mortality: Moderate | 3 RCTs (263) ^13,14,16^ | Medium | Direct | Consistent | Precise | Undetected | None | HBOT reduced odds of death by 68% (OR 0.32; 95% CI 0.18 to 0.57) compared to control groups^9^
Glasgow Outcome Scale (GOS): Low | 3 RCTs (141) ^13,14,17^ | Medium | Direct | Inconsistent | Imprecise | Undetected | Sensitivity analysis showed the results to be insignificant after the removal of 1 RCT,^13^ indicating that the meta-analysis had poor reliability.^9^ | HBOT improved GOS by 278% (OR 3.78; 95% CI 1.23 to 11.63) compared to the control groups. However, after removal of 1 RCT,^13^ HBOT did not significantly improve GOS (OR 2.18; 95% CI 0.92 to 5.17).^9^ The large effect in Ren cannot be explained.
Pulmonary complications: Low | 2 RCTs (228)^16,18^ | Medium | Direct | Consistent | Imprecise | Undetected | None | HBOT significantly increased risk of severe pulmonary complications (13% vs 0%; RR 15.57; 95% CI, 2.11 to 114.72) compared to control.^7^
Seizures: Low | 1 RCT (168)^16^ | Medium | Direct | Unknown | Imprecise | Undetected | None | HBOT did not significantly increase seizures (2.3% vs 0%; RR 5.0; 95% CI 0.24 to 102.6) compared to control.^7^
Ear barotrauma (Hemotympanum): Low | 1 RCT (168)^16^ | Medium | Direct | Unknown | Imprecise | Undetected | None | HBOT did not significantly increase hemotympanum (2.3% vs 0%; RR 5.0; 95% CI 0.24 to 102.6) compared to control.^7^

### APPENDIX F: RESEARCH IN PROGRESS

Status | Study Title | Study Design | Information Resources (Registry #; citation(s) for published protocols; links to project websites)
Unknown, past anticipated completion date | The effect of hyperbaric oxygen therapy on post-concussion syndrome: a systematic review and meta-analysis | SR | Yan Dong. The effect of hyperbaric oxygen therapy on post-concussion syndrome: a systematic review and meta-analysis. PROSPERO 2016:CRD42016032620 Available from http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=CRD42016032620
Unknown, past anticipated completion date | The effectiveness of hyperbaric oxygen therapy on mortality in adults with craniotrauma: a systematic review | SR | Miloslav Klugar, Ivana Nytra, Sona Bocková, Jitka Klugarová, Zuzana Kelnarová, Jana Marecková. The effectiveness of hyperbaric oxygen therapy on mortality in adults with craniotrauma: a systematic review protocol. PROSPERO 2015:CRD42015016547 Available from http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=CRD42015016547 Published Protocol (http://connect.jbiconnectplus.org/ViewSourceFile.aspx?0=12167)
Completed, outcome results not yet published | mTBI Mechanisms of Action of HBO2 for Persistent Post-Concussive Symptoms (BIMA) | RCT | U.S. Army Medical Research and Materiel Command NCT01611194 (https://clinicaltrials.gov/ct2/show/NCT01611194?term=hyperbaric&age=12&draw=3&rank=137)
Currently recruiting | Hyperbaric Treatment of Traumatic Brain Injury (TBI) | RCT | Barry Miskin, MD, Jupiter Medical Center NCT01847755 (https://clinicaltrials.gov/ct2/show/NCT01847755)
Currently recruiting | Hyperbaric Oxygen Treatment to Treat Mild Traumatic Brain Injury (mTBI)/Persistent Post-Concussion Syndrome (PPCS) | RCT | Paul G. Harch, M.D., Louisiana State University Health Sciences Center in New Orleans NCT02089594 (https://clinicaltrials.gov/ct2/show/NCT02089594)
Currently recruiting | Hyperbaric Oxygen Therapy and SPECT Brain Imaging in Traumatic Brain Injury | RCT | Paul G. Harch, M.D., Louisiana State University Health Sciences Center in New Orleans NCT00594503 (https://clinicaltrials.gov/ct2/show/NCT00594503?term=hyperbaric&age=12&draw=3&rank=110)
Currently recruiting | Magnetic resonance imaging study of hyperbaric oxygen treatment on cognitive dysfunction after traumatic brain injury | RCT | Liu Yang, Department of Rehabilitation Medicine, Fuzhou General Hospital of Nanjing Military Command, PLA. Fuzhou, Fujian, China ChiCTR-IOR-16010091 (http://apps.who.int/trialsearch/Trial2.aspx?TrialID=ChiCTR-IOR-16010091)
Not yet recruiting | Hyperbaric Oxygen Brain Injury Treatment Trial (HOBIT) | RCT | Minneapolis Medical Research Foundation NCT02407028 (https://clinicaltrials.gov/ct2/show/NCT02407028?term=hyperbaric&age=12&draw=3&rank=140)
Terminated | Hyperbaric Oxygen Therapy in Chronic Traumatic Brain Injury or Post-Traumatic Stress Disorder (NBIRR-1) | RCT | International Hyperbaric Medical Foundation NCT01105962 (https://clinicaltrials.gov/ct2/show/NCT01105962?cond=PTSD+or+tbi&intr=hyperbaric&rank=2) (new regulatory requirements will require funding for restart as a new study)

### APPENDIX G: PEER REVIEW

## REFERENCES

1 Adams E. Hyperbaric oxygen therapy for traumatic brain injury and post traumatic stress disorder. VA Technology Assessment Program. 2010.
2 Veterans Affairs/Department of Defense. Clinical practice guideline for the management of posttraumatic stress disorder and acute stress disorder. 2017.
3 Veterans Affairs/Department of Defense. Clinical practice guidelines for the management of concussion-mild traumatic brain injury (mTBI). 2016.
4 Colorado Division of Workers' Compensation. Traumatic brain injury medical treatment guidelines. 2012, https://guideline.gov/summaries/summary/43752/traumatic-brain-injury-medical-treatment-guidelines?q=hyperbaric.
5 Carney N, Totten AM, O'Reilly C, . Guidelines for the management of severe traumatic brain injury. Neurosurgery. 2017;80(1):6-15.27654000
6 Mathieu D, Marroni A, Kot J. Tenth European consensus conference on hyperbaric medicine: Recommendations for accepted and non-accepted clinical indications and practice of hyperbaric oxygen treatment. Diving & Hyperbaric Medicine. 2017;47(1):24-32.28357821
7 Bennett MH, Trytko B, Jonker B. Hyperbaric oxygen therapy for the adjunctive treatment of traumatic brain injury. Cochrane Database of Systematic Reviews. 2012;12:CD004609.
8 Crawford C, Teo L, Yang E, Isbister C, Berry K. Is hyperbaric oxygen therapy effective for traumatic brain injury? A rapid evidence assessment of the literature and recommendations for the field. Journal of Head Trauma Rehabilitation. 2017;32(3):E27-E37.
9 Wang F, Wang Y, Sun T, Yu HL. Hyperbaric oxygen therapy for the treatment of traumatic brain injury: A meta-analysis. Neurological Sciences. 2016;37(5):693-701.26746238
10 Boussi-Gross R, Golan H, Fishlev G, . Hyperbaric oxygen therapy can improve post concussion syndrome years after mild traumatic brain injury - randomized prospective trial. PLoS One. 2013;8(11):e79995.24260334
11 Miller RS, Weaver LK, Bahraini N, . Effects of hyperbaric oxygen on symptoms and quality of life among service members with persistent postconcussion symptoms: A randomized clinical trial. JAMA Internal Medicine. 2015;175(1):43-52.25401463
12 Ren H, Wang W, Ge Z. Glasgow coma scale, brain electric activity mapping and Glasgow Outcome Scale after hyperbaric oxygen treatment of severe brain injury. Chinese Journal of Traumatology= Zhonghua Chuang Shang Za Zhi. 2001;4(4):239-241.11835741
13 Ren H, Wang W, Ge Z, Zhang J. Clinical, brain electric earth map, endothelin and transcranial ultrasonic doppler findings after hyperbaric oxygen treatment for severe brain injury. Chinese Medical Journal. 2001;114(4):387-390.11780460
14 Rockswold SB, Rockswold GL, Zaun DA, Liu J. A prospective, randomized phase II clinical trial to evaluate the effect of combined hyperbaric and normobaric hyperoxia on cerebral metabolism, intracranial pressure, oxygen toxicity, and clinical outcome in severe traumatic brain injury. Journal of Neurosurgery. 2013;118(6):1317-1328.23510092
15 Wolf EG, Baugh LM, Kabban CM, Richards MF, Prye J. Cognitive function in a traumatic brain injury hyperbaric oxygen randomized trial. Undersea & Hyperbaric Medicine. 2015;42(4):313-332.26403017
16 Rockswold GL, Ford SE, Anderson DC, Bergman TA, Sherman RE. Results of a prospective randomized trial for treatment of severely brain-injured patients with hyperbaric oxygen. Journal of Neurosurgery. 1992;76(6):929-934.1588426
17 Lin J-W, Tsai J-T, Lee L-M, . Effect of hyperbaric oxygen on patients with traumatic brain injury. Reconstructive Neurosurgery. 2008:145-149.
18 Artru F, Chacornac R, Deleuze R. Hyperbaric oxygenation for severe head injuries. European Neurology. 1976;14(4):310-318.782888
19 U.S. Food & Drug Administration. Hyperbaric oxygen therapy: Don't be misled. 2013, https://www.fda.gov/forconsumers/consumerupdates/ucm364687.htm.Accessed February 21, 2018
20 Staff MC Tests and procedures: Hyperbaric oxygen therapy. 2014, https://www.mayoclinic.org/tests-procedures/hyperbaric-oxygen-therapy/basics/why-its-done/prc-20019167. https://www.mayoclinic.org/tests-procedures/hyperbaric-oxygen-therapy/basics/why-its-done/prc-20019167. Accessed November 15, 2017.
21 Cifu DX, Hart BB, West SL, Walker W, Carne W The effect of hyperbaric oxygen on persistent postconcussion symptoms. Journal of Head Trauma Rehabilitation. 2014;29(1):11-20.24052094
22 Cifu DX, Hoke KW, Wetzel PA, Wares JR, Gitchel G, Carne W Effects of hyperbaric oxygen on eye tracking abnormalities in males after mild traumatic brain injury. Journal of Rehabilitation Research & Development. 2014;51(7):1047-1056.25436771
23 Cifu DX, Walker WC, West SL, . Hyperbaric oxygen for blast-related postconcussion syndrome: Three-month outcomes. Annals of Neurology. 2014;75(2):277-286.24255008
24 Wolf EG, Prye J, Michaelson R, Brower G, Profenna L, Boneta O Hyperbaric side effects in a traumatic brain injury randomized clinical trial. Undersea Hyperb Med. 2012;39(6):1075-1082.23342764
25 Wolf G, Cifu D, Baugh L, Carne W, Profenna L The effect of hyperbaric oxygen on symptoms after mild traumatic brain injury. J Neurotrauma. 2012;29(17):2606-2612.23031217
26 Hadanny A, Efrati S The efficacy and safety of hyperbaric oxygen therapy in traumatic brain injury. Expert Review of Neurotherapeutics. 2016;16(4):359-360.26900796
27 Weaver L Hyperbaric oxygen therapy indications: The Hyperbaric Oxygen Therapy Committee report. Undersea and Hyperbaric Medical Society; 2014.
28 Harch PG Hyperbaric oxygen therapy for post-concussion syndrome: Contradictory conclusions from a study mischaracterized as sham-controlled. J Neurotrauma. 2013;30(23):1995-1999.24004322