# Evidence Brief: Factors that Optimize Therapy with Repetitive Transcranial Magnetic Stimulation for Treatment-Resistant Depression

## PREFACE

Quality Enhancement Research Initiative's (QUERI) Evidence-based Synthesis Program (ESP) was established to provide timely and accurate syntheses of targeted healthcare topics of particular importance to Veterans Affairs (VA) clinicians, managers and policymakers as they work to improve the health and healthcare of Veterans. The ESP disseminates these reports throughout the VA, and some evidence syntheses inform the clinical guidelines of large professional organizations.

QUERI provides funding for four ESP Centers and each Center has an active university affiliation. The ESP Centers generate evidence syntheses on important clinical practice topics, and these reports help:

- develop clinical policies informed by evidence;
- guide the implementation of effective services to improve patient outcomes and to support VA clinical practice guidelines and performance measures; and
- set the direction for future research to address gaps in clinical knowledge.

In 2009, the ESP Coordinating Center was created to expand the capacity of HSR&D Central Office and the four ESP sites by developing and maintaining program processes. In addition, the Center established a Steering Committee comprised of QUERI field-based investigators, VA Patient Care Services, Office of Quality and Performance, and Veterans Integrated Service Networks (VISN) Clinical Management Officers. The Steering Committee provides program oversight, guides strategic planning, coordinates dissemination activities, and develops collaborations with VA leadership to identify new ESP topics of importance to Veterans and the VA healthcare system.

Comments on this evidence report are welcome and can be sent to Nicole Floyd, ESP Coordinating Center Program Manager, at Nicole.Floyd@va.gov

## EXECUTIVE SUMMARY

Major depressive disorder is one of the most common mental disorders in the general and Veteran populations. The one- to two-thirds of MDD patients who do not respond to the first antidepressant prescribed, and the 15% to 33% who do not respond to multiple drugs are defined as having treatment-resistant depression (TRD). Repetitive transcranial magnetic stimulation (rTMS) is one of many possible options for treating TRD. It is supported by two FDA-cleared protocols and acceptable acute efficacy based on a recent Comparative Effectiveness Review conducted by the RTI-UNC EPC. This Evidence Brief synthesizes the literature on factors that optimize rTMS therapy in patients with TRD.

### WHICH PATIENTS HAVE THE BEST CHANCE OF SUCCESS WITH rTMS?

Whether the effectiveness of rTMS treatment differs by sex or in young (age 18-37 years) or older adults (age ≥ 65 years) is unclear. But evidence suggests that patients with unipolar or bipolar depression, with more or less stringently defined TRD, and who are treated with rTMS as monotherapy or as augmentation to pharmacotherapy, have similar chances of success with LHF-DLPFC rTMS. A major limitation of rTMS studies is that they generally exclude patients with medical and psychiatric comorbidities.

### WHAT ARE THE OPTIMAL rTMS TREATMENT PROTOCOLS AND PARAMETERS?

High-frequency rTMS applied to the left dorsolateral prefrontal cortex is the most well-studied approach and it includes a FDA-cleared protocol that has been shown to improve quality of life. But no particular protocol has been shown to have any advantages over others in head-to-head trials. In terms of dose for LHF-DLPFC, 2 large multicenter RCTs support using 10 Hz, 120% RMT, 5 days a week for 3-6 weeks to guarantee adequate stimulation. Intensities down to 100% may also be effective in certain patients. The effects of variability in coil geometry, coil placement, session duration, timing, or number of sessions remain unclear.

### WHAT IS KNOWN ABOUT CONTINUATION AND MAINTENANCE TREATMENT IN RESPONDERS?

Available evidence is inadequate for determining the value of maintenance rTMS in general and for defining optimal treatment parameters.

### CONCLUSIONS

There is a great need to determine the effects of rTMS in TRD patients with medical and psychiatric comorbidities and to determine the long-term durability of rTMS response. Although the optimum protocols and parameters have not yet been determined, the best evidence available supports use of the FDA-cleared LHF-DLPFC protocol. However, nearly all of this evidence was developed in experimental settings. In order to collect meaningful data from clinical experience, the VA should increase standardization of rTMS delivery. In the meantime, rTMS has acceptable acute efficacy and, compared to ECT, rTMS is less invasive, has a safety advantage for some patients, and may have more comparable benefits in TRD patients than originally thought.

## INTRODUCTION

A 2014 Department of Veterans Affairs (VA) Memorandum states, “Before rTMS can be incorporated into clinical practice guidelines or treatment algorithms for depression, more research is needed to address a number of questions including who may benefit, under what treatment protocol, and how treatment outcomes will be measured.”1,2 Important components of coverage policy design include identifying which subpopulations will benefit the most, which protocol is ideal, and the long-term efficacy of an intervention. To answer these questions, the VA is undertaking a number of research efforts. First, the VA's Office of Research and Development has implemented a large-scale ongoing cooperative study of rTMS compared with sham in Veterans with treatment-resistant depression and possible comorbid post-traumatic stress disorder (PTSD) and/or a history of substance abuse (CSP #556, NCT01191333). Second, the VA has proposed evaluating data from their own accumulating experience with rTMS on a system-wide basis. Third, the Mental Health Operations (10NC5) and Mental Health Services (10P4M) in the Office of Patient Care Services requested that the VA Evidence-based Synthesis Program Coordinating Center (ESP CC) conduct an Evidence Brief to synthesize the literature on factors that optimize therapy with rTMS in patients with TRD.

## BACKGROUND

Major depressive disorder (MDD) continues to be one of the most common mental disorders in the United States. In the general population, roughly 5 to 7% have had an episode of depression in the past 12 months and 13% have had an episode at some point in their life.3,4 The estimated prevalence of depression is higher among recently deployed service members compared with the general US population; 11% to 17% of soldiers returning from Afghanistan or Iraq meet current criteria for depression.5-7 Among Operation Iraqi Freedom (OIF) and Operation Enduring Freedom (OEF) Veterans entering VA health care from 2001 to 2010, 17% to 22% were diagnosed with depression.6,8 Another survey of US Army soldiers and National Guard infantry brigade combat teams estimated the prevalence of depression ranged from 12% to 16% following deployment.5

OIF and OEF Veterans also have a greater burden of comorbid mental health conditions compared with the general population. OIF and OEF Veterans entering VA health care from 2002 to 2008 had 4 to 5 times greater 12-month prevalence of 2 (29% vs 5.8%) and 3 or more (27% to 33% vs 6%) comorbid DSM-IV disorders than for the general population.4

Treatment-resistant depression (TRD) is defined as depression resistant to antidepressant medications. Between one- and two-thirds of MDD patients will not respond to the first antidepressant prescribed, and 15% to 33% will not respond to multiple drugs.9,10 Among clinical studies, case definitions of TRD differ in:

- The number of antidepressant treatment failures: one, 2, or more than 2^11^
  ○ For a failed antidepressant trial, what constitutes a “sufficient” length of time or an “adequate dose”;12,13
  ○ With or without a change in antidepressant class;11
- The degree of effect: from non-response (< 25% symptom reduction from baseline) to response without remission (50% or greater symptom reduction from baseline without achieving remission);13
- Whether antidepressant treatment failed in the current episode or in a past episode.14

Some have suggested that patients with TRD should be classified to differentiate those resistant to all first-line interventions (including antidepressant medication and psychotherapy) from those resistant to one type of first-line intervention (for example, SSRI-TRD).11

Options for treating patients with TRD include various pharmacologic and nonpharmacologic strategies. Pharmacologic options include optimization of current treatment, combination of antidepressants, switching to a different antidepressant, and augmentation of antidepressants with neuromodulator drugs.12 Non-pharmacologic options include psychotherapy, electroconvulsive therapy (ECT), transcranial magnetic stimulation (TMS) or repetitive transcranial magnetic stimulation (rTMS), vagus nerve stimulation (VNS), and deep brain stimulation (DBS).12

Over the last decade, research on rTMS as a potential treatment for TRD has gained momentum. Using an electromagnetic coil system, rTMS delivers short, repeated pulses of magnetic energy intended to activate cortical nerve cells within the area of interest and indirectly stimulate the limbic system, the area of the brain that influences emotion.2 An rTMS system consists of a treatment chair, mobile console and touchscreen display, and an electromagnetic coil. The patient sits in the treatment chair and wears a helmet connected to an apparatus holding the electromagnetic coil. The patient's resting motor threshold, defined as the stimulator setting that moves the patient's thumb 50% of the time, is determined in the first session of rTMS using single magnetic pulses over the motor cortex. Resting motor threshold (RMT) is used to determine the treatment level that will be used to minimize seizure risk and to determine the amount of stimulation needed to penetrate the cortex.2 rTMS can be administered in an outpatient or inpatient setting, and facilities providing rTMS require additional staffing, infrastructure, and credentialing/training resources aside from the cost of obtaining an rTMS system.2 A licensed psychiatrist prescribes and oversees treatment and a psychiatrist or trained staff member administers treatment and ensures patient safety.2 System operators must complete the appropriate trainings before using any rTMS therapy system, including system efficacy and safety, general information on clinical use, hands-on training in determining motor threshold, identifying treatment location(s), and moving and seating the treatment coil.2 Training is typically provided by the manufacturer and through appropriate non-vendor courses and certifications required by many insurance companies and health systems, including the VHA.2

TMS encompasses a wide spectrum of treatments. Aside from a single TMS stimulation, repetitive TMS, and deep TMS, strategies for using rTMS vary based on types of coils, region of the brain stimulated (ie, left or right dorsolateral prefrontal cortex, or bilateral), “dose” (eg, intensity, percent of resting motor threshold (% RMT)), speed of pulses (ie, Hz, pulses per second), pulse train duration, inter-train interval, trains per session, total number of pulses,* number of weekly sessions, duration (ie, 2 to 6 weeks), and total number of sessions.

To date, the US Food and Drug Administration has granted 510(k) marketing clearance to 2 specific rTMS protocols and devices for use in TRD.15,16 The first was in October 2008 for the NeuroStar TMS device (manufactured by Neuronetics, Inc.) for use specifically in patients who failed one, but no more than one, adequate antidepressant medication trial. The protocol reviewed by the FDA is 3,000 high-frequency (10 Hz) pulses administered to the left dorsolateral prefrontal cortex at 120% of motor threshold on a schedule of 5 sessions per week for 4-6 weeks (60,000 to 90,000 total pulses). The reason for the limitation to one previous treatment failure was that the initial data submitted by the manufacturer showed no efficacy among patients who had failed two or more antidepressant trials.17 In 2014, in response to the results from another multicenter sham-controlled RCT, sponsored by the National Institutes of Health (NIH),18 the clearance was expanded to include patients who had failed one or more prior antidepressant medications in the current episode.19

In 2013, the FDA cleared a second device, the Brainsway Deep TMS System, for use in adult patients who failed to achieve satisfactory improvement from one or more courses of anti-depressant medication treatment in the current episode of major depression. The specific cleared deep TMS parameters include an intensity of 120% of resting motor threshold, a frequency of 18 Hz, 1980 pulses per session, on a schedule of 5 daily sessions for 4 weeks (39,600 total pulses).

The American Psychiatric Association (APA) recommends ECT as a treatment of choice for patients with severe MDD that is not responsive to psychotherapeutic and/or pharmacological interventions.20 The recommendation was based on older meta-analyses of clinical trials which found remission rates of 70% to 90% for major depression and demonstrated that ECT is more effective and works faster than other therapies with which it has been compared, including rTMS.21,22 Although a 2014 meta-analysis confirmed these older findings about the superiority of ECT for severe or resistant major depression overall,23 findings from other recent meta-analyses that focused exclusively on TRD suggest there may be less of a difference between ECT and rTMS in TRD subgroups in response (range, 20% to 64% vs 20% to 58%) and remission (range, 15% to 53% vs 9% to 43%).14,24,25 ECT requires general anesthesia and is associated with transient episodes of hypertension, tachycardia, and arrhythmia, is still socially stigmatized, has high relapse rates (> 60%), and, in a community-based setting, may have more modest remission rates than expected.26

Several professional societies have issued clinical practice guidelines on the use of rTMS for treating depression, including the American Psychiatric Association (APA),20 World Federation of Societies of Biological Psychiatry Task Force (WFSBPTF),27 the Canadian Network for Mood and Anxiety Treatments (CANMAT),28 the National Collaborating Centre for Mental Health (NCCMH) in the UK,29 and, most recently, the International Federation of Clinical Neurophysiology.30 All but the NCCMH regard rTMS as a clinically relevant technique to treat major depression, including treatment-resistant depression. The NCCMH recommends that TMS should only be performed in research studies designed to investigate factors that might increase the procedure's clinical efficacy.29

Several recent systematic reviews have examined the efficacy of rTMS compared with sham specifically for treatment-resistant depression.14,24,25,31-33 Among these, the Agency for Healthcare Research and Quality's (AHRQ) Comparative Effectiveness Review (CER) conducted by the RTI International-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC)14,24 and a health technology assessment completed by the University of Calgary conducted to inform the Alberta Health Technologies Decision Process25 are the two highest quality and most comprehensive. Across 31 TRD RCTs overall (N=1377), regardless of definition of TRD, the University of Calgary reported that the average short-term response rate was over 2 times greater after rTMS compared with sham (30% vs 12%) with a number needed to treat (NNT) of 6 to benefit one additional patient, and that the average short-term remission rate was over 2 times greater with rTMS (20% vs 7%), with an NNT of 8. Gains were even greater among the subset of 15 RCTs (N=642) using the most stringent definition of TRD, based on the RTI-UNC EPC CER findings of high-strength evidence that the average short-term response rate was over 3 times greater after rTMS compared with sham (29% vs 8%) with an NNT of 5 to benefit one additional patient, and that the average short-term remission rate was over 5 times greater with rTMS (28% vs 5%), with an NNT of 5. The RTI-UNC EPC also noted the response and remission rates for rTMS were consistent with other standard pharmacologic next-step options for TRD, including switching to a different antidepressant or adding a second antidepressant. However, they also concluded that there is only low-strength evidence that rTMS improves short-term health-related outcomes (eg quality of life, health status, and daily functioning) and insufficient evidence regarding short-term withdrawals due to adverse events and maintenance of remission.

Insurance coverage of rTMS treatment is mixed, and to help make coverage decisions, several health plans have conducted their own reviews.34-36 The BlueCross BlueShield Technology Assessment Program published an updated assessment on the effect of TMS therapy on depression in early 2014.^34^ The assessment relied on results from 2 published trials,17,18 FDA documents, extension studies, and 7 meta-analyses, and concluded that, while the mechanism by which TMS might improve depression is biologically plausible, large trials and meta-analyses do not provide convincing evidence of improved health outcomes.34 In 2013, United Healthcare published a medical policy on TMS that stated “there is insufficient evidence that transcranial magnetic stimulation (TMS) is beneficial for health outcomes in patients with major depression.”36 Anthem (Wellpoint) covers rTMS for major depression with one of the 2 FDA-cleared devices for patients meeting very strict criteria.35 CMS has not issued a coverage policy on rTMS; however, a number of Medicare contractors have issued Local Coverage Determinations regarding rTMS coverage. Cahaba Government Benefit Administrators®, LLC (L32834), Palmetto GBA (L34170), Novitas Solutions, Inc. (L32055 and L33660), and First Coast Service Options, Inc. (L33676) cover rTMS for patients diagnosed with resistant depression with some requirements on the definition of resistance and limitations on which patients can safely receive rTMS treatment. Conversely, National Government Services, Inc. (L32038), Wisconsin Physicians Service Insurance Corporation (L32220), and Noridian Healthcare Solutions, LLC (L33495) have issued non-coverage policies, concluding that rTMS is not medically necessary.

## SCOPE

An evidence brief differs from a full systematic review in that the scope is narrowly defined and the traditional review methods are streamlined in order to synthesize evidence within a shortened timeframe. An evidence brief does not outline the full context in which the information is to be used and does not present a comprehensive assessment of knowledge on the topic. Brief or rapid review methodology is still developing and there is not yet consensus on what represents best practice.

The objective of this Evidence Brief is to synthesize the literature on factors that optimize therapy with rTMS in patients with TRD. The ESP CC investigators and representatives of the Mental Health Operations (10NC5) and Mental Health Services (10P4M) in the Office of Patient Care Services worked together to identify the population, comparator, outcome, timing, setting, and study design characteristics of interest. The Mental Health Operations (10NC5) and Mental Health Services (10P4M) in the Office of Patient Care Services approved the following key questions and eligibility criteria to guide this review:

### KEY QUESTIONS

- Key Question 1: For adults with TRD, how do the benefits and harms of treatment with rTMS differ in subpopulations based on age, gender, TRD symptom subtypes, comorbid mental health conditions, complicating medication conditions, and definitions of treatment resistance?
- Key Question 2: For adults with TRD, how do the benefits and harms of treatment with rTMS differ based on variation in rTMS treatment protocol (eg, coil geometry, coil placement, stimulus parameters, duration of a treatment session, timing and number of sessions, etc)?
  ○ Key Question 2a: What defines an adequate course of treatment?
- Key Question 3: For adults with TRD, what is the evidence about early predictors of rTMS treatment benefit?
- Key Question 4: What is known about the need for and effectiveness of continuation or maintenance treatment to prevent relapses or recurrences in patients who have responded to rTMS?

### INCLUSION CRITERIA

The ESP CC included studies that met the following criteria:

- Population: Adults with treatment-resistant depression, defined as some history of treatment failure. We expect that studies will vary in how treatment resistance is defined. We will accept any definition that refers to a history of treatment failure, even if not well-characterized, and will analyze results based on variation found.
- Intervention: Repetitive transcranial magnetic stimulation, given as a single treatment or part of a combination treatment.
- Comparator: Any pharmacologic, nonpharmacologic, or sham interventions.
- Outcomes:
  ○ Benefits: Response, remission, maintenance of response or remission (eg, preventing relapse or recurrence) quality of life, functional capacity.
  ○ Harms: Withdrawals due to adverse events, seizures, cognitive dysfunction.
- Timing: Any duration of follow-up.
- Setting: Any setting.
- Study design: Systematic reviews, technology assessments, controlled clinical trials, and intervention series with well-defined inclusion criteria.

## METHODS

The protocol for this Evidence Brief was published on the PROSPERO register (CRD42014009579). To identify articles relevant to the key questions, our research librarian searched MEDLINE (1946-April 2014), PsychINFO (1806-April 2014), and the Cochrane Library using the terms repetitive transcranial magnetic stimulation and treatment-resistant depression (see Supplemental Materials for complete search strategies). Additional citations were identified from hand searching reference lists and consultation with content experts. We limited the search to published and indexed articles involving human subjects available in the English language. Study selection was based on the eligibility criteria described above. Titles, abstracts, and full-text articles were reviewed by one investigator and checked by another. All disagreements were resolved by consensus.

Due to the volume of literature encountered, we added a post-hoc requirement that, in order to be included in this report, studies must report both benefits and harms of rTMS. In the absence of RCTs reporting both benefits and harms or multicenter trials, we used a best-evidence approach.37 Further, we only rated the internal validity (quality) of multicenter trials and systematic reviews. We used the Cochrane Collaboration's Risk of Bias Tool to rate the internal validity of all multicenter trials based on adequate sequence generation, allocation concealment, blinding, assessment of incomplete data, outcome reporting bias, and other sources of bias.38 We used the AMSTAR tool to assess the quality of included systematic reviews.39 We abstracted data for each outcome from selected studies (available from the authors upon request). All data abstraction and internal validity ratings were first completed by one reviewer and then checked by another. All disagreements were resolved by consensus.

For meta-analysis, we used random-effects models to estimate pooled effects. Forest plots graphically summarize results of individual studies and of the pooled analysis. The Q statistic and the I^2^ statistic (the proportion of variation in study estimates due to heterogeneity) were calculated to assess heterogeneity in effects between studies. Meta-analyses were conducted using StatsDirect statistical software (StatsDirect Ltd. 2013. Altrincham, UK). Due the time limitations of this Brief, we did not formally rate the Strength of Evidence. Instead we informally applied the principles recommended by the AHRQ Methods Guide for Comparative Effectiveness Reviews (risk of bias (includes study design and aggregate quality), consistency, directness, and precision) to interpret the evidence and commented on relevant limitations in these domains.40

A previous version of this Evidence Brief was reviewed by 4 invited peer reviewers. The peer review disposition table can be found in the Supplemental Materials.

## RESULTS

### OVERVIEW

Figure 1 provides the results of the study selection process. A full listing of all studies excluded at the full-text level is provided in the Supplemental Materials.

Figure 1 Literature Flow Chart

The Agency for Healthcare Research and Quality's (AHRQ) Comparative Effectiveness Review (CER) conducted by the RTI International-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC)14,24 and the health technology assessment completed by the University of Calgary conducted to inform the Alberta Health Technologies Decision Process25 provide the best source of evidence to answer some of our Key Questions. Table 1 summarizes all relevant findings from the RTI-UNC EPC and University of Calgary reviews. After Table 1, we describe findings from all other systematic reviews and original studies we reviewed to supplement gaps in the RTI-UNC EPC and University of Calgary reviews.

Table 1 Summary of all relevant findings from the RTI-UNC EPC and University of Calgary reviews

RTI-UNC EPC-University of Calgary

KQ1: Benefits/harms in subpopulations
Age: None-None
Sex: None
Bipolar Depression: rTMS was as effective in patients who had bipolar depression as in patients with major depression. This conclusion was based on a comparison of the results of rTMS versus sham for response (5.40, 95% CI 1.88 to 15.50 compared with 3.38, 95% CI, 2.24 to 5.10) or remission (15.19, 95% CI, 2.13 to 108.47 compared with 5.07, 95% CI, 2.50 to 10.30) for patients with major depression versus studies that had a mix of patients with bipolar or unipolar depression.
Depression Severity: Since nearly all patients in the included RCTs were severely depressed, no difference in treatment outcomes by severity of depression could be detected.
Comorbid psychiatric and medical conditions: None
Concomitant medications: Due to the small number of studies and great variability between them, no difference in rTMS outcomes could be detected by pharmacotherapy strategy.
TRD Defnition: Classified studies based on whether they defined TRD as failure 2 or more prior antidepressant courses of adequate dose and duration (Tier 1); 1 or more antidepressant failures (Tier 2), or did not report the number of failures (Tier 3). They found no clear difference between the pooled estimates of rTMS versus sham for the Tier 1-only and combined Tiers analyses for response (3.38, 95% CI, 2.24 to 5.10 compared with 2.62, 95% CI 1.93 to 3.56) or remission (5.07, 95% CI, 2.50 to 10.30 compared with 2.76, 95% CI, 1.79 to 4.26). Relative risk of remission in Tier 1 subgroup may be overestimated due to reporting bias; remission only reported in 7 of 18 trials. It would be clinically useful to consider whether rTMS effects vary based on type of previous treatments (eg, which antidepressant drugs), rather than just on how many. They could not evaluate this because the studies did not provide adequate detail on the specifc types of previous failed treatments.
KQ2. Differences in benefits/harms based on variation in rTMS protocol
Did not perform subgroup analyses because the number of studies was too limited. | High Frequency versus Low Frequency: “The optimal frequency of rTMS is unclear. There is a trend towards high frequency rTMS being more effective to achieve both clinical response and remission than low frequency.”
Did not perform subgroup analyses because the number of studies was too limited.
Did not perform subgroup analyses because the number of studies was too limited. | Meta-analysis results: Response: RR=1.19 (95% CI: 0.97, 1.46); remission: RR=1.29 (95% CI: 0.75, 2.22).
Did not perform subgroup analyses because the number of studies was too limited.
Did not perform subgroup analyses because the number of studies was too limited. | Comment: These results do not isolate the effect of frequency because this analysis merged data from varying protocols without adjusting for differences
Did not perform subgroup analyses because the number of studies was too limited.
Did not perform subgroup analyses because the number of studies was too limited. | Unilateral versus Bilateral: “The optimal location of treatment for rTMS is unclear. There is a trend towards bilateral rTMS being more effective to achieve both clinical response and remission than bilateral.”
Did not perform subgroup analyses because the number of studies was too limited.
Did not perform subgroup analyses because the number of studies was too limited. | Meta-analysis results: response: RR=1.15 (95% CI: 0.85, 1.56); remission: RR=1.18 (95% CI: 0.71, 1.96)
Did not perform subgroup analyses because the number of studies was too limited.
Did not perform subgroup analyses because the number of studies was too limited. | High Intensity versus Low Intensity: “The optimal intensity of rTMS is unclear. There is a trend towards high intensity rTMS being more effective to achieve both clinical response and remission than low intensity.”
Did not perform subgroup analyses because the number of studies was too limited.
Did not perform subgroup analyses because the number of studies was too limited. | Meta-analysis results: response: RR=1.15 (95% CI: 0.54, 2.41); remission: RR=1.72 (95% CI: 0.89, 3.33).
Did not perform subgroup analyses because the number of studies was too limited.
Did not perform subgroup analyses because the number of studies was too limited. | Various Other rTMS Protocols: “Active research is ongoing with the use of image-guided techniques, scheduling of treatment, timing of treatment, and deep brain stimulation. None of these research areas are developed enough to clarify the role of these variables in the effective use of rTMS.”
KQ2a. Defnition of adequate course of rTMS treatment
None | None
KQ3. Early predictors of rTMS benefit
None | None
KQ4. Continuation/maintenance treatment
Found that no sham-controlled RCTs assessed rTMS outcomes beyond a week following acute treatment. | None

### KEY QUESTION 1 For adults with TRD, how do the benefits and harms of treatment with rTMS differ in subpopulations based on age, gender, TRD symptom subtypes, comorbid mental health conditions, complicating medical conditions, concomitant medications, and definitions of treatment resistance?

#### Age

Whether the effectiveness of rTMS treatment differs in young (age 18-37 years) or older adults (age ≥ 65 years) is unclear; these populations have been underrepresented in controlled trials.14

##### LHF-DLPFC rTMS

Two small trials that recruited patients 40 years and older41,42 and subgroup analyses of sham-controlled trials43 and a single-site, single-arm study44 are frequently cited to support the assertion that older patients are less likely to respond to LHF-DLPFC rTMS when it is used at stimulation intensities of 80% to 120% RMT. Some experts have suggested that higher stimulation intensities of LHF-DLPFC rTMS are needed in older adults to overcome selective prefrontal atrophy.45 However, important methodological limitations prevent firm conclusions based on this evidence.

Two single-site sham-controlled RCTs that specifically recruited older adults (n=44)41,42 found that LHF-DLPFC rTMS at 80% to 100% RMT, and 4,000-16,000 total pulses did not significantly increase response over sham (Table 2). In contrast, in one single-site sham-controlled RCT in younger patients,46 LHF-DLPFC rTMS at 110% RMT for 60,000 total pulses significantly increased response compared with sham in younger adults, but not in older adults. However, since the dose of rTMS was higher in the RCT of younger adults, it is not possible to attribute the difference in response rates to age alone.

Table 2 Sham-controlled trials with varying age of participants

Author Year Sample size | Stimulation parameters Comparator | Mean patient age | Response | Remission | Adverse event withdrawals
Manes 2001^41^ N=20 | LHF-DLPFC, 80% RMT, 20 Hz, 4,000 total pulses vs sham | 60.5 vs 60.9 years | 30% vs 30% | 20% vs 20% | NR
Mosimann 2004^42^ N=24 | LHF-DLPFC, 100% RMT, 20 Hz, 16,000 total pulses vs sham | 60.0 vs 64.4 years | 27% vs 0%; P=0.089 | NR | NR
Zheng 2010^46^ N=34 | LHF-DLPFC, 110% RMT, 15 Hz, 60,000 total pulses vs sham | 26.9 vs 26.7 | 63% vs 7%; P<0.001 | NR | NR

A pooled analysis of 5 RCTs and one open-label study (N=195) cited in the APA Practice Guideline20 found a small negative association between age and response (OR=0.95; 95% CI: 0.92-0.99) and remission (OR=0.94; 95% CI: 0.90-0.98) after rTMS treatment.43 But this study has 2 main weaknesses. First, it is unclear how this subset of studies was selected for inclusion among the larger body of similar evidence. Second, 3 of the 6 studies included are unpublished, so data and methods of these studies cannot be verified.

A subgroup analysis of an uncontrolled single-site study of LHF-DLPFC rTMS at 110% RMT and 10Hz in 56 adults found a numerically lower response rate in 22 adults aged 65 years and above, compared those aged less than 65 years (23% compared with 56%); however, we cannot rule out that this difference is due to chance alone due to the small sample sizes or due to other confounding factors such as baseline depression severity and type.44

Finally, in an uncontrolled single-site study of 18 older adults (mean age 61.2 years),when rTMS was administered at higher intensities (range, 103% to 141% RMT, mean of 114%) that were individually tailored to account for MRI-measured prefrontal atrophy, response and remission rates were 28% and 22%, respectively.45 However, head-to-head trials are needed to compare the effects of using individually-tailored intensity levels compared to the more widely-used method of not adjusting for prefrontal atrophy.

##### RLF-DLPFC or bilateral rTMS in older adults

Although subgroup analyses from 3 recent RCTs consistently found that age was not significantly associated with RLF-DLPFC rTMS or bilateral rTMS response, this may have been due to the lack of variation in age of the study participants.47-49 Two multicenter head-to-head trials performed secondary analyses to identify predictors of response to treatment and concluded that age was not significantly associated with response to rTMS treatment.47,48 The earlier head-to-head trial (N=130) compared the benefits and harms of 10 sessions of 1-Hz and 2-Hz RLF-DLPFC48 while the later trial (N=219) compared 2 forms of bilateral stimulation to RLF-DLPFC.47 In both trials, mean age was under 50 years old, most patients were female, and besides alcohol or substance dependence, there were no restrictions on concurrent Axis I psychiatric disorders. Neither trial reported differences in response or remission among groups receiving different simulation parameters. Upon multivariate logistic regression analysis, age was not significantly associated with response to rTMS treatment (P>0.05). In one small trial (N=34), although the significant difference in HDRS percent change from baseline between older (>45 years) and younger (≤45 years) patients was emphasized, there was not a significant difference in the proportion of responders and remitters in each group (P>0.05).49

#### Sex

The proportion of female participants in meta-analyses of RLF-DLPFC,32 LHF-DLPFC,33and bilateral31 rTMS ranged from 54.4% to 66.4%. Sex was not significantly associated with response in two multicenter head-to-head trials of bilateral versus RLF-DLPFC rTMS treatment (N= 219 and N=130, respectively).47,48 But we did not identify any analyses of response or remission rates by sex among studies of LHF-DLPFC rTMS.

#### Bipolar Depression

Findings from earlier meta-analyses that focused on either RLF-DLPFC rTMS32 or LHF-DLPFC33 were consistent with RTI-UNC EPC (see Table 1). There was no significant difference in response or remission rates between RCTs including subjects with unipolar depression only and those including mixed samples of subjects with unipolar and bipolar depression.

#### Treatment-resistance defnition

The RTI-UNC EPC CER is the best source of evidence about the differential effects of rTMS based on variation in TRD definitions and its findings are summarized in Table 1 above.

#### Comorbid mental health and medical conditions

Most studies of rTMS excluded patients with comorbid mental health conditions, such as substance abuse and post-traumatic stress disorder, as well as medical comorbidities. This prevented us from adequately evaluating how rTMS may differ in various patient subpopulations with comorbidities. However, consistent findings from 3 trials provide some preliminary evidence that rTMS can produce a clinically significant response in patients with comorbid posttraumatic stress disorder (PTSD).47,48,50 One trial from the Partial Hospitalization Program and Post Traumatic Stress Disorder Clinic of the Mental Health Service Line at the Department of Veterans Affairs Medical Center in Washington, DC included 12 patients with TRD and combat PTSD who remained depressed after a minimum of one month on antidepressant therapy (100% male; mean age of 55 years).50 After 2 weeks of fast (5 Hz) and slow (1 Hz) frequency left-sided rTMS, response rates were 67% and 83%, respectively. Additionally, subgroup analyses based on 139 patients with concurrent Axis I psychiatric disorders from 2 trials found that response to rTMS did not differ based on the presence of various comorbid anxiety disorders, including PTSD.47,48

We are aware of a multi-site, sham-controlled VA Cooperative Study of rTMS that is currently enrolling Veterans with TRD and possible comorbid disorders and/or a history of substance abuse (NCT01191333, CSP #556). This study will provide findings that are directly applicable to the Veteran population and has the potential to provide more general insights about how comorbidities may affect rTMS treatment. This VA study plans to enroll 360 Veterans across 9 VA Medical Centers and the estimated completion date is November 2017.

#### Overall illness morbidity

Compared to the findings of controlled trials of patients with typically narrow ranges of symptomatology and comorbidity, response and remission rates (58% and 37%, respectively) were similar in one multisite, naturalistic, uncontrolled observational study of 307 outpatients that were selected using less stringent eligibility criteria.52 In particular, patients in the observational study had a higher incidence of prior inpatient psychiatric hospitalizations (44%) and a greater number of failed antidepressant trials (2.5) than patients in controlled trials. However, only 15% of patients had comorbid anxiety disorders and rates of other comorbidities were not reported. Also, because there was no sham control group in this study, the observed improvements may have been a result of being part of the study, including the remuneration patients received for completing the study procedures.

#### Concomitant medications

Evidence from the Berlim 2014 meta-analysis of sham-controlled LHF-DLPFC rTMS RCTs suggest that patients who are treated with rTMS as monotherapy or as augmentation to pharmacotherapy have similar response (29% vs 10%; 19% vs 5%) and remission (34% vs 13%; 24% vs 6%) rates compared to sham (response: Q=0, df=1, P=0.95, remission: Q=0.01, df=1, P=0.91).33

It is unknown whether the benefits of RLF-DLPFC rTMS differ in subpopulations based on use of concomitant medications. Results of the Berlim 2013 meta-analysis of sham-controlled trials suggest a greater chance of response (Q=5.99; df=1; P=0.014) when used as monotherapy (OR=27.94; 95% CI: 4.3-181.53) versus an augmentation strategy (OR=2.32; 95% CI: 1.17-4.6).32 But the problem with the RLF-DLPFC monotherapy therapy evidence is that it has unclear applicability to patients with stringently defined TRD because patients either were not treatment resistant53 or were only required to have failed at least one antidepressant in either the current or previous episode.54

### KEY QUESTION 2 For adults with TRD, how do the benefits and harms of treatment with rTMS differ based on variation in rTMS treatment protocol (eg, coil geometry, coil placement, stimulus parameters, duration of a treatment session, timing and number of sessions, etc)?

#### Overview

Head-to-head trials provide the most direct evidence of how benefits and harms of treatment with rTMS differ based on variation in rTMS treatment protocols. When the University of Calgary combined data from head-to-head trials, they found no statistically significant differences based on frequency, intensity, or on use of bilateral protocols (Table 1); however, their meta-analyses did not adjust for the potentially confounding effects of variation in other parameters (eg, left vs right). To try to better isolate the effects of individual stimulation parameters, we sought to create more homogenous subgroupings of head-to-head trials based on whether they compared (1) different LHF-DLPFC protocols; (2) RLF-DLPFC versus LHF-DLPFC; (3) bilateral versus unilateral protocols; or (4) involved other rTMS protocol variations such as the use of priming, stimulating other regions of the brain, image guidance, etcetera.

However, the wide variation in rTMS protocols we encountered in the literature, and probably reflected in clinical practice, makes it almost impossible to determine how to achieve the best result. High-frequency rTMS applied to the left dorsolateral prefrontal cortex is the most well-studied approach and it includes a FDA-cleared protocol that has been shown to improve quality of life. Head-to-head trials have not found any particular protocol to have any advantages over others. In terms of dose for LHF-DLPFC, 2 large multicenter RCTs support using 120% RMT to guarantee adequate stimulation intensity. Intensities down to 100% may also be effective in certain patients. LFR-DLPFC has primarily been used as augmentation at 1 Hz and intensity ranging from 90% to 110% and has shown higher levels of response with more than 1200 total pulses per session. We found no reviews that have evaluated the effects of variability in coil geometry, coil placement, session duration, timing or number of sessions. Most studies have used the figure-eight coil and the 5-cm technique for coil placement. rTMS has most commonly been delivered daily during the week, for 2 to 4 weeks, with each session ranging in duration from 10 to 40 minutes. In order to collect meaningful data from clinical experience, the VA should increase standardization of rTMS delivery.

#### Standard LHF-DLPFC rTMS

##### General efficacy of LHF-DLPFC rTMS

The rTMS protocol that is FDA-cleared is the only one that has been studied in 2 published multisite studies.17,18 It is comprised of administration to the left dorsolateral prefrontal cortex (DLPFC) at a speed of 10 pulses per second, an intensity of 120% motor threshold, with 3,000 pulses delivered per session, and one session conducted per day in 5-day sequences for 3-6 weeks. The first of these multisite trials was Neuronetics' pivotal trial which led to the 2008 FDA clearance.17 This trial randomized 325 medication-free outpatients with major depression who had previously failed one to 4 adequate antidepressant trials, were medically healthy, and who were without additional psychiatric comorbidity (eg, PTSD).17 When response was defined as at least a 50% improvement in HAMD24 total score, rates were statistically significantly greater for rTMS at both 4 weeks (19.4% vs 11.6%; P<0.05) and 6 weeks (23.9% vs 15.1%; P<0.05). The advantage of rTMS over sham in remission rates (HAMD24 Total Score < 11) did not reach statistical significance until week 6 (17.4% vs 8.2%; P<0.05). rTMS was also found to modestly improve quality of life, based on significant improvements in the Q-LES-Q total score (+4.8 points vs 2.8 points; P=0.035) and in the SF-36 mental component score (+6.3 points vs +3.6 points; P=0.043).55 Discontinuation due to adverse events was similar (4.5% vs 3.4%; P not reported) and there were no deaths or seizures.

The second multisite trial was sponsored by the NIH and had similar results to the Neuronetics' pivotal trial, thus strengthening the therapeutic profile of this particular rTMS protocol.18 The NIH multisite trial involved a similar rTMS protocol and a similar patient population, but included a few notable methodological advances, including an effort to improve the blinding by better simulating the rTMS somatosensory experience in the sham condition and a formal assessment of patients, raters, and treaters to assess the adequacy of the blind. The rate of correctly guessing treatment assignment was 60% for patients, 65% for treaters, and 48% for raters. Patients were generally moderately to extremely confident in their guesses, whereas treaters and raters were generally not at all to moderately confidence in their guesses. At 3 weeks, there was a significant effect of rTMS on the proportion of remitters (primary outcome, HAMD ≤ 3 or 2 consecutive HAMD scores < 10; 14% vs 5%; OR 4.2, 95% CI, 1.32-13.24; P=0.02) and responders (≥ 50% decrease in HAMD; 15% vs 5%; P=0.009). Rates of withdrawal due to adverse events were 5.4% for rTMS and 0 for sham (P not reported). No seizures or suicides were reported.

##### Head-to-head trials of diffierent LHF-DLPFC protocols

Eight eligible head-to-head trials compared different variations in LHF-DLPFC protocols. All are small (N≤54), single-site studies. Three compared different intensities (Table 1 and 3),56-58 5 compared different speeds (Table 4),48,50,54,59,60 and one compared daily treatments to less than daily treatments (N=12).61 None compared the protocol used in the multisite trials described above to any other protocol and all used lower doses than the FDA-cleared protocol. These trials didn't demonstrate any obvious dose-response relationship, but comparison among these studies is difficult due to clinical diversity (eg, patient characteristics, whether rTMS was used as an augmentation strategy or as monotherapy, rTMS stimulation parameters) and methodological diversity (eg, how treatment resistance was defined). Our finding of no frequency or intensity-related differences in head-to-head trials of different LHF-DLPFC protocols is consistent with those of University of Calgary, even though their meta-analyses combined a broader set of head-to-head trials. A meta-regression based on 29 sham-controlled trials of 1,371 patients also found no significant association between variation in rTMS speed, intensity, total number of sessions, or total number of pulses and response or remission.33,25

Table 3 Trials comparing different LHF-DLPFC intensities

Author, Year Sample size | Intensity comparisons | Speed | Total pulses | Response | Remission | Adverse event withdrawals
Bakim 2012^56^ N=35 | 110% vs 80% vs sham | 20 HZ | 24,000 | 73% vs 83% vs 17% | 55% vs 25% vs 9% | NR
Rossini 2005^58^ N=54 | 100% vs 80% vs sham | 15 Hz | 6,000 | 61% vs 28% vs 6.2% | NR | None
Padberg 2002^57^ N=31 | 100% vs 90% vs sham | 10 Hz | 15,000 | 30% vs 20% vs 0 | 20% vs 10% vs 0 | NR

Table 4 Trials comparing different LHF-DLPFC frequencies (Hz)

Author Year Sample Size | CC AD meds? | Hz comparison | Intensity (% RMT) | Total pulses | Response | Remission | Adverse event withdrawals
George 2000^59^ N=32 | N | 20 vs 5 vs sham | 100% | 16,000 | 30% vs 60% vs 0 | NR | 0% vs 20% vs 0%
Su 2005^60^ N=30 | Y | 20 vs 5 vs sham | 100% | 16,000 | 60% vs 60% vs 10% | 50% vs 50% vs 0 | NR
Fitzgerald^a^ 2006^48^ N=30 | Y | 10 vs 5 | 100% | 15,000 | 28% vs 6%; P=0.16 | NR | NR
Stern 2007^54^ N=45 | N | 10 vs 1 vs sham | 110% | 16,000 | 60% vs 0 vs 0 | 40% vs 0 vs 0 | 0% vs 50% vs 30%
Rosenberg 2002^50^ N=12 | Y | 5 vs 1 | 90% | 6,000 | 83% vs 67% | NR | 1, group NR

a Non-responders to 1- or 2-Hz rTMS over the R-DLPFC

In general, the findings of the head-to-head trials are most applicable to women in their mid-forties to early sixties, who are medically healthy, and do not have any Axis I comorbidities. A fair-quality head-to-head trial of 12 Veterans found statistically comparable response rates for 1 Hz and 5 Hz rTMS after 2 weeks (67% vs 83%).50 When the Veterans were followed for an additional 2 months after treatment discontinuation to monitor the durability of the rTMS effects, a slight relapse of symptoms was noted, with the response rate dropping to 50% in both groups. The sample came from the Partial Hospitalization Program and Post Traumatic Stress Disorder Clinic of the Mental Health Service Line at the Department of Veterans Affairs Medical Center in Washington, DC, who had treatment-refractory depression and combat PTSD, and who remained depressed after a minimum of one month on antidepressant therapy (100% male; mean age of 55 years). Table 4 describes the characteristics of the rTMS protocol used in this trial and its results at the end of rTMS treatment. The magnitude of response in both treatment groups was considerably greater than that seen in other studies. This may have been due to the trial's open design in which neither patients nor raters were blinded to treatment.

Only one trial evaluated re-treatment with left-sided high-frequency PFC rTMS of patients who failed to response to a previous course of right-sided low-frequency PFC rTMS.48 This trial reported a response rate almost 5 times greater with 10-Hz compared with 5-Hz left-sided PFC rTMS, but the difference was not statistically significant, likely due to the small sample size. Limitations of this study are that the between-group comparability of important baseline characteristics is unknown and no information was collected on the integrity of the blind.

#### Deep LHF-DLPFC rTMS

We did not identify any study that has directly compared deep LHF-DLPFC TMS to any standard rTMS protocol. However, in January 2013 the FDA determined deep rTMS, administered at an intensity of 120% of motor threshold and a frequency of 18 Hz for 1,980 pulses per session on a schedule of five daily sessions for 4 weeks, to be substantially equivalent to the FDA-cleared standard rTMS protocol described above.15 The FDA determination of substantial equivalence appears to be based on indirect evidence from an unpublished, multisite, international sham-controlled trial of 229 patients with TRD (NCT00927173).15 Results of per-protocol analyses, which excludes 31 subjects who “did not receive the adequate DTMS treatment regimen,” found significantly greater rates of response (38.4% compared with 21.4%; P=0.0138) and remission (32.6% compared with 14.6%; P=0.0051) in the deep TMS group compared with sham, but the differences were not statistically significant in the ITT analysis set. Information about the balance of benefits and harms is not available, however, as rates of withdrawals due to adverse events were not reported. Also, the quality of this trial is unknown, as essential information about the randomization and allocation concealment methods and the balance of important patient characteristics at baseline is not available. We contacted the principal investigators to request additional information, but had not received any response at the time of this report. A 2013 review of deep rTMS identified an additional 7 uncontrolled trials, but no other sham-controlled trials.62

#### Right low-frequency dorsolateral prefrontal cortex (RLF-DLPFC) protocols

The most widely studied alternative rTMS strategy to the LHF-DLPFC approach is low frequency stimulation over the right DLPFC (RLF-DLPFC). The proposed advantages to the low frequency stimulation are lower risk of seizure induction and a lesser degree of scalp discomfort. It has been hypothesized that RLF-DLPFC could be a potential alternative in people with risk factors for seizure. Our finding of no frequency or intensity-related differences in head-to-head trials that compared RLF-DLPFC to LHF-DLPFC protocols or compared different RLF-DLPFC protocols is consistent with those of University of Calgary, even though their meta-analyses combined a broader set of head-to-head trials.

##### General efficacy of RLF-DLPFC rTMS approaches

Many small, single-site clinical trials have investigated the benefits and harms of RLF-DLPFC, but it has not yet been studied in a large, multicenter trial, such as has been done for LHF-DLPFC. A 2013 systematic review by Berlim and colleagues synthesized data from 8 randomized trials totaling 263 patients.32 rTMS frequency was 1 Hz in all the studies. Intensity did not vary much and was 110% of resting motor threshold in 6 trials and 100 and 90% in each of the remaining 2 trials. Total pulses ranged quite a bit, though, from 1,200 to 24,000. rTMS was used as augmentation in the majority of trials. Results of their meta-analysis found that RLF-DLPFC produced higher response (38.2% vs 15.1%; OR 3.35 (95% CI, 1.34-8.02); NNT=5; I^2^=34.18) and remission rates (34.6% vs 9.7%; OR 4.76; 95% CI, 2.13-10.64; NNT=5; I^2^=0) than sham, with no worsening of overall withdrawals (5.3% vs 11.28; P=0.22). Sensitivity analyses found that protocols that delivered greater than 1200 total pulses were associated with higher response rates (OR 6.9; 95% CI, 2.39 to 19.92). The greatest weakness of this systematic review is that the authors did not formally assess the quality of the included studies. The authors expressed an intent to increase their reliability by restricting their inclusion criteria to only studies that used random allocation and were double-blind, but they did not assess how well those methodologies were carried out.

##### Head-to-head comparisons of RLF-DLPFC to LHF-DLPFC

Eight small, single-site clinical trials (N=338) have directly compared RLF-DLPFC to LHF-DLPFC approaches (Table 5).63-70 The response, remission, and adverse event withdrawal profiles of the RLF-DLPFC approaches were all comparable to the LHF-DLPFC approaches, but the LHF-DLPFC approaches used in these trials were all of lower dose than those FDA-cleared or studied in multicenter trials.

Table 5 Head-to-head comparisons of RLF-DLPFC to LHF-DLPFC

Author Year Sample Size | RLF: Hz, % RMT, pulses per session | LHF: Hz, % RMT, pulses per session | Total # sessions (given 5 days/wk) | Response (≤ 50% reduction in MADRS or HAMD, unless otherwise specifed) | Remission | Adverse event withdrawals
Fitzgerald 2003^64^ N=60 | 1, 100%, 300 | 10, 100%; 1,000 | Phase 1=10, 5 d/wk, Phase 2: responders continued another 10 sessions | ≤ 20% decrease in MADRS: 35% vs 40% | NR | None
Fitzgerald 2009^63^ N=27 | Hz NR; 110%; pulses per session unclear | Hz NR; 100%; pulses per session unclear | 20 | 44% vs 45% | 19% vs 36% | NR
Fitzgerald 2007^65^ N=26 | 1, 110%, 720 | 10; 110; 1,500 | 15 | ≤ 30% decrease in MADRS: 54% vs 60% | NR | NR
Isenberg 2005^69^ N=28 | 1, 110%, 120 | 20, 80%, 2,000 | ≤ 20 | 29% vs 36% | 14% vs 21% | NR
Rossini 2010^66^ N=74 | 1, 100%, 600 | 15, 100%, 600 | 10 | 57% vs 66% | NR | None
Richieri 2012^70^ N=61 | 1, 120%, 360 | 10, 120%, 2,000 | 20 | ≤ 50% reduction in BDI: 54.5% vs 28.6% | NR | None
Triggs 2010^67^ N=48 | 5, 100%, 2,000 | 5, 100%, 2,000 | 10 | 31% vs 22% | NR | None
Eche 2012^68^ N=14 | 1, 100%, 120 | 10, 100%, 2,000 | 10-20 | MADRS < 15: 2 weeks: 25% vs 50% 4 weeks: 50% vs 67% | NR | None

##### Head-to-head comparisons of diffierent RLF-DLPFC protocols

Clinical trials that have evaluated RLF-DLPFC protocols have predominantly used 1.0 Hz stimulation speed. We only identified one eligible clinical trial that compared alternative RLF-DLPFC protocols.48 This multisite, double-blind randomized trial compared the benefits and harms of 10 sessions of 1-Hz and 2-Hz RLF-DLPFC in 130 inpatients. Stimulation intensity was 110% RMT. Total number of pulses was 900 in the 1 Hz group and 1,800 in the 2 Hz group. Mean age was 49 years and most patients were female. Current alcohol or substance dependence was excluded, but there were no other restrictions on concurrent Axis I psychiatric disorders, and 14% had anxiety disorders. Mean number of failed antidepressant trials was 5.5. This trial found that a double dose of RLF-DLPFC (2-Hz) offered no advantages over 1-Hz RLF-DLPFC in terms of proportion of patients who met response (27% vs 32%) or remission (7% vs 16%) criteria or withdrawals due to adverse events. The main limitations of this trial are that it may have been underpowered and it did not collect information on the integrity of the blind.

#### Bilateral dorsolateral prefrontal cortex (DLPFC) protocols

The second most widely studied alternative rTMS strategy is bilateral stimulation to the right and left-side DLPFC. The proposed advantage to bilateral stimulation is that it could maximize the likelihood of improvement in any individual patient who may have left-side or right-side resistance.31

##### General efficacy of bilateral DLPFC protocols

No bilateral DLPFC protocol has yet been studied in a large, multicenter trial. A 2013 systematic review by Berlim and colleagues synthesized data from 7 randomized, sham-controlled trials totaling 279 patients.31 Right DLPFC protocol parameters included primarily 1 Hz frequency, percent of resting motor thresholds of 90 to 120, total pulses ranging from 4,200 to 27,000, and number of sessions ranging from 10 to 15. Ranges of left DLPFC protocol parameters included 10 to 20 Hz for frequencies, 90 to 120 for percent of resting motor thresholds, 7,500 to 27,000 for total pulses, and 10 to 15 for total sessions. rTMS was used as an antidepressant medication augmentation strategy in 6 of 7 trials. Six of 7 trials administered the left- and right-sided stimulations sequentially. Results of their meta-analysis found that RLF-DLPFC produced higher response (24.7% vs 6.8%; OR 4.3, 95% CI, 1.95-9.52; NNT=6; I^2^=0) and remission rates (19% vs 2.6%; OR 6, 95% CI, 1.65-21.8; NNT=7; I^2^=0) than sham, with no worsening of overall withdrawals (7.15% vs 13.4%; P=0.19). The greatest weakness of this systematic review is that the authors did not formally assess the quality of the included studies. The authors expressed an intent to increase their reliability by restricting their inclusion criteria to only studies that used random allocation and were double-blind, but they did not assess how well those methodologies were carried out.

##### Head-to-head comparisons of bilateral to unilateral protocols

The University of Calgary systematic review pooled data from 5 studies comparing bilateral and unilateral LHF-DLPFC stimulation and reported no significant difference in response, remission, or side effects (Table 1).

Clinical trials that have compared bilateral rTMS approaches to unilateral LHF-DLPFC approaches have predominantly given left-sided stimulation first, followed by stimulation on the right side. So far, only one single center trial of 62 patients has investigated whether the order of bilateral sequential rTMS stimulation makes a difference, but found similar rates of response (28% compared with 12%) and remission (12% compared with 0%), regardless of whether fast left stimulation or slow right was given first.71

##### Other comparisons with bilateral DLPFC protocols

A few other trials of bilateral DLPFC protocols combining high and low frequencies have found no differences based on variation in treatment schedule or when compared to either unilateral left-sided DLPFC stimulation at alternating low and high frequencies or bilateral stimulation at low frequency on both sides.

Clinical trials of bilateral rTMS have predominantly used a daily treatment schedule. However, results from one single-site trial of 77 patients has shown that giving treatment 3 days a week for 6 weeks has the potential of achieving similar rates of response (43% compared with 43%) and remission (33% compared with 31%) compared with giving treatments daily for 4 weeks.72

Response rates were not statistically significantly different between groups that received a bilateral DLPFC protocol that combined high and low frequency stimulation (50%) or a unilateral left-sided DLPFC protocol that also combined (10 Hz) high and low (1 Hz) frequency stimulation (67%) in a trial of 36 inpatients at a single site in Austria.73

We also identified one multisite randomized controlled trial that compared 2 forms of bilateral stimulation to RLF-DLPFC in 219 inpatients.47 Mean age was 47 years and most patients were female. Mean number of failed antidepressant trials was 5.5. Current alcohol or substance dependence was excluded, but there were no other restrictions on concurrent Axis I psychiatric disorders and 40% had anxiety disorders. Stimulation intensity was 110% of resting motor threshold and total number of pulses was 900 in all groups. Stimulation speed was 1 Hz in the unilateral right group, 1 Hz on the right side followed by 10 Hz on the left side in the sequential bilateral group, and 1 Hz on the right side followed by 1 Hz on the left side in the low-frequency sequential bilateral group. There were no significant differences between the right unilateral, sequential bilateral, or low-frequency sequential bilateral groups in response (56% , 49%, and 55%; P=0.61) or remission (35%, 29%, 31%; P=0.71), or withdrawals due to adverse events (1%, 1%, 3%, P not reported).

#### Other rTMS protocol variations

Future trends in rTMS research include protocol variations such as: (1) enhancement of RLF-DLPFC protocols by “priming” them with a preceding period of higher frequency stimulation provided at low intensity74,75; (2) exploring stimulation in different regions of the brain76; (3) improving the stimulus location by using structural MRI-guided77,78 or PET-guided79 navigation; and (4) individualizing stimulus timing parameters based on background EEG activity.80 As most of these alternatives would require even more resources, however, more research in larger samples is still needed to confirm their value.

### KEY QUESTION 2A What defines an adequate course of treatment?

In contrast with the drug development process, dose response assessment has not been an integral component of establishing the effectiveness and safety of rTMS treatment. We are aware that surrogate markers of brain activity have been examined to infer the minimum dose needed to interact with brain circuits,81-83 but this evidence was outside of the scope of this evidence brief. We discuss the use of biomarkers in Key Question 3. We did not find any prospective dose-ranging study that used a factorial design to directly and simultaneously compare the effects of multiple stimulation parameters in isolation from one another (eg, intensity, quantity of pulses, duration). In the absence of definitive direct data on minimally effective rTMS dose, we looked across sham-controlled trials to indirectly examine the effects of variable dose intensities. However, a limitation of relying on sham-controlled trials for evidence on dose response is that the generalizability of their findings is limited to narrower ranges of dose and patient characteristics than are encountered in typical VA clinical practice settings.

The best evidence from 2 large multicenter RCTs supports using 120% RMT to guarantee an adequate stimulation intensity.17,18 Using data from the 2014 systematic review by Berlim and colleagues of 29 sham-controlled trials of high-frequency left-sided PFC rTMS at lower intensities, 80% to 110%,33 we found that intensities down to 100% may also be effective in patients primarily under 50 years of age without Axis I comorbidities and past substance abuse.33 When we grouped trials by % RMT for 80%, 90%, 100%, and 110% (Table 6), we found that the relative risks for response gradually increased with increasing % RMT. The 100% RMT was the lowest level at which the higher response rate for rTMS versus sham reached statistical significance. However, within any 100% RMT regimen, there are still the questions of how many sessions and how many total pulses are minimally effective. Among the 8 trials of 100% RMT, the number of sessions ranged from 10 to 15 and the total number of pulses ranged widely, from 6,000 to 22,500. Likely because most regimens were represented by only a single trial with a small sample size, when examining the plot of relative risks (Figure 2), we found no clear dose response pattern based on escalating numbers of sessions and total number of pulses. However, when we pooled the 3 trials that used the same stimulation regimen of 100% RMT in 10 sessions of 16,000 total pulses, we found a statistically significant increased response for rTMS, and this did not appear to be at the expense of increased withdrawals.42,59,60

Table 6 Pooled analyses of response rates from sham-controlled trials from Berlim 2014 grouped based on % RMT for examining dose

% RMT | # sessions | Total # pulses | # RCTs/ Total N | Response rates, Relative Risk (95% CI), I^2^ | Overall withdrawals, Relative Risk (95% CI), I^2^
80% | 10 | 8,000 | 4/105 | 11% vs 6%; RR 1.39 (95% CI, 0.44 to 4.40), I^2^=0% | 2% vs 13%; 0.29 (0.06 to 1.38); I^2^=0%
90% | 10 | 8,000-16,000 | 3/87 | 44% vs 21%; RR 1.88 (95% CI, 0.74 to 4.79); I^2^=43.4% | 11% vs 5%; 2.08 (0.75 to 5.75), I^2^=0%
100% | 10-15 | 6,000-22,500 | 8/266 | 31% vs 10%; RR 2.24 (95% CI, 1.07 to 4.70); I2=18.5% | 13% vs 10%; 1.41 (0.70 to 2.87), I^2^=0%
100% | 10 | 16,000 | 3/84 | 40% vs 3%; RR 5.40 (95% CI, 1.34 to 21.76) | 7% vs 5%; 1.10 (0.22 to 5.40); I2=0%
110% | 10-20 | 10,000-60,000 | 9/313 | 41% vs 12%; RR 2.78 (95% CI, 1.67, 4.63); I2=13% | 6% vs 9%; 0.71 (0.30 to 1.66); I^2^=0%
110% | 10 | 16,000 | 3/63 | 39% vs 14%; RR 2.39 (95% CI, 0.50 to 11.39), I2=48.8% | 5% vs 12%; 0.50 (0.07 to 3.71)
110% | 20 | 30,000 | 2/66 | 42% vs 21%; RR 2.00 (95% CI, 0.95 to 4.23) | 6% vs 6%; 1.00 (0.15 to 6.69)

Figure 2 Relative risk (random effects) of response for rTMS 100% RMT versus sham (95% confidence interval) in order of escalating number of sessions and total number of pulses

Although the systematic review by Berlim and colleagues did not report withdrawals due to adverse events, we pooled their data for overall withdrawals, which includes withdrawals due to adverse events. Overall withdrawal rates did not consistently escalate as a function of increasing rTMS intensity. We did not attempt to evaluate dose response for low-frequency right-sided PFC rTMS due to the smaller number of trials available.32

### KEY QUESTION 3 For adults with TRD, what is the evidence about early predictors of rTMS treatment benefit?

Early prediction of treatment benefit can be based on clinical or physiological factors that are established before treatment, such as age and gender, and those that may change early in response to treatment, such as neurochemical or hormonal biomarkers. Key Question 1 focused on a number of pre-specified subpopulations based on factors established before treatment. Here we focus on factors that may change early in response to treatment. The minimally acceptable study would prospectively test the ability of a tool, designed a priori, to predict treatment benefit based on multiple factors. We did not identify any such studies. Factors that have been preliminarily examined as predictors of rTMS outcomes in primarily retrospective, uncontrolled studies include neuroimaging (fMRI, SPECT, PET, MRS, and NIRS), electrophysiological (EEG, TMS-indexed cortical excitability, and saccadic eye movements), and neuroimmunoendocrine (cortisol, THS, BDNF, ILs, and sexual hormones) biological markers.81 Some of these factors have been shown to be associated with clinical outcomes, but due to small, heterogeneous samples and uncontrolled confounders, drawing definitive conclusions about their use is impossible at this time.81

### KEY QUESTION 4 What is known about the need for and effectiveness of continuation or maintenance treatment to prevent relapses or recurrences in patients who have responded to rTMS?

No sham-controlled RCTs assessed rTMS outcomes beyond a week following acute treatment.14 In an older review84 cited in the APA guideline for MDD treatment,20 a pooled analysis of 14 studies that tested patients 2 weeks after acute rTMS treatment showed that the effect of rTMS treatment on remission had disappeared. We included 13 nonrandomized studies of relapse or recurrence.85-97

#### Persistence of benefit following end of acute treatment

For patients with TRD, response to ECT or various antidepressant medications is often transient.98 Six studies examined the persistence of benefit in patients who had achieved remission or response during RCTs of acute rTMS treatment (Table 7).85,87,89,93,95,97 These studies lasted from 3 months to 1 year and reported widely varying rates of relapse. The largest study included 76 remitters in a naturalistic setting followed for one year, 30% of which relapsed mostly during the first 6 months.97 Among the 44 responders, 42% did not sustain their response during follow-up. In another year-long study, recurrence was experienced by 1 of 4 remitters, 1 of 2 responders, and 2 of 3 who had a partial response at the end of acute rTMS treatment.89 Three studies followed patients for 6 months after the end of acute rTMS treatment and found relapse rates of 10% among patients who at least partially responded,93 20% among 21 patients who achieved response (identical to the relapse rate in the ECT group),87 and 77% among 204 patients who achieved remission during acute rTMS treatment.85 In the 6-month study of remitters, upon multivariate analysis younger age (P=0.003) and additional rTMS treatment sessions (P=0.027) were statistically significantly associated with increased duration of remission.85 Finally, a follow-up of a RCT and an open-label trial reported that after 3 months, 5 out of 37 (14%) patients had relapsed and the mean time to relapse was 7.2 weeks.95 This study was a follow-up of the multisite NIH trial reviewed in Key Question 2.^18^

Table 7 Extension studies of persistence of benefit following end of acute rTMS treatment

Author Year Sample size Duration | Population | Continuation, maintenance therapy | Outcomes
Dell'Osso 2011^89^ N=11 1 year | Responders (BD) | Pharmacotherapy | Recurrence: 17% responders, 0% remitters, 67% partial responders
Cohen 2009^85^ N=204 6 months | Remitters (MDD) | Pharmacotherapy | Relapse: 77%
Dannon 2002^87^ N=21 6 months | ECT or rTMS responders (MDD) | Pharmacotherapy | Relapse: rTMS: 19%; ECT: 20%
Janicak 2010^93^ N=99 6 months | At least partial responders (MDD) | Pharmacotherapy | Relapse: 10% after a mean of 164 days
Mantovani 2012^95^ N=37 3 months | Remitters (MDD) | Pharmacotherapy | Relapse: 14% after mean of 7.2 weeks
Dunner 2014 N=76^97^ 12 months | Remitters (MDD) | Varied | Relapse: 30% mostly during first 6 months
Dunner 2014 N=44^97^ 12 months | Responders (MDD) | Varied | Did not sustain response: 42%

#### Long-term rTMS maintenance therapy strategies for relapse prevention

We identified 4 uncontrolled studies of 4 different rTMS maintenance therapy strategies for preventing relapse among responders to acute rTMS treatment (Table 8).86,92,94,96 None of the strategies has been directly compared in any head-to-head trials and while relapse rates in these studies ranged widely, it is difficult to attribute this variation to different maintenance strategies given the heterogeneity in follow-up time, type of acute rTMS treatment, and patient populations. In 2 studies of weekly rTMS maintenance, relapse rates ranged from 50%^96^ to 57%^94^ after a mean of 24 weeks. A retrospective cohort examining tapered rTMS maintenance reported 62% of patients maintained response at 6 months.86 Finally, a recent RCT follow-up examining clustered rTMS maintenance reported that 71% relapsed after an average of 10.2 months.92

Table 8 Extension studies of rTMS continuation or maintenance therapy

Author Year Sample size Duration | Population | Continuation, maintenance therapy | Outcomes
Connolly 2012^86^ N=42 6 months | Responders (MDD and BD) | Tapered rTMS: 1 per week for 4 weeks, 2 per month for 2 months, and 1 per month for 3 months | Response duration: 62%
Fitzgerald 2013^92^ N=35 50 months | Responders (MDD and BD) | Clustered rTMS: 5 sessions over 2.5 days every 4 weeks | Relapse: 71% Withdrew: 11% Remained in treatment: 17%
Li 2004^94^ N=7 1 year | Responders (BD) | Weekly rTMS | Completed f-u: 43% Multiple relapse: 57% after mean of 24 weeks
O'Reardon 2005^96^ N=10 | Responders (MDD) | Weekly rTMS | Relapse or recurrence: 50%

#### rTMS retreatment following relapse

Four uncontrolled studies examined retreatment with rTMS following relapse in patients who responded to an initial acute course of rTMS (Table 9).90,91,93,97 Rates of re-achievement of response ranged from 50 to 100%, but as with the studies of long-term rTMS maintenance strategies, we cannot attribute the apparent variation in rates of re-achievement of response to retreatment parameters, due to the heterogeneity in study design and patient populations. In one multisite naturalistic study, among those who received rTMS introduction, 20%, 21%, 44%, and 66% of non-responders, partial responders, responders, and remitters did not experience a later relapse.97 A follow-up of a RCT reported that patients received an average of 4 rescue treatments, with a mean treatment interval of 4.9 months, and after 4 years, 50% of patients sustained their response.90 Another RCT follow-up reported that of the patients that received one rescue treatment, 63% responded; of the patients that received a second treatment, 57% responded; and 100% of patients that received a third or fourth rescue treatment responded.91 A final RCT follow-up reported that of the patients that were reintroduced to rTMS after symptom worsening, 84% benefited from treatment, 40% experienced a second instance of symptom worsening, and 13% experienced a third instance of symptom worsening.93 This study was a follow-up of Neuronetics' pivotal trial which led to the 2008 FDA clearance.17

Table 9 Extension studies of rTMS rescue treatment

Author Year Sample size Duration | Population Response, remission definition | Rescue treatment | Outcomes
Demirtas-Tatlidede 2008^90^ N=14 4 years | Responders (MDD) | Mean treatments: 4 Mean interval: 4.9 months | Sustained response: 50%
Fitzgerald 2006^91^ N=19 3 years | At least partial responders (MDD and BD) | Mean interval: 1^st^ re-treatment: ∼11 months 2^nd^: ∼12 months 3^rd^: ∼9 months 4^th^: 6 months | Response: 1^st^ re-treatment: 63% 2^nd^ re-treatment: 57% 3^rd^ re-treatment: 100% 4^th^ re-treatment:100%
Janicak 2010^93^ N=38 6 months | At least partial responders (MDD) | 2 sessions/week for 2 weeks followed by 5 sessions/week for up to 4 more weeks | 84% benefited and continued
Dunner 2014^97^ N= 15 (non-responders), 19 (partial responders), 27 (responders), 32 (remitters) 12 months | Non-responders Partial responders Responders Remitters | Varied | Did not experience relapse: Non-responders: 20% Partial responders: 21% Responders: 44% Remitters: 66%

### SUMMARY OF MAIN FINDINGS

- Which patients have best chances of success with rTMS? Whether the effectiveness of rTMS treatment differs by sex or in young (age 18-37 years) or older adults (age ≥ 65 years) is unclear. But evidence suggests that patients with unipolar or bipolar depression, with more or less stringently defined TRD, and who are treated with rTMS as monotherapy or as augmentation to pharmacotherapy have similar chances of success with LHF-DLPFC rTMS. However, the strength of this evidence is low due to small sample sizes, resulting in limitations in precision and methodological quality of the studies (eg, single center, inconsistent assessment of blinding integrity). Also, as subgroup analyses tended to focus on benefits only, it was not possible to assess the balance of benefits and harms in subpopulations. For example, it is possible that populations that are traditionally susceptible to lower tolerability of treatments in general, such as elderly patients, may be less likely to succeed with rTMS, but this has not yet been explored in the literature.
  ○ A major limitation of rTMS studies is that they generally excluded patients with medical and psychiatric comorbidities. However, consistent findings from 3 trials provide some preliminary evidence that rTMS can produce a clinically significant response in TRD patients with comorbid posttraumatic stress disorder (PTSD).
- What are the optimal rTMS treatment protocols/parameters? Evidence suggests that more intensive protocols are not uniformly more effective, and it is not yet clear which parameters matter the most. The effects of variability in coil geometry, coil placement, session duration, timing, or number of sessions remain unclear.
  ○ LHF-DLPFC protocols: This is the most well-studied approach and it includes a FDA-cleared protocol that has been shown to improve quality of life, but head-to-head trials and meta-regressions of sham-controlled trials have not yet demonstrated any particular LHF-DLPFC protocol to have any advantages over another.
    ▪ To guarantee adequate stimulation, 2 large multicenter RCTs support using standard rTMS at 10 Hz, 120% RMT, 3,000 pulses per session, 5 days per week for 3 to 6 weeks. Intensities down to 100% may also be effective in patients primarily under 50 years of age without Axis I comorbidities and past substance abuse.
      ▫ Deep rTMS, applied to the left DLPFC and administered at an intensity of 120% of motor threshold and a frequency of 18 Hz, for 1980 pulses per session on a schedule of 5 daily sessions for 4 weeks, is also FDA-cleared, but we identified no published sham-controlled trials that provided evidence to assess the balance of its benefits and harms in general. It is also unknown how its benefit/ harm profile directly compares to established standard rTMS protocols as we did not identify any head-to-head trials.
  ○ Low-frequency rTMS applied to the right DLPFC (RLF-DLPFC) at a speed of 1 pulse per second, intensities of 90 to 110%, and total pulses over 1,200 appears to be an additional viable approach. Although the theoretical advantages of lower risk of seizure induction and a lesser degree of scalp discomfort than LHF-DLPFC have not yet been proven in any multicenter clinical trials, it may be worth a try in patients with risk factors for seizure since it seems to provide comparable response and remission rates to LHF-DLPFC when given using parameters up to a speed of 10 pulses per second, an intensity of 100% motor threshold, with 2,000 pulses delivered per session (lower than FDA-cleared protocol). It has not yet been directly compared to the FDA-cleared LHF-DLPFC protocol.
  ○ Bilateral rTMS stimulation, sequentially targeting both the left and right DLPFC, is more effective than sham in improving response and remission. But since head-to-head trials have not yet demonstrated any significant advantage of bilateral rTMS stimulation over unilateral LHF-DLPFC or RLF-DLPFC, the value of the more complicated, time-consuming approach is not yet clear.
- Early prediction of benefit: We did not identify any evidence on a risk prediction tool for the early detection of rTMS treatment benefit.
- Continuation/maintenance treatment in rTMS responders: Available evidence is inadequate for determining the value of maintenance rTMS in general and for defining optimal treatment parameters. No studies have directly compared different rTMS maintenance strategies head-to-head and uncontrolled studies are limited by small sample sizes and heterogeneity in duration, acute rTMS parameters, and population characteristics. Rates of relapse during maintenance treatment ranged from 38% at 6 months (when rTMS was administered once weekly for 4 weeks, twice monthly for 2 months, and once monthly for 3 months), to 71% in a mean of 10.5 months (using a form of “clustered” maintenance, whereby rTMS was applied in monthly maintenance sessions of 5 treatments over a 2-day period).
  ○ Limited evidence suggests that rTMS retreatment following relapse may have some value, as rates of re-achievement of response ranged from 50% to 100%.

## DISCUSSION

As stated in a Memorandum dated March 20, 2014, in order to consider whether to make rTMS more broadly available to Veterans and/or consider developing detailed clinical guidance, the VA is seeking more research on a number of questions about who may benefit, under what treatment protocol, what the predictors of benefit are, and what the longer term outcomes are. Except for providing some low-strength guidance on parameters for using LHF-DLPFC rTMS, when to consider RLF- DLPFC rTMS, and on who may benefit, this Evidence Brief found that currently available evidence is still falling short of addressing all of the VA's questions.

The most important limitation of the included rTMS studies is that they generally excluded patients with medical and psychiatric comorbidities or did not report their prevalence. This particularly limits the generalizability of the evidence in this Brief to Veterans, who are known to have a greater burden of comorbid mental health conditions compared with the general population. While we identified some evidence that rTMS can produce a clinically significant response in patients with comorbid PTSD (KQ 1), it is unclear if the benefits and harms of rTMS treatment would differ among MDD patients with other comorbidities. A multi-site, sham-controlled VA Cooperative Study of rTMS that is currently enrolling Veterans with treatment resistant depression and possible comorbid disorders and/or a history of substance abuse will provide findings that are directly applicable to the Veteran population and have the potential to provide more general insights about how comorbidities may affect rTMS treatment (NCT01191333, CSP #556). This VA study plans to enroll 360 Veterans across 9 VA Medical Centers and the estimated completion date is November 2017. The results from this study may answer many outstanding questions regarding the use of rTMS among TRD patients with comorbidities.

Another major limitation is the heterogeneous definition of TRD throughout the literature on rTMS treatment for depression. We included studies that used a variety of definitions of TRD, which may have affected the conclusions in this report and lessened the apparent benefit of rTMS. If the VA wishes to evaluate their own data on rTMS, a uniform definition of TRD should be adopted.

A search of Clinicaltrials.gov identified an additional 16 ongoing clinical trials focusing on rTMS and depression (see Supplemental Materials). Three are multicenter trials and another trial is comparing clustered versus tapered maintenance rTMS over 2 years. Interventions for the ongoing trials identified are consistent with interventions acknowledged throughout this review, including high- versus low-frequency rTMS, deep TMS, accelerated TMS, and rTMS versus selective serotonin reuptake inhibitors. One ongoing clinical trial (NCT02080507) is recruiting patients that meet the criteria for ECT and will shed light on the effects of rTMS in this population. Two additional studies are focusing on theta burst rTMS, which consists of applying short, high frequency trains repeated at intervals of 200ms.99 However, due to the high frequency bursts delivered, there is a higher risk of seizure with TBS than with other rTMS protocols.99

We attempted to extend the results from several recent systematic reviews of sham-controlled trials by seeking additional evidence from head-to-head randomized trials that directly compared different rTMS parameters and from observational studies. Unfortunately, these additional sources of evidence generally suffered from the same limitations as in the sham-controlled trials, including use of small sample sizes from single centers. Despite their limitations, we included data from a number of head-to-head trials of different rTMS parameters for Key Question 2, as it offered the most direct evidence to address this question. However, we did not identify any observational studies with a concurrent control group, and none of the numerous small uncontrolled before-after studies clearly filled gaps in the trial evidence.

In the March 20, 2014 VA Memorandum on rTMS, one of the stated goals is to evaluate their own accumulating experience with rTMS on a system-wide basis to inform policy and practice. We agree that doing so could make an important contribution to the existing body of observational evidence by including a larger sample of patients across multiple sites and patients with a greater number of risk factors such as medical and psychiatric comorbidities and possible suicidality. As there is a great need to determine the durability of rTMS reponse, monitoring of outcomes after treatment should be included in this effort. Considering the high resource and time investments required with rTMS treatment, evaluation of its effects on reducing hospitalizations could be very useful. Clarifying whether response to rTMS differs based on level of social support,67 type of failed pharmacotherapy approaches, number of past episodes of TRD, and history of ECT failure could also help guide selection of Veterans who may be better candidates for rTMS.

Aside from the limitations we encountered in the literature described above, there are a number of methodological limitations with our review. An evidence brief differs from a full systematic review in that the scope is narrowly defined and the traditional review methods are streamlined in order to synthesize evidence within a shortened timeframe. Rapid review methodology is still developing and there is not yet consensus on what represents best practice. Methodological limitations of this Evidence Brief include the exclusion of studies published in languages other than English. Second, rather than generalizing from the broader base of all rTMS studies in major depression, we focused on a narrower subgroup of studies specifically in patients with TRD. However, we believe that enough evidence has accumulated for TRD to stand on its own, and findings from other recent reviews suggest that generalizing from all rTMS studies could underestimate the effects of rTMS in TRD on HAM-D change scores (37% in all MDD trials vs 48% in TRD trials)100 and on response (34% in all MDD trials and 43% in TRD) and remission (49% in all MDD trials and 58% in remission).23,25 Third, we considered a narrower range of outcomes than may be of interest to some stakeholders, such as cost-effectiveness, mean change in symptom scales, or patient satisfaction. Fourth, given the time constraints on completing this Evidence Brief and the large volume of literature encountered, we only included studies that reported both benefits and harms and were only able to perform quality assessment on multicenter trials. Finally, given the time constraints, we could not conduct a broad search for unpublished studies. However, in our search of Clinicaltrials.gov, we did identify 4 studies that were completed at least a year ago and still have not been published (see Supplemental Materials for details). Two of these studies had potential publication matches, but only one of these was included in the review. Lack of access to these unpublished trials is a potential limitation of this review.

In summary, rTMS represents a wide spectrum of treatments, many variations of which are still not well-studied. The specific LHF-DLPFC protocols cleared by the FDA have the strongest evidence of efficacy, with response and remission rates that are at least as good or better than those in the third and fourth acute treatment steps in the STAR*D trial, as well as of improvements in quality of life, and no major safety concerns have been uncovered. However, nearly all of this evidence was developed in experimental settings. Also, decisions to use rTMS must be weighed by consideration of the uncertainty about the maintenance of its benefits beyond the first 4-6 weeks of treatment and of the potential difficulty of implementing a 5-day per week intervention. The current VA/DoD Clinical Practice Guidelines (2009) support ECT as the recommended somatic treatment strategy for patients who have failed multiple other treatment strategies on management of Major Depressive Disorder and does not address rTMS.101 Since the sections of the 2009 VA/DoD CPG on MDD management appear outdated in their statement that TMS is not FDA-approved, we suggest the VA/DoD update the CPG to consider the two FDA clearances and the AHRQ findings of high-strength evidence about rTMs' acute efficacy that have emerged since 2009. In the meantime, rTMS has acceptable acute efficacy, and, compared to ECT, rTMS is less invasive, has a safety advantage for some patients, and may have more comparable benefits in TRD patients than originally thought.

## AKNOWLEDGEMENTS

We would like to thank Shammarie Mathis and Faye Arbues for assisting with data abstraction, Rose Relevo and Robin Paynter for conducting our literature searches, and Julia Haskin for assisting with editing.

## REFERENCES

1 (2014). Memorandum: Repetitive transcranial magnetic stimulation.
2 (2012). Emerging Technology Evidence Report: Repetitive Transcranial Magetic Stimulation Using the NeuroStar System for Treating Major Depressive Disorder.
3 Hasin DS, Goodwin RD, Stinson FS, Grant BF. (2005). Epidemiology of major depressive disorder: results from the National Epidemiologic Survey on Alcoholism and Related Conditions. Arch Gen Psychiatry.
4 Kessler RC, Chiu WT, Demler O, Merikangas KR, Walters EE. (2005). Prevalence, severity, and comorbidity of 12-month DSM-IV disorders in the National Comorbidity Survey Replication. Arch Gen Psychiatry.
5 Thomas JL, Wilk JE, Riviere LA, McGurk D, Castro CA, Hoge CW. (2010). Prevalence of mental health problems and functional impairment among active component and National Guard soldiers 3 and 12 months following combat in Iraq. Arch Gen Psychiatry.
6 Seal KH, Metzler TJ, Gima KS, Bertenthal D, Maguen S, Marmar CR. (2009). Trends and risk factors for mental health diagnoses among Iraq and Afghanistan veterans using Department of Veterans Affairs health care, 2002-2008. Am J Public Health.
7 Zinzow HM, Britt TW, McFadden AC, Burnette CM, Gillispie S. (2012). Connecting active duty and returning veterans to mental health treatment: interventions and treatment adaptations that may reduce barriers to care. Clin Psychol Rev.
8 Seal KH, Cohen G, Waldrop A, Cohen BE, Maguen S, Ren L. (2011). Substance use disorders in Iraq and Afghanistan veterans in VA healthcare, 2001-2010: Implications for screening, diagnosis and treatment. Drug Alcohol Depend.
9 Berlim MT, Fleck MP, Turecki G. (2008). Current trends in the assessment and somatic treatment of resistant/refractory major depression: An overview. Ann Med.
10 Little A. (2009). Treatment-resistant depression. Am Fam Physician.
11 Harald B, Gordon P. (2012). Meta-review of depressive subtyping models. J Affect Disord.
12 Vieta E, Colom F. (2011). Therapeutic options in treatment-resistant depression. Ann Med.
13 Fava M. (2003). Diagnosis and definition of treatment-resistant depression. Biol Psychiatry.
14 Gaynes BN, Lloyd SW, Lux L, et al. (2014). Repetitive transcranial magnetic stimulation for treatment-resistant depression: a systematic review and meta-analysis. J Clin Psychiatry.
15 (2008). Administration FaD, editor. 510(k) Summary NeuroStar TMS Therapy System.
16 (2013). Administration FaD, editor. 501(k) Summary Brainsway Deep TMS System.
17 O'Reardon JP, Solvason HB, Janicak PG, et al. (2007). Efficacy and safety of transcranial magnetic stimulation in the acute treatment of major depression: a multisite randomized controlled trial. Biol Psychiatry.
18 George MS, Lisanby SH, Avery D, et al. (2010). Daily left prefrontal transcranial magnetic stimulation therapy for major depressive disorder: a sham-controlled randomized trial. Arch Gen Psychiatry.
19 (2014). Administration FaD, editor. 510(k) Summary NeuroStar TMS Therapy System.
20 Gelenberg AJ, Freeman MP, Markowitz JC, et al. (2014). Practice guidelines for the treatment of patients with major depressive disorder.
21 Greenhalgh J, Knight C, Hind D, Beverley C, Walters S. (2005). Clinical and cost-effectiveness of electroconvulsive therapy for depressive illness, schizophrenia, catatonia and mania: systematic reviews and economic modelling studies. Health Technology Assessment (Winchester, England).
22 Pagnin D, de Queiroz V, Pini S, Cassano GB. (2004). Efficacy of ECT in depression: a meta-analytic review. J ECT.
23 Ren L, Li H, L P, Liu H, Wang J, Li C. (2014). Repetitive transcranial magnetic stimulation versus electroconvulsive therapy for major depression: A systematic review and meta-analysis. Prog Neuropsychopharmacol Biol Psychiatry.
24 Gaynes BN, Lux LJ, Lloyd SW, et al. (2011). Nonpharmacologic Interventions for Treatment-Resistant Depression in Adults.
25 (2014). Repetitive Transcranial Magnetic Stimulation for Treatment Resistant Depression: A Health Technology Assessment.
26 Prudic J, Olfson M, Marcus SC, Fuller RB, Sackeim HA. (2004). Effectiveness of electroconvulsive therapy in community settings. Biol Psychiatry.
27 Schlaepfer TE, George MS, Mayberg H. (2010). WFSBP Guidelines on Brain Stimulation Treatments in Psychiatry. World J Biol Psychiatry.
28 Kennedy SH, Milev R, Giacobbe P, et al. (2009). Canadian Network for Mood and Anxiety Treatments (CANMAT) Clinical guidelines for the management of major depressive disorder in adults. IV. Neurostimulation therapies. J Affect Disord.
29 (2010). The NICE Guideline on the Treatmnet and Management of Depression in Adults.
30 Lefaucheur JP, Andre-Obadia N, Antal A, et al. (2014). Evidence-based guidelines on the therapeutic use of repetitive transcranial magnetic stimulation (rTMS). Clin Neurophysiol.
31 Berlim MT, Van Den Eynde F, Daskalakis ZJ. (2013). A systematic review and meta-analysis on the efficacy and acceptability of bilateral repetitive transcranial magnetic stimulation (rTMS) for treating major depression. Psychol Med.
32 Berlim MT, Van den Eynde F, Jeff Daskalakis Z. (2013). Clinically meaningful efficacy and acceptability of low-frequency repetitive transcranial magnetic stimulation (rTMS) for treating primary major depression: a meta-analysis of randomized, double-blind and sham-controlled trials. Neuropsychopharmacology.
33 Berlim MT, Van Den Eynde F, Tovar-Perdomo S, Daskalakis ZJ. (2014). Response, remission and drop-out rates following high-frequency repetitive transcranial magnetic stimulation (rTMS) for treating major depression: A systematic review and meta-analysis of randomized, double-blind and sham-controlled trials. Psychol Med.
34 (2014). Transcranial Magnetic Stimulation for Depression.
35 (2014). Transcranial Magnetic Stimulation.
36 (2013). Transcranial Magnetic Simulation.
37 Slavin RE. (1995). Best evidence synthesis: an intelligent alternative to meta-analysis. J Clin Epidemiol.
38 Higgins JP, Altman DG, Gotzsche PC, et al. (2011). The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ.
39 Shea BJ, Hamel C, Wells GA, et al. (2009). AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. J Clin Epidemiol.
40 Owens DK, Lohr KN, Atkins D, et al. (2010). AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol.
41 Manes F, Jorge R, Morcuende M, Yamada T, Paradiso S, Robinson RG. (2001). A controlled study of repetitive transcranial magnetic stimulation as a treatment of depression in the elderly. Int Psychogeriatr.
42 Mosimann UP, Schmitt W, Greenberg BD, et al. (2004). Repetitive transcranial magnetic stimulation: a putative add-on treatment for major depression in elderly patients. Psychiatry Res.
43 Fregni F, Marcolin MA, Myczkowski M, et al. (2006). Predictors of antidepressant response in clinical trials of transcranial magnetic stimulation. Int J Neuropsychopharmacol.
44 Figiel GS, Epstein C, McDonald WM, et al. (1998). The use of rapid-rate transcranial magnetic stimulation (rTMS) in refractory depressed patients. J Neuropsychiatry Clin Neurosci.
45 Nahas ZH, Xingbao L, Kozel AF, et al. (2004). Safety and benefits of distance-adjusted prefrontal transcranial magnetic stimulation in depressed patients 55-75 years of age: A pilot study. Depress Anxiety.
46 Zheng H, Zhang L, Li L, et al. (2010). High-frequency rTMS treatment increases left prefrontal myo-inositol in young patients with treatment-resistant depression. Prog Neuropsychopharmacol Biol Psychiatry.
47 Fitzgerald PB, Hoy K, Gunewardene R, et al. (2011). A randomized trial of unilateral and bilateral prefrontal cortex transcranial magnetic stimulation in treatment-resistant major depression. Psychol Med.
48 Fitzgerald PB, Huntsman S, Gunewardene R, Kulkarni J, Daskalakis ZJ. (2006). A randomized trial of low-frequency right-prefrontal-cortex transcranial magnetic stimulation as augmentation in treatment-resistant major depression. Int J Neuropsychopharmacol.
49 Aguirre I, Carretero B, Ibarra O, et al. (2011). Age predicts low-frequency transcranial magnetic stimulation efficacy in major depression. J Affect Disord.
50 Rosenberg PB, Mehndiratta RB, Mehndiratta YP, Wamer A, Rosse RB, Balish M. (2002). Repetitive transcranial magnetic stimulation treatment of comorbid posttraumatic stress disorder and major depression. J Neuropsychiatry Clin Neurosci.
51 CSP#556 - The effectiveness of rTMS in depressed VA patients.
52 Carpenter LL, Janicak PG, Aaronson ST, et al. (2012). Transcranial magnetic stimulation (TMS) for major depression: a multisite, naturalistic, observational study of acute treatment outcomes in clinical practice. Depression & Anxiety.
53 Januel D, Dumortier G, Verdon C-M, et al. (2006). A double-blind sham controlled study of right prefrontal repetitive transcranial magnetic stimulation (rTMS): therapeutic and cognitive effect in medication free unipolar depression during 4 weeks. Prog Neuropsychopharmacol Biol Psychiatry.
54 Stern WM, Tormos JM, Press DZ, Pearlman C, Pascual-Leone A. (2007). Antidepressant effects of high and low frequency repetitive transcranial magnetic stimulation to the dorsolateral prefrontal cortex: a double-blind, randomized, placebo-controlled trial. J Neuropsychiatry Clin Neurosci.
55 Solvason HB, Husain M, Fitzgerald PB, et al. (2014). Improvement in quality of life with left prefrontal transcranial magnetic stimulation in patients with pharmacoresistant major depression: acute and six month outcomes. Brain Stimul.
56 Bakim B, Uzun UE, Karamustafalioglu O, et al. (2012). The combination of antidepressant drug therapy and high-frequency repetitive transcranial magnetic stimulation in medication-resistant depression. Klinik Psikofarmakoloji Bulteni / Bulletin of Clinical Psychopharmacology.
57 Padberg F, Zwanzger P, Keck ME, et al. (2002). Repetitive transcranial magnetic stimulation (rTMS) in major depression: relation between efficacy and stimulation intensity. Neuropsychopharmacology.
58 Rossini D, Lucca A, Zanardi R, Magri L, Smeraldi E. (2005). Transcranial magnetic stimulation in treatment-resistant depressed patients: a double-blind, placebo-controlled trial. Psychiatry Res.
59 George MS, Nahas Z, Molloy M, et al. (2000). A controlled trial of daily left prefrontal cortex TMS for treating depression. Biol Psychiatry.
60 Su TP, Huang CC, Wei IH. (2005). Add-on rTMS for medication-resistant depression: a randomized, double-blind, sham-controlled trial in Chinese patients. J Clin Psychiatry.
61 Turnier-Shea Y, Bruno R, Pridmore S. (2006). Daily and spaced treatment with transcranial magnetic stimulation in major depression: a pilot study. Australian & New Zealand Journal of Psychiatry.
62 Bersani FS, Minichino A, Enticott PG, et al. (2013). Deep transcranial magnetic stimulation as a treatment for psychiatric disorders: A comprehensive review. Psychiatrie & Psychobiologie.
63 Fitzgerald PB, Hoy K, Daskalakis ZJ, Kulkarni J. (2009). A randomized trial of the anti-depressant effects of low- and high-frequency transcranial magnetic stimulation in treatment-resistant depression. Depression & Anxiety.
64 Fitzgerald PB, Brown TL, Marston NA, Daskalakis ZJ, De Castella A, Kulkarni J. (2003). Transcranial magnetic stimulation in the treatment of depression: a double-blind, placebo-controlled trial. Arch Gen Psychiatry.
65 Fitzgerald PB, Sritharan A, Daskalakis ZJ, de Castella AR, Kulkarni J, Egan G. (2007). A functional magnetic resonance imaging study of the effects of low frequency right prefrontal transcranial magnetic stimulation in depression. J Clin Psychopharmacol.
66 Rossini D, Lucca A, Magri L, et al. (2010). A symptom-specific analysis of the effect of high-frequency left or low-frequency right transcranial magnetic stimulation over the dorsolateral prefrontal cortex in major depression. Neuropsychobiology.
67 Triggs WJ, Ricciuti N, Ward HE, et al. (2010). Right and left dorsolateral pre-frontal rTMS treatment of refractory depression: a randomized, sham-controlled trial. Psychiatry Res.
68 Eche J, Mondino M, Haesebaert F, Saoud M, Poulet E, Brunelin J. (2012). Low-vs high-frequency repetitive transcranial magnetic stimulation as an add-on treatment for refractory depression. Frontiers in Psychiatry.
69 Isenberg K, Downs D, Pierce K, et al. (2005). Low frequency rTMS stimulation of the right frontal cortex is as effective as high frequency rTMS stimulation of the left frontal cortex for antidepressant-free, treatment-resistant depressed patients. Ann Clin Psychiatry.
70 Richieri R, Boyer L, Padovani R, et al. (2012). Equivalent brain SPECT perfusion changes underlying therapeutic efficiency in pharmacoresistant depression using either high-frequency left or low-frequency right prefrontal rTMS. Prog Neuropsychopharmacol Biol Psychiatry.
71 McDonald WM, Easley K, Byrd EH, et al. (2006). Combination rapid transcranial magnetic stimulation in treatment refractory depression. Neuropsychiatric Disease and Treatment.
72 Galletly C, Gill S, Clarke P, Burton C, Fitzgerald PB. (2012). A randomized trial comparing repetitive transcranial magnetic stimulation given 3 days/week and 5 days/week for the treatment of major depression: is efficacy related to the duration of treatment or the number of treatments. Psychol Med.
73 Conca A, Di Pauli J, Beraus W, et al. (2002). Combining high and low frequencies in rTMS antidepressive treatment: preliminary results. Hum Psychopharmacol.
74 Fitzgerald PB, Hoy K, McQueen S, et al. (2008). Priming stimulation enhances the effectiveness of low-frequency right prefrontal cortex transcranial magnetic stimulation in major depression. J Clin Psychopharmacol.
75 Fitzgerald PB, Hoy KE, Singh A, et al. (2013). Equivalent beneficial effects of unilateral and bilateral prefrontal cortex transcranial magnetic stimulation in a large randomized trial in treatment-resistant major depression. Int J Neuropsychopharmacol.
76 Garcia-Toro M, Salva J, Daumal J, et al. (2006). High (20-Hz) and low (1-Hz) frequency transcranial magnetic stimulation as adjuvant treatment in medication-resistant depression. Psychiatry Res.
77 Fitzgerald PB, Hoy K, McQueen S, et al. (2009). A randomized trial of rTMS targeted with MRI based neuro-navigation in treatment-resistant depression. Neuropsychopharmacology.
78 Rusjan PM, Barr MS, Farzan F, et al. (2010). Optimal transcranial magnetic stimulation coil placement for targeting the dorsolateral prefrontal cortex using novel magnetic resonance image-guided neuronavigation. Hum Brain Mapp.
79 Paillere Martinot M-L, Galinowski A, Ringuenet D, et al. (2010). Influence of prefrontal target region on the efficacy of repetitive transcranial magnetic stimulation in patients with medication-resistant depression: A [18F]-flurodeoxyglucose PET and MRI study. Int J Neuropsychopharmacol.
80 Price GW, Lee JWY, Garvey CL, Gibson N. (2010). The use of background EEG activity to determine stimulus timing as a means of improving rTMS efficacy in the treatment of depression: A controlled comparison with standard techniques. Brain Stimul.
81 Fidalgo TM, Morales-Quezada JL, Muzy GS, et al. (2014). Biological markers in noninvasive brain stimulation trials in major depressive disorder: a systematic review. J ECT.
82 Speer AM, Willis MW, Herscovitch P, et al. (2003). Intensity-dependent regional cerebral blood flow during 1-Hz repetitive transcranial magnetic stimulation (rTMS) in healthy volunteers studied with H215O positron emission tomography: I. Effects of primary motor cortex rTMS. Biol Psychiatry.
83 Speer AM, Willis MW, Herscovitch P, et al. (2003). Intensity-dependent regional cerebral blood flow during 1-Hz repetitive transcranial magnetic stimulation (rTMS) in healthy volunteers studied with H215O positron emission tomography: II. Effects of prefrontal cortex rTMS. Biol Psychiatry.
84 Martin JLR, Barbanoj MJ, Schlaepfer TE, Thompson E, Perez V, Kulisevsky J. (2003). Repetitive transcranial magnetic stimulation for the treatment of depression. Systematic review and meta-analysis. Br J Psychiatry.
85 Cohen RB, Boggio PS, Fregni F. (2009). Risk factors for relapse after remission with repetitive transcranial magnetic stimulation for the treatment of depression. Depression & Anxiety.
86 Connolly KR, Helmer A, Cristancho MA, Cristancho P, O'Reardon JP. (2012). Effectiveness of transcranial magnetic stimulation in clinical practice post-FDA approval in the United States: results observed with the first 100 consecutive cases of depression at an academic medical center. J Clin Psychiatry.
87 Dannon PN, Dolberg OT, Schreiber S, Grunhaus L. (2002). Three and six-month outcome following courses of either ECT or rTMS in a population of severely depressed individuals-preliminary report. Biol Psychiatry.
88 Dannon PN, Schreiber S, Dolberg OT, Shemer L, Grunhaus L. (2000). Transcranial magnetic stimulation is effective in the treatment of the relapse of depression. International Journal of Psychiatry in Clinical Practice.
89 Dell'Osso B, D'Urso N, Castellano F, Ciabatti M, Altamura AC. (2011). Long-term efficacy after acute augmentative repetitive transcranial magnetic stimulation in bipolar depression: A 1-year follow-up study. Convuls Ther.
90 Demirtas-Tatlidede A, Mechanic-Hamilton D, Press DZ, et al. (2008). An open-label, prospective study of repetitive transcranial magnetic stimulation (rTMS) in the long-term treatment of refractory depression: reproducibility and duration of the antidepressant effect in medication-free patients. J Clin Psychiatry.
91 Fitzgerald PB, Benitez J, de Castella AR, Brown TL, Daskalakis ZJ, Kulkarni J. (2006). Naturalistic study of the use of transcranial magnetic stimulation in the treatment of depressive relapse. Australian & New Zealand Journal of Psychiatry.
92 Fitzgerald PB, Grace N, Hoy KE, Bailey M, Daskalakis ZJ. (2013). An open label trial of clustered maintenance rTMS for patients with refractory depression. Brain Stimul.
93 Janicak PG, Nahas Z, Lisanby SH, et al. (2010). Durability of clinical benefit with transcranial magnetic stimulation (TMS) in the treatment of pharmacoresistant major depression: assessment of relapse during a 6-month, multisite, open-label study. Brain Stimul.
94 Li X, Nahas Z, Anderson B, Kozel FA, George MS. (2004). Can left prefrontal rTMS be used as a maintenance treatment for bipolar depression. Depress Anxiety.
95 Mantovani A, Pavlicova M, Avery D, et al. (2012). Long-term efficacy of repeated daily prefrontal transcranial magnetic stimulation (TMS) in treatment-resistant depression. Depression & Anxiety.
96 O'Reardon JP, Blumner KH, Peshek AD, Pradilla RR, Pimiento PC. (2005). Long-Term Maintenance Therapy for Major Depressive Disorder With rTMS. Dis Nerv Syst.
97 Dunner DL, Aaronson S, Sackeim HA, et al. (2014). A multisite, naturalistic, observational study of transcranial magnetic stimulation (TMS) for patients with pharmacoresistant major depression: durability of benefir over a one-year follow-up period. J Clin Psychiatry.
98 Sackeim HA, Brannan SK, Rush AJ, George MS, Marangell LB, Allen J. (2007). Durability of antidepressant response to vagus nerve stimulation (VNS). Int J Neuropsychopharmacol.
99 Oberman L, Edwards D, Eldaief M, Pascual-Leone A. (2011). Safety of theta burst transcranial magnetic stimulation: A systematic review of the literature. J Clin Neurophysiol.
100 Lepping P, Schonfeldt-Lecuona C, Sambhi RS, et al. (2014). A systematic review of the clinical relevance of repetitive transcranial magnetic stimulation. Acta Psychiatr Scand.
101 (2009). VA/DoD Clinical Practice Guideline for Management of Major Depressive Disorder (MDD).

## SUPPLEMENTAL MATERIALS

### LIST OF ABBREVIATIONS

APA: American Psychiatric Association
BD: Bipolar Disorder
DBS: Deep Brain Stimulation
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition
ECT: Electroconvulsive Therapy
EPC: Evidence-based Practice Center
ESP CC: VA Evidence-based Synthesis Program Coordinating Center
FDA: Food and Drug Administration
HAMD: Hamilton Rating Scale for Depression
LHF-DLPFC: Left High-frequency Dorsolateral Prefrontal Cortex
MDD: Major Depressive Disorder
OEF: Operation Enduring Freedom
OIF: Operation Iraqi Freedom
PFC: Prefrontal Cortex
PTSD: Posttraumatic Stress Disorder
RCT: Randomized Controlled Trials
RLF-DLPFC: Right Low-frequency Dorsolateral Prefrontal Cortex
RMT: Resting Motor Threshold
RTI-UNC: RTI-University of North Carolina
rTMS: Repetitive Transcranial Magnetic Stimulation
SSRI: Selective Serotonin Reuptake Inhibitor
TRD: Treatment-resistant Depression
VNS: Vagus Nerve Stimulation

### SEARCH STRATEGIES

Ovid MEDLINE and OLDMEDLINE (1946 to April Week 2 2014)

Date Searched: April 14, 2014

1 | Depressive disorder.mp. or exp Depressive Disorder/
2 | transcranial magnetic stimulation.mp. or exp Transcranial Magnetic Stimulation/
3 | rTMS.mp.
4 | 2 or 3
5 | 1 and 4
6 | limit 5 to (english language and humans)
7 | limit 6 to (case reports or editorial or letter)
8 | 6 not 7

Ovid PsycINFO 1806 to April Week 2 2014

Date Searched: April 17, 2014

1 | exp major depression/ or (depression or depressive).ti,ab.
2 | transcranial magnetic stimulation/ or (rtms or transcranial magnetic stimulation).ti,ab.
3 | 1 and 2
4 | limit 3 to english language
5 | limit 4 to human
6 | limit 5 to editorial
7 | limit 5 to letter
8 | 6 or 7
9 | 5 not 8

Ovid EBM Reviews

Date Searched: April 17, 2014

1 | (depression or depressive).ti,ab.
2 | (rtms or transcranial magnetic stimulation).ti,ab.
3 | 1 and 2

### PEER REVIEW COMMENT DISPOSITION TABLE

Reviewer # | REVIEWER COMMENT | RESPONSE
1. Are the objectives, scope, and methods for this review clearly described?
1 | Yes (no comments)
2 | Yes (no comments)
3 | Yes (no comments)
2. Is there any indication of bias in our synthesis of the evidence?
1 | Yes; The review is not done by anyone with clinical neuroscience knowledge to understand critical issues like the physics of TMS and how that interacts with dose questions. Some of the conclusions are thus frankly wrong. Additionally, there is a hubris in thinking that the review can come up with a minimally effective dose, when in fact they cannot. Finally, they rely too heavily on older reviews which relied on earlier studies, and this is thus out of date in many areas, particularly the issue of professional society support and insurance coverage. | Please see related changes detailed below.
2 | No (no comments)
3 | No (No comments)
3. Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
1 | Yes; See my extensive comments at the end with references.
2 | No (no comments)
3 | I'd encourage taking a look at the several studies that have examined accuracy of placement of the magnetic stimulation as a potential way to improve outcomes. See, for example, Rusjan PM, Barr MS, Farzan F, Arenovich T, Maller JJ, Fitzgerald PB, Daskalakis ZJ. Optimal transcranial magnetic stimulation coil placement for targeting the dorsolateral prefrontal cortex using novel magnetic resonance image-guided neuronavigation. Hum Brain Mapp. 2010 Nov;31(11):1643-52 | Yes, we noted the imaging-guided navigation approach to improving stimulus parameters as a future trend in rTMS research, but that more research is needed in larger samples. We added Rusjan 2010 reference.
4. Please write any additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
1 | Page 4, line 12. The rMT also helps determine the amount of stimulation needed to get into the cortex, not just minimizing risk. This is important for a comment below about the minimum intensity needed to treat. | Added.
1 | Line 21. Manufacturer training shows people how to operate the machine and turn it on and off and who to call if it breaks. It is like the training you get when you buy a car and they show you where the spare tire is hidden. True TMS training is like a driver's license, and the Ford dealer cannot give you that. Training must be done through appropriate non-vendor courses, CME's, offered at annual meetings and at universities. Many insurance companies are requiring non-vendor certification before they will reimburse. The user groups in this area (Clinical TMS Society, World Federation of Societies of Biological Psychiatry Taskforce on Brain Stimulation Therapies) all support non-vendor certification as minimal requirements for practice. VA hospital, for credentialing of TMS, require this non-vendor certification as well. | Changed to, “Training is typically provided by the manufacturer and through appropriate non-vendor courses and certifications required by many insurance companies and health systems, including the VHA.”
1 | The FDA has now revised this limitation based on more data supplied by the manufacturer and the limitation has been lifted (April 2014). See the Neuronetics webpage or do an FDA search to find the new language | Added “In 2014, in response to the results from another multicenter sham-controlled RCT, sponsored by the National Institutes of Health (NIH), the clearance was expanded to include patients who had failed one or more prior antidepressant medications in the current episode.”
1 | Page 5 line 6. This is an outdated and incorrect statement. The citing of a summary published in 2009, which went back in time and was out of date, ignores new clear guidelines published in the last 5 years. The APA guidelines were published before the NIH large trial was complete. Over the past 5 years all professional societies who have examined the literature have concluded that there is convincing class I evidence of effectiveness in acute depression, and they recommend that it be used. Efficacy and effectiveness are no longer in question. Please see clear recent guidelines published by the WFSBP and others. (1, 2); 1. George MS, Schlaepfer T, Padberg F, Fitzgerald PB. Brain stimulation treatments for depression. World J Biol Psychiatry. 2014;15(2):167-8. doi: 10.3109/15622975.2013.869619. PubMed PMID: 24506290.; 2. Schlaepfer TE, George MS, Mayberg H. WFSBP Guidelines on Brain Stimulation Treatments in Psychiatry. World J Biol Psychiatry. 2010;11(1):2-18. Epub 2010/02/12. doi: 10.3109/15622970903170835. PubMed PMID: 20146648.; Your discussion of the current status of practice guidelines and position statements did not include consideration of the use of TMS as promulgated in the 3rd Edition of the American Psychiatric Association Practice Guidelines for the Treatment of Patients with Major Depressive Disorder, and in other practice guidelines, nor does it reference the current CPT Category I code status. The following authoritative organizations now include TMS Therapy as an established, proven, standard of care treatment option after initial treatment failure with medications. They include the two domestic and two international authorities listed below.; - American Psychiatric Association, 2010 Practice Guidelines for the Treatment of Patients with Major Depressive Disorder; - Agency for Healthcare Research and Quality (2011); - World Federation of Societies for Biological Psychiatry, Schlaepfer, et al, World J Bio Psych (2009); - Canadian Network for Mood and Anxiety Treatments, Kennedy, et al. J Aff Disorders (2009); The recommendations for the use of TMS in the current APA 2010 Practice Guidelines for the Treatment of Patients with Major Depressive Disorder, are clear and unambiguous. Specifically, the document states, “…for patients whose symptoms have not responded adequately to medication…transcranial magnetic stimulation could also be considered…”. | Changed to “Several professional societies have issued clinical practice guidelines on the use of rTMS for treating depression, including the American Psychiatric Association (APA), World Federation of Societies of Biological Psychiatry Task Force (WFSB-PTF), the Canadian Network for Mood and Anxiety Treatments (CANMAT), the National Collaborating Centre for Mental Health (NCCMH) in the UK, and, most recently, the International Federation of Clinical Neurophysiology. All but the NCCMH regard rTMS as a clinically relevant technique to treat major depression, including treatment-resistant depression. The NCCMH recommends that TMS should only be performed in research studies designed to investigate factors that might increase the procedure's clinical efficacy.”
1 | This review does not reference one of the most recent, authoritative and independent policy papers on the safety and efficacy of TMS, namely the Agency for Healthcare Research and Quality (AHRQ, 2011) report on the comparative effectiveness analysis of non-pharmacologic treatments for treatment resistant depression. That document is significant largely because of its rigorous methodologic approach to study analysis. In that report, the AHRQ Panel concluded that the strength of evidence was “high” for the efficacy of TMS compared to sham treatment. The AHRQ report is also significant for its detailed and thorough analysis of how these outcomes compare to the outcomes expected for medication treatment as an alternative. Specifically, the report summarizes for the reader the likelihood of patient benefit from the standard pharmacologic ‘next-step’ options. They note for example, that the likelihood of achieving remission in patients with a routine pharmacologic “switch” to next best medication only averaged 22.3% (95% CI: 16.2% to 28.4%). With augmentation, the likelihood of achieving remission was similar, averaging 27.2% (95% CI: 20.4% to 34.0%). These numbers highlight the diminishing benefit with of treating increasing levels of treatment resistance with standard pharmacologic options, and are not as good as the remission rates observed in Neuronetics' Outcomes Study 37.1% (95% CI: 31.8% to 42.8%). | We had previously referenced the associated 2014 Journal of Clinical Psychiatry publication of the 2011 AHRQ review. We added reference to the 2011 Evidence Report as well and added details about the strength of the evidence for response and remission, respectively, as well as a comment about the comparability of rTMs' response and remission rates with other next step pharmacologic options. To better reflect rTMs' balance of benefits and harms, we also added information about the low and insufficient evidence on health outcomes and harms, respectively.
1 | Line 27. Again, this is out of date and incorrect. ‘Most health plans have decided against…’ needs data. In fact, most Medicare subgroups including Palmetto in South Carolina now cover TMS, as do most Blue Cross Blue Shield affiliates. This statement is out of date and needs updating. | Changed to “Insurance coverage of rTMS treatment is mixed, and to help make coverage decisions, several health plans have conducted their own reviews. The BlueCross BlueShield Technology Assessment Program published an updated assessment on the effect of TMS therapy on depression in early 2014. The assessment relied on results from 2 published trials, FDA documents, extension studies, and 7 meta-analyses, and concluded that, while the mechanism by which TMS might improve depression is biologically plausible, large trials and meta-analyses do not provide convincing evidence of improved health outcomes. In 2013, United Healthcare published a medical policy on TMS that stated “there is insufficient evidence that transcranial magnetic stimulation (TMS) is beneficial for health outcomes in patients with major depression.” Anthem (Wellpoint) covers rTMS for major depression with one of the 2 FDA-cleared devices for patients meeting very strict criteria. CMS has not issued a coverage policy on rTMS, however a number of Medicare contractors have issued Local Coverage Determinations regarding rTMS coverage. Cahaba Government Benefit Administrators®, LLC (L32834), Palmetto GBA (L34170), Novitas Solutions, Inc. (L32055 and L33660), and First Coast Service Options, Inc. (L33676) cover rTMS for patients diagnosed with resistant depression with some requirements on the definition of resistance and limitations on which patients can safely receive rTMS treatment. Conversely, National Government Services, Inc. (L32038), Wisconsin Physicians Service Insurance Corporation (L32220), and Noridian Healthcare Solutions, LLC (L33495) have issued non-coverage policies, concluding that rTMS is not medically necessary.”
2 | Impressive accomplishment in a brief period of time. In the Background (P. 3, lines 23-33): While there is no national consensus on Medicare coverage nationally, regional coverage has fluctuated. I would confirm the current status of CMS coverage in various sections of the country. | Thank you. Changed to, “CMS has not issued a coverage policy on rTMS, however a number of Medicare contractors have issued Local Coverage Determinations regarding rTMS coverage. Cahaba Government Benefit Administrators®, LLC (L32834), Palmetto GBA (L34170), Novitas Solutions, Inc. (L32055 and L33660), and First Coast Service Options, Inc. (L33676) cover rTMS for patients diagnosed with resistant depression with some requirements on the definition of resistance and limitations on which patients can safely receive rTMS treatment. Conversely, National Government Services, Inc. (L32038), Wisconsin Physicians Service Insurance Corporation (L32220), and Noridian Healthcare Solutions, LLC (L33495) have issued non-coverage policies, concluding that rTMS is not medically necessary.”
2 | In the Scope, allowing studies employing a large variation of TRD definitions, while understandable, is a key factor that might limit findings, because the heterogeneity can mask effects. This point needs to be more clearly made in the Discussion as a limitation, and its implications need to be discussed. | Added “Another major limitation is the heterogeneous definition of TRD throughout the literature on rTMS treatment for depression. We included studies that used a variety of definitions of TRD, which may have affected the conclusions in this report and lessened the apparent benefit of rTMS. If the VA wishes to evaluate their own data on rTMS, a uniform definition of TRD should be adopted.”
1 | Page 10, Line 8. Well, this certainly shows how simply doing meta-analyses can stand in the way of scholarship. There is a great deal known about how age influences TMS antidepressant outcome, none of which is mentioned in this evidence-based synthesis. I will attempt to summarize it here. In the early days of TMS studies, the FDA was quite concerned about potential harm of TMS, particularly seizures. We knew that the risk of seizures was a function of a matrix of TMS intensity, frequency, train duration, and inter-train interval. (3) The FDA thus limited us to treating at or below the motor threshold. Realize that the motor threshold is determined over the motor cortex while we treat over the prefrontal cortex. In the early studies with low intensity, no one over 50 responded to TMS. (4) We wondered if there might be selective prefrontal atrophy in depressed patients as they aged, and in fact found this was so, and then determined the needed MT for actually reaching the prefrontal cortex and overcoming this atrophy. This was 117% of MT, rounded up to 120. We then carried this out in an elderly depressed group and found that it worked. (5-7) Most studies since that time have used intensities at least 120%MT. For patients over 80, or who may have comorbid conditions that cause atrophy (like past substance abuse, alzheimer's disease, etc), the intensity may need to be greater than 120% MT. It is incorrect to state that 100%MT works, as it does not for anyone over age 50. In summary, now that we know about the minimum intensity needed to reach the brain in older adults, age does not seem to be a predictor, at intensities at least 120%. But the caveat is that most studies did not include the typical VA population with many comorbidities and past substance abuse. Veterans may need even higher intensities. A Merit grant coordinated with CSP 556 is examining this question directly. (PI Allyson Rosen, Palo Alto VA) 3. Wassermann EM. Risk and safety of repetitive transcranial magnetic stimulation: report and suggested guidelines from the International Workshop in the Safety of Repetitive Transcranial Magnetic Stimulation, June 5-7, 1996. Electroencephalography and Clinical Neurophysiology. 1998;108:1-16. 4. Figiel GS, Epstein C, McDonald WM, Amazon-Leece J, Figiel L, Saldivia A, et al. The use of rapid-rate transcranial magnetic stimulation (rTMS) in refractory depressed patients. Journal of Neuropsychiatry & Clinical Neurosciences. 1998;10(1):20-5. 5. Nahas Z, Li X, Kozel FA, Mirzki D, Memon M, Miller K, et al. Safety and benefits of distance-adjusted prefrontal transcranial magnetic stimulation in depressed patients 55-75 years of age: a pilot study. Depress Anxiety. 2004;19(4):249-56. Epub 2004/07/27. doi: 10.1002/ da.20015. PubMed PMID: 15274174. 6. McConnell KA, Nahas Z, Shastri A, Lorberbaum JP, Kozel FA, Bohning DE, et al. The transcranial magnetic stimulation motor threshold depends on the distance from coil to underlying cortex: a replication in healthy adults comparing two methods of assessing the distance to cortex. Biol Psychiatry. 2001;49(5):454-9. Epub 2001/03/29. http://www.ncbi.nlm.nih.gov/pubmed/11274657. PubMed PMID: 11274657. 7. Kozel FA, Nahas Z, deBrux C, Molloy M, Lorberbaum JP, Bohning D, et al. How coil-cortex distance relates to age, motor threshold, and antidepressant response to repetitive transcranial magnetic stimulation. J Neuropsychiatry Clin Neurosci. 2000;12(3):376-84. Epub 2000/08/24. http://www.ncbi.nlm.nih.gov/pubmed/10956572. PubMed PMID: 10956572. | We thank the reviewer for suggesting additional citations related to age. Figel 1998 and Nahas 2004 met our eligibility criteria and were added to the report. In Key Question on adequate course of treatment added qualifications to statement that 100% RMT works primarily in patient under 50 years of age without Axis I comorbidities and past substance abuse.
1 | In terms of predictors of response, TMS is like all other antidepressants. Higher levels of treatment resistance have consistently correlated with poorer outcomes. Additionally, comorbid anxiety disorders, or anxiety symptoms, predict poorer response. See Lisanby (8)et al. 8. Lisanby SH, Husain MM, Rosenquist PB, Maixner D, Gutierrez R, Krystal A, et al. Daily left prefrontal repetitive transcranial magnetic stimulation in the acute treatment of major depression: clinical predictors of outcome in a multisite, randomized controlled clinical trial. Neuropsychopharmacology : official publication of the American College of Neuropsychopharmacology. 2009;34(2):522-34. doi: npp2008118 [pii] 10.1038/npp.2008.118 [doi]. PubMed PMID: 18704101. | We thank the reviewer for suggesting additional evidence about predictors of response. Since our report focuses on response and remission outcomes, rather than pre- to post-treatment changes in depression scores, Lisanby 2009 did not meet our eligibility criteria.
2 | In Results, I'm a little confused by the comorbidity results on p.11, lines 21-25. It looks like the Partial Hospitalization Program and PTSD Clinic population involved patients with MDD or PTSD, although it might be that patients with PTSD “who remained depressed” indicates comorbid depression. The authors should be clearer about this part. | Changed to, “One trial from the Partial Hospitalization Program and Post Traumatic Stress Disorder Clinic of the Mental Health Service Line at the Department of Veterans Affairs Medical Center in Washington, DC included 12 patients with TRD and combat PTSD who remained depressed after a minimum of one month on antidepressant therapy (100% male; mean age of 55 years). After 2 weeks of fast (5 Hz) and slow (1 Hz) frequency left-sided rTMS, response rates were 67% and 83%, respectively.”
2 | In Results, lines 8 and 10, I think the reference, listed as # 15 in two places, should be # 16. | Corrected.
1 | Page 14 conmeds. Most of the early studies required that patients be antidepressant medication free as this was scientifically simpler in assessing whether TMS worked or not, without having to worry about medication interactions. The overall response and remission rates in the two large modern RCT's were 15% in the double blind phase (3 or 4 weeks) and then 30% remission in the active open at 6 weeks. In contrast to this 30% remission at 3-4 weeks in the medication free studies, the Carpenter open label study found remission rates much higher and an overall response rate of about 60%. Many people use these studies to suggest that TMS rates on patients with medications would likely be higher than the medication free initial studies. This has clearly been shown to be the case with ECT for example (see Sackeim, 2010) The Synthesis is correct in that this has not been formally studied. | We appreciate the reviewer's confirmation of our synthesis of the effects of concomitant medications.
1 | Page 15, line 23. The NIH trial did not use the same protocol as Neuronetics, and did not confirm it as they were conducted simultaneously. The NIH trial randomized patients and stratified based on treatment resistance. Moreover it was for a fixed 3 week course, with continued treatment for those showing improvement. The NIH trial was the first truly double-blinded study, with an active sham and clear documentation of the integrity of the blind. | Corrected.
1 | See this reference for quality of life data from the neuronetics pivotal study. (9)M. A.</ author><author>Lisanby, S. H.</author></authors></contributors><auth-address>Department of Psychiatry, Stanford University Medical Center, Stanford University, 401 Quarry Road, Palo Alto, CA 94305 USA. Electronic address: solvason@mac.com.&#xD;University of Texas Southwestern Medical School, Dallas, TX, USA.&#xD;The Alfred Hospital, Melbourne, Australia.&#xD;Medical College of Georgia, Augusta, GA, USA.&#xD;Wake Forest University, Winston-Salem, NC, USA.&#xD;Northwestern University, Chicago, IL, USA.&#xD;Neuronetics, Inc., Malvern, PA, USA.&#xD;Duke University, Durham, NC, USA.</ auth-address><titles><title>Improvement in Quality of Life With Left Prefrontal Transcranial Magnetic Stimulation in Patients With Pharmacoresistant Major Depression: Acute and Six Month Outcomes</title><secondary-title>Brain Stimul</secondary-title><alt-title>Brain stimulation</alt-title></titles><alt-periodical><full-title>Brain stimulation</full-title><abbr-1>Brain Stimulat</abbr-1></alt-periodical><edition>2013/12/18</edition><dates><year>2013</ year><pub-dates><date>Nov 4</date></pub-dates></dates><isbn>1935-861X (Electronic This needs to be in the review. 9. Solvason HB, Husain M, Fitzgerald PB, Rosenquist P, McCall WV, Kimball J, et al. Improvement in Quality of Life With Left Prefrontal Transcranial Magnetic Stimulation in Patients With Pharmacoresistant Major Depression: Acute and Six Month Outcomes. Brain Stimul. 2013;10.1016/j.brs.2013.10.008. Epub 2013/12/18. doi: 10.1016/j.brs.2013.10.008. PubMed PMID: 24332384. | Added.
1 | Page 19, line 31 adequate dose. This section is naïve about TMS and ignores the substantial translational clinical work done with TMS in the motor system, where one can stimulate and see immediate movements in the opposite body, and measure changes in cortical inhibition or excitability. It also ignores the brain imaging (PET, SPECT, fMRI) work where surrogate markers of brain activity have been used to infer the minimum dose needed to interact with brain circuits. | We are aware of the brain imaging work and agree that the surrogate markers of brain activity are on the causal pathway to clinical outcomes. However, since this report is focused only on the final clinical outcomes, we did not include the evidence on surrogate markers.
1 | Line 38 The fact that 100% MT works is not due to sample size, but physics!! See the discussion above about the body of work showing why you need at least 100% MT in most adults, and 120% MT in anyone with atrophy or over age 50. | Removed statement about sample size and added qualification that intensities down to 100% RMT were effective primarily in patient under 50 years of age without Axis I comorbidities and past substance abuse.
1 | Line 39 This is a logical fallacy and is not correct. The minimum intensity for which there are class I data is 120% MT. There are no supportive data less than this. | Added, “The best evidence from 2 large multicenter RCTs supports using 120% RMT to guarantee an adequate stimulation intensity. Using data from the 2014 systematic review by Berlim and colleagues of 29 sham-controlled trials of high-frequency left-sided PFC rTMS at lower intensities, 80% to 110%, we found that intensities down to 100% may also be effective in patients primarily under 50 years of age without Axis I comorbidities and past substance abuse.”
1 | Page 20, line 11 This is incorrect. The only large Class I trials used 120% MT for 4-6 weeks. Any dose less than this is inadequate. The statistical logic behind starting with an inadequate dose based on small inadequate trials baffles me. If fluoxetine were being analyzed this way, they would suggest 5 mg for 2 weeks to start. This would clearly be inadequate, and waste much time and effort and promote dropouts due to non-response. As an expert in the field the statement on line 13 that an underdosed prescription is a ‘reasonable place to start’ is not scientifically correct and is not justified and is bad medicine. This should not be a statement in the final synthesis. Imagine recommending systematic underdosing of an antibiotic, allowing the infection to continue growing and patients to suffer. There are no data to support the incorrect speculation of line 13, and lots of studies to show this is an inadequate dose. | Deleted.
1 | Line 16. There are no data to support that what is written here is a ‘minimally effective dose.’ This should be stricken. The minimally effective dose is that which was approved by the FDA and tested in two large RCT's. | Deleted
1 | Page 22 long-term durability. For proper interpretation, this section needs to note that the current treatments for depression have poor long term durability, with the exception of vagus nerve stimulation where long-term durability is high. For example, from the STAR*D medication study, in patients who did not respond to the first two levels, only 20% of eventual remitters remained remitted after 12 months. ECT has >50% relapse rates at 6 months. The small studies with TMS suggest durability that is at least as good as other treatments for this population. | Added: “For patients with TRD, response to ECT or various antidepressant medications is often transient.”
1 | Page 25 line 22 Again, the suggestion that there is ‘low-strength evidence’ that 10 treatments at 10% RMT is incorrect. Low-strength evidence means no strength evidence and that it has not been scientifically proven. This conclusion is not based on data, or the scientific method, and should be removed. The only minimally effective doses are those that have been shown effective in large RCT, and are FDA approved. Publishing this statement would be tantamount to malpractice, and should not be in the final conclusions. | Changed to: “To guarantee adequate stimulation, 2 large multicenter RCTs support using standard rTMS at 10 Hz, 120% RMT, 3,000 pulses per session, 5 days per week for 3 to 6 weeks. Intensities down to 100% may also be effective in patients primarily under 50 years of age without Axis I comorbidities and past substance abuse.”
1 | Page 27 line 41 – response and remission rates in open label trials on medications with comorbidities are in the 50-60% range, for treatment resistant depressed patients. This is better than stage III in the STAR*D studies, and approaches modern ECT outcomes. | Changed to: “In summary, rTMS represents a wide spectrum of treatments, many variations of which are still not well-studied. The specific LHF-DLPFC protocols cleared by the FDA have the strongest evidence of efficacy, with response and remission rates that are at least as good or better than those in the third and fourth acute treatment steps in the STAR*D trial, as well as improvements in quality of life, and no major safety concerns have been uncovered.”
1 | Page 27, Line 42. The RCT's were done on patients off medications. More recent trials on medications show much better response. ECT done on antidepressant medication free patients has worse outcomes than ECT on patients who maintain their antidepressants (Sackeim, 2011). | The RCT's are mixed in terms of whether the patients were on or off medications and clear differences have not yet been found based on whether rTMS is used as augmentation.
1 | Page 27, Line 43. See above, there have been studies showing improvement in quality of life. This conclusion is not correct | Changed to: “The specific LHF-DLPFC protocols cleared by the FDA have the strongest evidence of efficacy, with response and remission rates that are at least as good or better than those in the third and fourth acute treatment steps in the STAR*D trial, as well as improvements in quality of life, and no major safety concerns have been uncovered.”
2 | In their summary, I think the authors understate the potential benefit of rTMS in TRD patients (p. 27, lines 39-43). TRD is hard to treat. From STAR*D findings, after you've failed two good antidepressant trials, the likelihood of remission is 15% or lower. Compared to these outcomes, a remission rate range of 19-35% looks more promising, so I think their categorization of rTMS rates as being “modest” needs to be placed in perspective of these rates in TRD patients otherwise being worse. I think their results more strongly support considering the use of rTMS in this TRD VA population than their summary indicates. | Changed to, “The specific LHF-DLPFC protocols cleared by the FDA have the strongest evidence of efficacy, with response and remission rates that are at least as good or better than those in the third and fourth acute treatment steps in the STAR*D trial, as well as improvements in quality of life, and no major safety concerns have been uncovered.”
2 | Also, I think the evidence of limited adverse events so far for rTMS is important to emphasize more in the context of TRD, especially as the gold standard treatment for TRD presented here is ECT (which can be harder to tolerate and has more clearly described adverse events). This point may be especially relevant to a VA TRD population, which has higher rates of comorbid traumatic brain injury and potentially more contraindications to ECT treatment. | Changed to, “In the meantime, rTMS has acceptable acute efficacy, and, compared to ECT, rTMS is less invasive, has a safety advantage for some patients, and may have more comparable benefits in TRD patients than originally thought.”
1 | Page 28 line 3. This is a healthcare economics statement. These data were not presented in the review. In fact, in non-VA settings, TMS is quite cost-effective. (10) 10. Simpson KN, Welch MJ, Kozel FA, Demitrack MA, Nahas Z. Cost-effectiveness of transcranial magnetic stimulation in the treatment of major depression: a health economics analysis. Adv Ther. 2009;26(3):346-68. Epub 2009/03/31. doi: 10.1007/s12325-009-0013-x. PubMed PMID: 19330495. | Deleted
1 | Page 28, Line 6. This is a bizarre statement, totally lacking any supporting data. There are no data about TMS response rates in patients who have failed or could not tolerate ECT. ECT is only minimally used in the VA system, for a variety of reasons, including scheduling recovery room time, cognitive side effects, medical comorbidities and stigma. None of these are problems with TMS. Most healthcare systems are using TMS as a second line treatment after some level of medication failure, and BEFORE ECT. That is the population that has been studied and for which there is evidence of effectiveness and for which it is FDA approved. Concluding a synthesis with a totally heretical and unsupported speculation seems unwise and detracts from the many more reasoned conclusions within the body of work. | Changed to, “In the meantime, rTMS has acceptable acute efficacy, and, compared to ECT, rTMS is less invasive, has a safety advantage for some patients, and may have more comparable benefits in TRD patients than originally thought.”
2 | The authors could emphasize more the potential importance of researching how rTMS might play a role in MDD/PTSD comorbidity in the VA population. | Regarding the VA Cooperative Study that is currently enrolling participants, we added, “The results from this study may answer many outstanding questions regarding the use of rTMS among TRD patients with comorbidities.”
2 | An important general point, implied throughout but never clearly stated, is that rTMS is really a general approach rather than a specific entity, and that researchers, clinicians, and patients are early on in understanding how to most effectively apply this spectrum of treatments. Overall, however, I found this to be an excellent, thoughtful, and comprehensive report. | On page 4 we added: “TMS encompasses a wide spectrum of treatments. Aside from a single TMS stimulation, repetitive TMS, and deep TMS, strategies for using rTMS vary based on types of coils, region of the brain stimulated (ie, left or right dorsolateral prefrontal cortex, or bilateral), “dose” (eg, intensity, percent of resting motor threshold (%RMT)), speed of pulses (ie, Hz, pulses per second), pulse train duration, inter-train interval, trains per session, total number of pulses, number of weekly sessions, duration (ie, 2 to 6 weeks), and total number of sessions.”
3 | I thought the report side stepped comparisons with ECT to too much of an extent. Specifically, there is good reason to extrapolate from meta-analyses and more contemporary RCTs that TMS is substantially less effective that ECT across 4-6 weeks, but TMS has some advantages concerning tolerability (i.e., lack of significant cognitive side effects) and medical safety (it does not require general anesthesia). There does not need to be an adequately powered RCT to accept the notion that the treatment that requires 6-12 administrations of general anesthesia is more dangerous than the one that does not! ECT is not even available at the Philadelphia VAMC – we have to refer out for this treatment when it is urgently indicated. | Added to Background: “The American Psychiatric Association (APA) recommends ECT as a treatment of choice for patients with severe MDD that is not responsive to psychotherapeutic and/or pharmacological interventions.20 The recommendation was based on older meta-analyses of clinical trials which found remission rates of 70% to 90% for major depression and demonstrated that ECT is more effective and works faster than other therapies with which it has been compared, including rTMS.21,22 Although a 2014 meta-analysis confirmed these older findings about the superiority of ECT for severe or resistant major depression overall,23 findings from other recent meta-analyses that focused exclusively on TRD suggest there may be less of a difference between ECT and rTMS in TRD subgroups in response (range, 20% to 64% vs 20% to 58%) and remission (range, 15% to 53% vs 9% to 43%).14,24,25 ECT requires general anesthesia and is associated with transient episodes of hypertension, tachycardia, and arrhythmia, is still socially stigmatized, has high relapse rates (> 60%), and, in a community-based setting, may have more modest remission rates than expected.26” Changed conclusion to: “In the meantime, rTMS has acceptable acute efficacy, and, compared to ECT, rTMS is less invasive, has a safety advantage for some patients, and may have more comparable benefits in TRD patients than originally thought.”
5. Are there any VA clinical performance measures, programs, quality improvement measures, patient care services, or conferences that will be directly affected by this report? If so, please provide detail.
1 | no response
2 | Not that I know of.
3 | I can't think of any that aren't already mentioned in the report.
4 | I'd begin accepted that the FDA has approved several TMS devices (i.e., it is a “proven” treatment in the eyes of the most important regulatory authority), but that – outside of the specific protocols that were accepted by the FDA as pivotal trials - the parameters of administering the treatment are not well-studied and there is real reason to be skeptical about the relative effectiveness and cost-effectiveness of this treatment. Given the difficulty of implementing a 5 day per week intervention within most VAMC, it would behoove us to take these implementation issues – including questions of dose-response and maintenance of gains following the first 4-6 weeks of treatment – very seriously! I likewise would encourage a “call to action” regarding monitoring outcomes after treatment – there is great need to determine the durability of TMS response. | Added to the Discussion: “In summary, rTMS represents a wide spectrum of treatments, many variations of which are still not well-studied. The specific LHF-DLPFC protocols cleared by the FDA have the strongest evidence of efficacy, with response and remission rates that are at least as good or better than those in the third and fourth acute treatment steps in the STAR*D trial, as well as of improvements in quality of life, and no major safety concerns have been uncovered. However, nearly all of this evidence was developed in experimental settings. Also, decisions to use rTMS must be weighed by consideration of the uncertainty about the maintenance of its benefits beyond the first 4-6 weeks of treatment and of the potential difficulty of implementing a 5-day per week intervention. The current VA/DoD Clinical Practice Guidelines (2009) support ECT as the recommended somatic treatment strategy for patients who have failed multiple other treatment strategies on management of Major Depressive Disorder and does not address rTMS.101 Since the sections of the 2009 VA/DoD CPG on MDD management appear outdated in their statement that TMS is not FDA-approved, we suggest the VA/DoD update the CPG to consider the two FDA clearances and the AHRQ findings of high-strength evidence about rTMs' acute efficacy that have emerged since 2009. In the meantime, rTMS has acceptable acute efficacy, and, compared to ECT, rTMS is less invasive, has a safety advantage for some patients, and may have more comparable benefits in TRD patients than originally thought.” Also added to the list of recommended objectives for future research. “As there is a great need to determine the durability of rTMS response, monitoring of outcomes after treatment should be included in this effort.”
6. Please provide any recommendations on how this report can be revised to more directly address or assist implementation needs.
1 | See below. I would be glad to re-review if that would help.
2 | Unsure.
3 | None come to mind

### LIST OF STUDIES EXCLUDED AFTER FULL-TEXT REVIEW

1 Abraham G, Milev R, Lazowski L, Jokic R, du Toit R, Lowe A. (2007). Repetitive transcranial magnetic stimulation for treatment of elderly patients with depression--An open label trial. Neuropsychiatric Disease and Treatment.
2 Alino JJL-I, Jimenez JLP, Flores SC, Alcocer MIL-I. (2010). Efficacy of transcranial magnetic stimulation (TMS) in depression: naturalistic study. Actas Esp Psiquiatr.
3 Anderson BS, Kavanagh K, Borckardt JJ, et al. (2009). Decreasing procedural pain over time of left prefrontal rTMS for depression: initial results from the open-label phase of a multi-site trial (OPT-TMS). Brain Stimul.
4 Anderson IM, Delvai NA, Ashim B, et al. (2007). Adjunctive fast repetitive transcranial magnetic stimulation in depression. Br J Psychiatry.
5 Andreasson K, Liest V, Lunde M, et al. (2010). Identifying patients with therapy-resistant depression by using factor analysis. Pharmacopsychiatry.
6 Arns M, Drinkenburg WH, Fitzgerald PB, Kenemans JL. (2012). Neurophysiological predictors of non-response to rTMS in depression. Brain Stimul.
7 Avery DH, Claypoole K, Robinson L, et al. (1999). Repetitive transcranial magnetic stimulation in the treatment of medication-resistant depression: preliminary data. Journal of Nervous & Mental Disease.
8 Avery DH, Holtzheimer PE, Fawaz W, et al. (2006). A controlled study of repetitive transcranial magnetic stimulation in medication-resistant major depression. Biol Psychiatry.
9 Avery DH, Holtzheimer PE, Fawaz W, et al. (2007). Transcranial magnetic stimulation reduces pain in patients with major depression: a sham-controlled study. J Nerv Ment Dis.
10 Avery DH, Isenberg KE, Sampson SM, et al. (2008). Transcranial magnetic stimulation in the acute treatment of major depressive disorder: clinical response in an open-label extension trial. J Clin Psychiatry.
11 Baeken C, De Raedt R, Santermans L, et al. (2010). HF-rTMS treatment decreases psychomotor retardation in medication-resistant melancholic depression. Prog Neuropsychopharmacol Biol Psychiatry.
12 Baeken C, De Raedt R, Van Hove C, Clerinx P, De Mey J, Bossuyt A. (2009). HF-rTMS treatment in medication-resistant melancholic depression: results from 18FDG-PET brain imaging. Cns Spectrums.
13 Baeken C, De Raedt R, Vanderhasselt M-A, et al. (2010). A “hypersensitive” hypothalamic-pituitary-adrenal system could be indicative for a negative clinical high-frequency repetitive transcranial magnetic stimulation outcome in melancholic depressed patients. Brain Stimul.
14 Baeken C, Vanderhasselt M, Remue J, et al. (2013). Intensive HF-rTMS treatment in refractory medication-resistant unipolar depressed patients. J Affect Disord.
15 Bares M, Kopecek M, Novak T, et al. (2009). Low frequency (1-Hz), right prefrontal repetitive transcranial magnetic stimulation (rTMS) compared with venlafaxine ER in the treatment of resistant depression: a double-blind, single-centre, randomized study. J Affect Disord.
16 Bartuli E, Kolbinger HM, Hoflich G, Hufnagel A. (1995). Transcranial magnetic stimulation (TMS) in the treatment of depressive disorder. Pharmacopsychiatry.
17 Berlim MT, McGirr A, Beaulieu M-M, Turecki G. (2011). High frequency repetitive transcranial magnetic stimulation as an augmenting strategy in severe treatment-resistant major depression: a prospective 4-week naturalistic trial. J Affect Disord.
18 Berlim MT, McGirr A, Beaulieu M-M, Van den Eynde F, Turecki G. (2013). Are neuroticism and extraversion associated with the antidepressant effects of repetitive transcranial magnetic stimulation (rTMS)? An exploratory 4-week trial. Neurosci Lett.
19 Berlim MT, Van den Eynde F, Daskalakis ZJ. (2013). High-frequency repetitive transcranial magnetic stimulation accelerates and enhances the clinical response to antidepressants in major depression: a meta-analysis of randomized, double-blind, and sham-controlled trials. J Clin Psychiatry.
20 Berman RM, Narasimhan M, Sanacora G, et al. (2000). A randomized clinical trial of repetitive transcranial magnetic stimulation in the treatment of major depression. Biol Psychiatry.
21 Blumberger DM, Mulsant BH, Daskalakis ZJ. (2013). What is the role of brain stimulation therapies in the treatment of depression. Curr Psychiatry Rep.
22 Blumberger DM, Mulsant BH, Fitzgerald PB, et al. (2012). A randomized double-blind sham-controlled comparison of unilateral and bilateral repetitive transcranial magnetic stimulation for treatment-resistant major depression. World Journal of Biological Psychiatry.
23 Bocchio-Chiavetto L, Miniussi C, Zanardini R, et al. (2008). 5-HTTLPR and BDNF Val66Met polymorphisms and response to rTMS treatment in drug resistant depression. Neurosci Lett.
24 Boggio PS, Fregni F, Bermpohl F, et al. (2005). Effect of repetitive TMS and fluoxetine on cognitive function in patients with Parkinson's disease and concurrent depression. Mov Disord.
25 Borckardt JJ, Nahas ZH, Teal J, et al. (2013). The painfulness of active, but not sham, transcranial magnetic stimulation decreases rapidly over time: Results from the double-blind phase of the OPT-TMS trial. Brain Stimul.
26 Bortolomasi M, Minelli A, Fuggetta G, et al. (2007). Long-lasting effects of high frequency repetitive transcranial magnetic stimulation in major depressed patients. Psychiatry Res.
27 Boutros NN, Gueorguieva R, Hoffman RE, Oren DA, Feingold A, Berman RM. (2002). Lack of a therapeutic effect of a 2-week sub-threshold transcranial magnetic stimulation course for treatment-resistant depression. Psychiatry Res.
28 Brakemeier E-L, Luborzewski A, Danker-Hopfe H, Kathmann N, Bajbouj M. (2007). Positive predictors for antidepressive response to prefrontal repetitive transcranial magnetic stimulation (rTMS). J Psychiatr Res.
29 Brakemeier E-L, Wilbertz G, Rodax S, et al. (2008). Patterns of response to repetitive transcranial magnetic stimulation (rTMS) in major depression: replication study in drug-free patients. J Affect Disord.
30 Bretlau LG, Lunde M, Lindberg L, Unden M, Dissing S, Bech P. (2008). Repetitive transcranial magnetic stimulation (rTMS) in combination with escitalopram in patients with treatment-resistant major depression: a double-blind, randomised, sham-controlled trial. Pharmacopsychiatry.
31 Carretero B, Martin MJ, Juan A, et al. (2009). Low-frequency transcranial magnetic stimulation in patients with fibromyalgia and major depression. Pain Med.
32 Charnsil C, Suttajit S, Boonyanaruthee V, Leelarphat S. (2012). An open-label study of adjunctive repetitive transcranial magnetic stimulation (rTMS) for partial remission in major depressive disorder. International Journal of Psychiatry in Clinical Practice.
33 Charnsil C, Suttajit S, Boonyanaruthee V, Leelarphat S. (2012). Twelve-month, prospective, open-label study of repetitive transcranial magnetic stimulation for major depressive disorder in partial remission. Neuropsychiatric Disease and Treatment.
34 Chen J, Zhou C, Wu B, et al. (2013). Left versus right repetitive transcranial magnetic stimulation in treating major depression: A meta-analysis of randomised controlled trials. Psychiatry Res.
35 Chen S, Chang C, Tsai H, Chen S, Lin CCH. (2013). Superior antidepressant effect occurring 1 month after rTMS: Add-on rTMS for subjects with medication-resistant depression. Neuropsychiatric Disease and Treatment.
36 Chistyakov AV, Kaplan B, Rubichek O, et al. (2005). Antidepressant effects of different schedules of repetitive transcranial magnetic stimulation vs. clomipramine in patients with major depression: relationship to changes in cortical excitability. Int J Neuropsychopharmacol.
37 Chistyakov AV, Kaplan B, Rubichek O, et al. (2005). Effect of electroconvulsive therapy on cortical excitability in patients with major depression: a transcranial magnetic stimulation study. Clin Neurophysiol.
38 Chistyakov AV, Rubicsek O, Kaplan B, Zaaroor M, Klein E. (2010). Safety, tolerability and preliminary evidence for antidepressant efficacy of theta-burst transcranial magnetic stimulation in patients with major depression. Int J Neuropsychopharmacol.
39 Ciobanu C, Girard M, Marin B, Labrunie A, Malauzat D. (2013). rTMS for pharmacoresistant major depression in the clinical setting of a psychiatric hospital: Effectiveness and effects of age. J Affect Disord.
40 Cme Institute of Physicians Postgraduate Press I. (2007). Transcranial magnetic stimulation: potential new treatment for resistant depression. J Clin Psychiatry.
41 Cohen RB, Brunoni AR, Boggio PS, Fregni F. (2010). Clinical predictors associated with duration of repetitive transcranial magnetic stimulation treatment for remission in bipolar depression: a naturalistic study. Journal of Nervous & Mental Disease.
42 Conca A, Koppi S, Konig P, Swoboda E, Krecke N. (1996). Transcranial magnetic stimulation: a novel antidepressive strategy. Neuropsychobiology.
43 Conca A, Swoboda E, Konig P, et al. (2000). Clinical impacts of single transcranial magnetic stimulation (sTMS) as an add-on therapy in severely depressed patients under SSRI treatment. Human Psychopharmacology: Clinical and Experimental.
44 Couturier JL. (2005). Efficacy of rapid-rate repetitive transcranial magnetic stimulation in the treatment of depression: a systematic review and meta-analysis. Journal of Psychiatry & Neuroscience.
45 Cristancho MA, Helmer A, Connolly R, Cristancho P, O'Reardon JP. (2013). Transcranial magnetic stimulation maintenance as a substitute for maintenance electroconvulsive therapy: a case series. J ECT.
46 Dell'Osso B, Camuri G, Castellano F, et al. (2011). Meta-review of metanalytic studies with repetitive transcranial magnetic stimulation (rTMS) for the treatment of Major Depression. Clinical Practice and Epidemiology in Mental Health.
47 Dell'Osso B, Mundo E, D'Urso N, et al. (2009). Augmentative repetitive navigated transcranial magnetic stimulation (rTMS) in drug-resistant bipolar depression. Bipolar Disord.
48 Dolberg OT, Dannon PN, Schreiber S, Grunhaus L. (2002). Transcranial magnetic stimulation in patients with bipolar depression: A double blind, controlled study. Bipolar Disord.
49 Downar J, Daskalakis ZJ. (2013). New targets for rTMS in depression: A review of convergent evidence. Brain Stimul.
50 Dumas R, Richieri R, Guedj E, Auquier P, Lancon C, Boyer L. (2012). Improvement of health-related quality of life in depression after transcranial magnetic stimulation in a naturalistic trial is associated with decreased perfusion in precuneus. Health & Quality of Life Outcomes.
51 Ebmeier KP. (2002). Transcranial magnetic stimulation and neuroimaging. Bipolar Disord.
52 Ebmeier KP, Herrmann LL. (2008). TMS--the beginning of the end or the end of the beginning. Psychol Med.
53 Epstein CM, Evatt ML, Funk A, et al. (2007). An open study of repetitive transcranial magnetic stimulation in treatment-resistant depression with Parkinson's disease. Clin Neurophysiol.
54 Eranti S, Mogg A, Pluck G, et al. (2007). A randomized, controlled trial with 6-month follow-up of repetitive transcranial magnetic stimulation and electroconvulsive therapy for severe depression. Am J Psychiatry.
55 Eschweiler GW, Wegerer C, Schlotter W, et al. (2000). Left prefrontal activation predicts therapeutic effects of repetitive transcranial magnetic stimulation (rTMS) in major depression. Psychiatry Res.
56 Etribi AE, Nahas NE, Nagy N, Nabil H. (2010). Repetitive transcranial magnetic stimulation treatment in post-stroke depression. Current Psychiatry.
57 Fabre I, Galinowski A, Oppenheim C, et al. (2004). Antidepressant efficacy and cognitive effects of repetitive transcranial magnetic stimulation in vascular depression: an open trial. Int J Geriatr Psychiatry.
58 Feinsod M, Kreinin B, Chistyakov A, Klein E. (1998). Preliminary evidence for a beneficial effect of low-frequency, repetitive transcranial magnetic stimulation in patients with major depression and schizophrenia. Depression & Anxiety.
59 Fink M. (2011). Transcranial magnetic stimulation is not a replacement for electroconvulsive therapy in depressive mood disorders. J ECT.
60 Fitzgerald P. (2003). Is it time to introduce repetitive transcranial magnetic stimulation into standard clinical practice for the treatment of depressive disorders. Australian & New Zealand Journal of Psychiatry.
61 Fitzgerald P. (2004). Repetitive transcranial magnetic stimulation and electroconvulsive therapy: complementary or competitive therapeutic options in depression. Australasian Psychiatry.
62 Fitzgerald P. (2008). Brain stimulation techniques for the treatment of depression and other psychiatric disorders. Australasian Psychiatry.
63 Fitzgerald PB. (2008). A randomized-controlled trial of bilateral rTMS for treatment-resistant depression. Progress in Neurotherapeutics and Neuropsychopharmacology.
64 Fitzgerald PB, Benitez J, de Castella A, Daskalakis ZJ, Brown TL, Kulkarni J. (2006). A randomized, controlled trial of sequential bilateral repetitive transcranial magnetic stimulation for treatment-resistant depression. Am J Psychiatry.
65 Fitzgerald PB, Daskalakis ZJ. (2012). A practical guide to the use of repetitive transcranial magnetic stimulation in the treatment of depression. Brain Stimul.
66 Fitzgerald PB, Hoy KE, Herring SE, et al. (2012). A double blind randomized trial of unilateral left and bilateral prefrontal cortex transcranial magnetic stimulation in treatment resistant major depression. J Affect Disord.
67 Fitzgerald PB, McQueen S, Herring S, et al. (2009). A study of the effectiveness of high-frequency left prefrontal cortex transcranial magnetic stimulation in major depression in patients who have not responded to right-sided stimulation. Psychiatry Res.
68 Frank E, Eichhammer P, Burger J, et al. (2011). Transcranial magnetic stimulation for the treatment of depression: Feasibility and results under naturalistic conditions: A retrospective analysis. Archiv fur Psychiatrie und Nervenkrankheiten, European Archives of Psychiatry & Neurological Sciences.
69 Fregni F, Santos CM, Myczkowski ML, et al. (2004). Repetitive transcranial magnetic stimulation is as effective as fluoxetine in the treatment of depression in patients with Parkinson's disease. Journal of Neurology, Neurosurgery & Psychiatry.
70 Fujita K, Koga Y. (2005). Clinical application of single-pulse transcranial magnetic stimulation for the treatment of depression. Psychiatry & Clinical Neurosciences.
71 Garcia-Anaya M, Gonzilez-Olvera J, Ricardo-Garcell J, et al. (2011). Clinical and electrophysiological effect of right and left repetitive transcranial magnetic stimulation in patients with major depressive disorder. Salud Mental.
72 Garcia-Toro M, Mayol A, Arnillas H, et al. (2001). Modest adjunctive benefit with transcranial magnetic stimulation in medication-resistant depression. J Affect Disord.
73 Garcia-Toro M, Pascual-Leone A, Romera M, et al. (2001). Prefrontal repetitive transcranial magnetic stimulation as add on treatment in depression. Journal of Neurology, Neurosurgery & Psychiatry.
74 Gedge L, Beaudoin A, Lazowski L, duToit R, Jokic R, Milev R. (2012). Effects of electroconvulsive therapy and repetitive transcranial magnetic stimulation on serum brain-derived neurotrophic factor levels in patients with depression. Frontiers in Psychiatry.
75 George MS. (2006). Transcranial magnetic stimulation: a stimulating new method for treating depression, but saddled with the same old problems. Int J Neuropsychopharmacol.
76 George MS, Wassermann EM, Kimbrell TA, et al. (1997). Mood improvement following daily left prefrontal repetitive transcranial magnetic stimulation in patients with depression: a placebo-controlled crossover trial. Am J Psychiatry.
77 George MS, Wassermann EM, Williams WA, et al. (1995). Daily repetitive transcranial magnetic stimulation (rTMS) improves mood in depression. NeuroReport: For Rapid Communication of Neuroscience Research.
78 Gershon AA, Dannon PN, Grunhaus L. (2003). Transcranial magnetic stimulation in the treatment of depression. Am J Psychiatry.
79 Grunhaus L, Dannon PN, Schreiber S, et al. (2000). Repetitive transcranial magnetic stimulation is as effective as electroconvulsive therapy in the treatment of nondelusional major depressive disorder: an open study. Biol Psychiatry.
80 Grunhaus L, Dolberg OT, Polak D, Dannon PN. (2002). Monitoring the response to rTMS in depression with visual analog scales. Hum Psychopharmacol.
81 Grunhaus L, Schreiber S, Dolberg OT, Polak D, Dannon PN. (2003). A randomized controlled comparison of electroconvulsive therapy and repetitive transcranial magnetic stimulation in severe and resistant nonpsychotic major depression. Biol Psychiatry.
82 Hadley D, Anderson BS, Borckardt JJ, et al. (2011). Safety, tolerability, and effectiveness of high doses of adjunctive daily left prefrontal repetitive transcranial magnetic stimulation for treatment-resistant depression in a clinical setting. J ECT.
83 Hansen PE, Ravnkilde B, Videbech P, et al. (2011). Low-frequency repetitive transcranial magnetic stimulation inferior to electroconvulsive therapy in treating depression. J ECT.
84 Hansen PEB, Videbech P, Clemmensen K, Sturlason R, Jensen HM, Vestergaard P. (2004). Repetitive transcranial magnetic stimulation as add-on antidepressant treatment. The applicability of the method in a clinical setting. Nord J Psychiatry.
85 Harel EV, Zangen A, Roth Y, Reti I, Braw Y, Levkovitz Y. (2011). H-Coil repetitive transcranial magnetic stimulation for the treatment of bipolar depression: An add-on, safety and feasibility study. The World Journal of Biological Psychiatry.
86 Hausmann A, Kemmler G, Walpoth M, et al. (2004). No benefit derived from repetitive transcranial magnetic stimulation in depression: a prospective, single centre, randomised, double blind, sham controlled “add on” trial. Journal of Neurology Neurosurgery & Psychiatry.
87 Hausmann A, Pascual-Leone A, Kemmler G, et al. (2004). No deterioration of cognitive performance in an aggressive unilateral and bilateral antidepressant rTMS add-on trial. J Clin Psychiatry.
88 He M, Gu Z, Wang X, Tian X. (2009). Effects of repetitive transcranial magnetic stimulation on hypothalamic-pituitary-adrenal axis of patients with depression. Journal of Medical Colleges of PLA.
89 He M-L, Gu Z-T, Wang X-Y, Shi H-P. (2011). Treatment of depression using sleep electroencephalogram modulated repetitive transcranial magnetic stimulation. Chin Med J (Engl).
90 Herbsman T, Avery D, Ramsey D, et al. (2009). More lateral and anterior prefrontal coil location is associated with better repetitive transcranial magnetic stimulation antidepressant response. Biol Psychiatry.
91 Hernandez-Ribas R, Deus J, Pujol J, et al. (2013). Identifying brain imaging correlates of clinical response to repetitive transcranial magnetic stimulation (rTMS) in major depression. Brain Stimul.
92 Herrmann LL, Ebmeier KP. (2006). Factors modifying the efficacy of transcranial magnetic stimulation in the treatment of depression: a review. J Clin Psychiatry.
93 Herwig U, Fallgatter AJ, Hoppner J, et al. (2007). Antidepressant effects of augmentative transcranial magnetic stimulation: randomised multicentre trial. Br J Psychiatry.
94 Herwig U, Lampe Y, Juengling FD, et al. (2003). Add-on rTMS for treatment of depression: a pilot study using stereotaxic coil-navigation according to PET data. J Psychiatr Res.
95 Hoeppner J, Padberg F, Domes G, et al. (2010). Influence of repetitive transcranial magnetic stimulation on psychomotor symptoms in major depression. European Archives of Psychiatry & Clinical Neuroscience.
96 Hofich G, Kasper S, Hufnagel A, Moller HJ. (1992). Transcranial magnetic stimulation versus electroconvulsive therapy in major depression. Pharmacopsychiatry.
97 Holtzheimer PE, McDonald WM, Mufti M, et al. (2010). Accelerated repetitive transcranial magnetic stimulation for treatment-resistant depression. Depress Anxiety.
98 Holtzheimer PE, Russo J, Avery DH. (2001). A meta-analysis of repetitive transcranial magnetic stimulation in the treatment of depression. Psychopharmacol Bull.
99 Holtzheimer PE, Russo J, Claypoole KH, Roy-Byrne P, Avery DH. (2004). Shorter duration of depressive episode may predict response to repetitive transcranial magnetic stimulation. Depress Anxiety.
100 Hoppner J, Schulz M, Irmisch G, Mau R, Schlafke D, Richter J. (2003). Antidepressant efficacy of two different rTMS procedures. High frequency over left versus low frequency over right prefrontal cortex compared with sham stimulation. European Archives of Psychiatry & Clinical Neuroscience.
101 Horvath JC, Perez JM, Forrow L, Fregni F, PascualLeone A. (2011). Transcranial magnetic stimulation: A historical evaluation and future prognosis of therapeutically relevant ethical concerns. Journal of Medical Ethics: Journal of the Institute of Medical Ethics.
102 Hovington CL, McGirr A, Lepage M, Berlim MT. (2013). Repetitive transcranial magnetic stimulation (rTMS) for treating major depression and schizophrenia: a systematic review of recent meta-analyses. Ann Med.
103 Hoy KE, Segrave RA, Daskalakis ZJ, Fitzgerald PB. (2012). Investigating the relationship between cognitive change and antidepressant response following rTMS: a large scale retrospective study. Brain Stimul.
104 Huang C, Wei I, Chou Y, Su T. (2008). Effect of age, gender, menopausal status, and ovarian hormonal level on rTMS in treatment-resistant depression. Psychoneuroendocrinology.
105 Isserles M, Rosenberg O, Dannon P, et al. (2011). Cognitive-emotional reactivation during deep transcranial magnetic stimulation over the prefrontal cortex of depressive patients affects antidepressant outcome. J Affect Disord.
106 Janicak PG, Dowd SM, Martis B, et al. (2002). Repetitive transcranial magnetic stimulation versus electroconvulsive therapy for major depression: preliminary results of a randomized trial. Biol Psychiatry.
107 Janicak PG, Dowd SM, Strong MJ, Alam D, Beedle D. (2005). The Potential Role of Repetitive Transcranial Magnetic Stimulation in Treating Severe Depression. Psychiatric Annals.
108 Janicak PG, Dunner DL, Aaronson ST, et al. (2013). Transcranial magnetic stimulation (TMS) for major depression: a multisite, naturalistic, observational study of quality of life outcome measures in clinical practice. Cns Spectrums.
109 Janicak PG, O'Reardon JP, Sampson SM, et al. (2008). Transcranial magnetic stimulation in the treatment of major depressive disorder: a comprehensive summary of safety experience from acute exposure, extended exposure, and during reintroduction treatment. J Clin Psychiatry.
110 Jin Y, Phillips B. (2014). A pilot study of the use of EEG-based synchronized Transcranial Magnetic Stimulation (sTMS) for treatment of Major Depression. BMC Psychiatry.
111 Johnson KA, Baig M, Ramsey D, et al. (2013). Prefrontal rTMS for treating depression: location and intensity results from the OPT-TMS multi-site clinical trial. Brain Stimul.
112 Jorge RE, Moser DJ, Acion L, Robinson RG. (2008). Treatment of vascular depression using repetitive transcranial magnetic stimulation. Arch Gen Psychiatry.
113 Jorge RE, Robinson RG, Tateno A, et al. (2004). Repetitive transcranial magnetic stimulation as treatment of poststroke depression: a preliminary study. Biol Psychiatry.
114 Kauffmann CD, Cheema MA, Miller BE. (2004). Slow right prefrontal transcranial magnetic stimulation as a treatment for medication-resistant depression: a double-blind, placebo-controlled study. Depress Anxiety.
115 Keshtkar M, Ghanizadeh A, Firoozabadi A. (2011). Repetitive transcranial magnetic stimulation versus electroconvulsive therapy for the treatment of major depressive disorder, a randomized controlled clinical trial. J ECT.
116 Kim BR, Kim DY, Chun MH, Yi JH, Kwon JS. (2010). Effect of repetitive transcranial magnetic stimulation on cognition and mood in stroke patients: a double-blind, sham-controlled trial. American Journal of Physical Medicine & Rehabilitation / Association of Academic Physiatrists.
117 Kimbrell TA, Little JT, Dunn RT, et al. (1999). Frequency dependence of antidepressant response to left prefrontal repetitive transcranial magnetic stimulation (rTMS) as a function of baseline cerebral glucose metabolism. Biol Psychiatry.
118 Kito S, Fujita K, Koga Y. (2008). Regional cerebral blood flow changes after low-frequency transcranial magnetic stimulation of the right dorsolateral prefrontal cortex in treatment-resistant depression. Neuropsychobiology.
119 Kito S, Hasegawa T, Koga Y. (2012). Cerebral blood flow ratio of the dorsolateral prefrontal cortex to the ventromedial prefrontal cortex as a potential predictor of treatment response to transcranial magnetic stimulation in depression. Brain Stimul.
120 Kito S, Hasegawa T, Koga Y. (2012). Cerebral blood flow in the ventromedial prefrontal cortex correlates with treatment response to low-frequency right prefrontal repetitive transcranial magnetic stimulation in the treatment of depression. Psychiatry & Clinical Neurosciences.
121 Klein E, Kreinin I, Chistyakov A, et al. (1999). Therapeutic efficacy of right prefrontal slow repetitive transcranial magnetic stimulation in major depression: a double-blind controlled study. Arch Gen Psychiatry.
122 Knapp M, Romeo R, Mogg A, et al. (2008). Cost-effectiveness of transcranial magnetic stimulation vs. electroconvulsive therapy for severe depression: a multi-centre randomised controlled trial. J Affect Disord.
123 Kolbinger HM, Hoflich G, Hufnagel A, Muller H, Kasper S. (1995). Transcranial magnetic stimulation (TMS) in the treatment of major depression: A pilot study. Human Psychopharmacology: Clinical and Experimental.
124 Kozel FA, George MS. (2002). Meta-analysis of left prefrontal repetitive transcranial magnetic stimulation (rTMS) to treat depression. Journal of Practical Psychiatry and Behavioral Health.
125 Kozel FA, Nahas Z, deBrux C, et al. (2000). How coil-cortex distance relates to age, motor threshold, and antidepressant response to repetitive transcranial magnetic stimulation. J Neuropsychiatry Clin Neurosci.
126 Lam RW, Chan P, Wilkins-Ho M, Yatham LN. (2008). Repetitive transcranial magnetic stimulation for treatment-resistant depression: a systematic review and metaanalysis. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie.
127 Langguth B, Wiegand R, Kharraz A, et al. (2007). Pre-treatment anterior cingulate activity as a predictor of antidepressant response to repetitive transcranial magnetic stimulation (rTMS). Neuroendocrinology Letters.
128 Levkovitz Y, Harel EV, Roth Y, et al. (2009). Deep transcranial magnetic stimulation over the prefrontal cortex: evaluation of antidepressant and cognitive effects in depressive patients. Brain Stimul.
129 Levkovitz Y, Sheer A, Harel EV, et al. (2011). Differential effects of deep TMS of the prefrontal cortex on apathy and depression. Brain Stimul.
130 Lipsman N, Sankar T, Downar J, Kennedy SH, Lozano AM, Giacobbe P. (2014). Neuromodulation for treatment-refractory major depressive disorder. CMAJ Canadian Medical Association Journal.
131 Lisanby SH, Husain MM, Rosenquist PB, et al. (2009). Daily left prefrontal repetitive transcranial magnetic stimulation in the acute treatment of major depression: clinical predictors of outcome in a multisite, randomized controlled clinical trial. Neuropsychopharmacology.
132 Little JT, Kimbrell TA, Wassermann EM, et al. (2000). Cognitive effects of 1- and 20-hertz repetitive transcranial magnetic stimulation in depression: preliminary report. Neuropsychiatry, Neuropsychology, & Behavioral Neurology.
133 Liu AY, Rajji TK, Blumberger DM, Daskalakis ZJ, Mulsant BH. (2014). Brain stimulation in the treatment of late-life severe mental illness other than unipolar nonpsychotic depression. The American Journal of Geriatric Psychiatry.
134 Loo C, Mitchell P, Sachdev P, McDarmont B, Parker G, Gandevia S. (1999). Double-blind controlled investigation of transcranial magnetic stimulation for the treatment of resistant major depression. Am J Psychiatry.
135 Loo CK, McFarquhar TF, Mitchell PB. (2008). A review of the safety of repetitive transcranial magnetic stimulation as a clinical treatment for depression. Int J Neuropsychopharmacol.
136 Loo CK, Mitchell PB, Croker VM, et al. (2003). Double-blind controlled investigation of bilateral prefrontal transcranial magnetic stimulation for the treatment of resistant major depression. Psychol Med.
137 Loo CK, Mitchell PB, McFarquhar TF, Malhi GS, Sachdev PS. (2007). A sham-controlled trial of the efficacy and safety of twice-daily rTMS in major depression. Psychol Med.
138 Lowe A, Rajaratnam SMW, Hoy K, Taffe J, Fitzgerald PB. (2013). Can sleep disturbance in depression predict repetitive transcranial magnetic stimulation (rTMS) treatment response?. Psychiatry Res.
139 Luborzewski A, Schubert F, Seifert F, et al. (2007). Metabolic alterations in the dorsolateral prefrontal cortex after treatment with high-frequency repetitive transcranial magnetic stimulation in patients with unipolar major depression. J Psychiatr Res.
140 Mantovani A, Aly M, Dagan Y, Allart A, Lisanby SH. (2013). Randomized sham controlled trial of repetitive transcranial magnetic stimulation to the dorsolateral prefrontal cortex for the treatment of panic disorder with comorbid major depression. J Affect Disord.
141 Martis B, Alam D, Dowd SM, et al. (2003). Neurocognitive effects of repetitive transcranial magnetic stimulation in severe major depression. Clin Neurophysiol.
142 McDonald WM, Durkalski V, Ball ER, et al. (2011). Improving the antidepressant efficacy of transcranial magnetic stimulation: maximizing the number of stimulations and treatment location in treatment-resistant depression. Depression & Anxiety.
143 McLoughlin DM, Mogg A, Eranti S, et al. (2007). The clinical effectiveness and cost of repetitive transcranial magnetic stimulation versus electroconvulsive therapy in severe depression: a multicentre pragmatic randomised controlled trial and economic analysis. Health Technol Assess.
144 McNamara B, Ray JL, Arthurs OJ, Boniface S. (2001). Transcranial magnetic stimulation for depression and other psychiatric disorders. Psychol Med.
145 Menkes DL, Bodnar P, Ballesteros RA, Swenson MR. (1999). Right frontal lobe slow frequency repetitive transcranial magnetic stimulation (SF r-TMS) is an effective treatment for depression: a case-control pilot study of safety and efficacy. Journal of Neurology, Neurosurgery & Psychiatry.
146 Micoulaud-Franchi J-A, Richieri R, Cermolacce M, Loundou A, Lancon C, Vion-Dury J. (2012). Parieto-temporal alpha EEG band power at baseline as a predictor of antidepressant treatment response with repetitive Transcranial Magnetic Stimulation: a preliminary study. J Affect Disord.
147 Milev R, Abraham G, Hasey G, Cabaj JL. (2009). Repetitive transcranial magnetic stimulation for treatment of medication-resistant depression in older adults: a case series. J ECT.
148 Minichino A, Bersani FS, Capra E, et al. (2012). ECT, rTMS, and deepTMS in pharmacoresistant drug-free patients with unipolar depression: A comparative review. Neuropsychiatric Disease and Treatment.
149 Miniussi C, Bonato C, Bignotti S, et al. (2005). Repetitive transcranial magnetic stimulation (rTMS) at high and low frequency: an efficacious therapy for major drug-resistant depression. Clin Neurophysiol.
150 Mogg A, Pluck G, Eranti SV, et al. (2008). A randomized controlled trial with 4-month follow-up of adjunctive repetitive transcranial magnetic stimulation of the left prefrontal cortex for depression. Psychol Med.
151 Moller AL, Hjaltason O, Ivarsson O, Stefansson SB. (2006). The effects of repetitive transcranial magnetic stimulation on depressive symptoms and the P(300) event-related potential. Nord J Psychiatry.
152 Moreines JL, McClintock SM, Holtzheimer PE. (2011). Neuropsychologic effects of neuromodulation techniques for treatment-resistant depression: A review. Brain Stimul.
153 Moser DJ, Jorge RE, Manes F, Paradiso S, Benjamin ML, Robinson RG. (2002). Improved executive functioning following repetitive transcranial magnetic stimulation. Neurology.
154 Myczkowski ML, Dias AM, Luvisotto T, et al. (2012). Effects of repetitive transcranial magnetic stimulation on clinical, social, and cognitive performance in postpartum depression. Neuropsychiatric Disease and Treatment.
155 Nahas Z, Anderson BS. (2011). Brain stimulation therapies for mood disorders: The continued necessity of electroconvulsive therapy. Journal of the American Psychiatric Nurses Association.
156 Nahas Z, Kozel FA, Li X, Anderson B, George MS. (2003). Left prefrontal transcranial magnetic stimulation (TMS) treatment of depression in bipolar affective disorder: a pilot study of acute safety and efficacy. Bipolar Disord.
157 Nemeroff CB. (1996). Augmentation strategies in patients with refractory depression. Depression & Anxiety.
158 Noda Y, Daskalakis ZJ, Ramos C, Blumberger DM. (2013). Repetitive transcranial magnetic stimulation to maintain treatment response to electroconvulsive therapy in depression: A case series. Frontiers in Psychiatry.
159 Nongpiur A, Sinha VK, Praharaj SK, Goyal N. (2011). Theta-patterned, frequency-modulated priming stimulation enhances low-frequency, right prefrontal cortex repetitive transcranial magnetic stimulation (rTMS) in depression: A randomized, sham-controlled study. J Neuropsychiatry Clin Neurosci.
160 O'Connor M, Brenninkmeyer C, Morgan A, et al. (2003). Relative effects of repetitive transcranial magnetic stimulation and electroconvulsive therapy on mood and memory: a neurocognitive risk-benefit analysis. Cogn Behav Neurol.
161 O'Connor MG, Jerskey BA, Robertson EM, Brenninkmeyer C, Ozdemir E, Leone AP. (2005). The effects of repetitive transcranial magnetic stimulation (rTMS) on procedural memory and dysphoric mood in patients with major depressive disorder. Cognitive & Behavioral Neurology.
162 Padberg F, Zwanzger P, Thoma H, et al. (1999). Repetitive transcranial magnetic stimulation (rTMS) in pharmacotherapy-refractory major depression: comparative study of fast, slow and sham rTMS. Psychiatry Res.
163 Pallanti S, Bernardi S, Di Rollo A, Antonini S, Quercioli L. (2010). Unilateral low frequency versus sequential bilateral repetitive transcranial magnetic stimulation: is simpler better for treatment of resistant depression. Neuroscience.
164 Pallanti S, Di Rollo A, Antonini S, Cauli G, Hollander E, Quercioli L. (2012). Low-frequency rTMS over right dorsolateral prefrontal cortex in the treatment of resistant depression: cognitive improvement is independent from clinical response, resting motor threshold is related to clinical response. Neuropsychobiology.
165 Pascual-Leone A, Rubio B, Pallardo F, Catala MD. (1996). Rapid-rate transcranial magnetic stimulation of left dorsolateral prefrontal cortex in drug-resistant depression. Lancet.
166 Pellicciari MC, Cordone S, Marzano C, et al. (2013). Dorsolateral prefrontal transcranial magnetic stimulation in patients with major depression locally affects alpha power of REM sleep. Frontiers in Human Neuroscience.
167 Polley KH, Navarro R, Avery DH, George MS, Holtzheimer PE. (2011). 2010 updated Avery-George-Holtzheimer Database of rTMS depression studies. Brain Stimul.
168 Poulet E, Brunelin J, Boeuve C, et al. (2004). Repetitive transcranial magnetic stimulation does not potentiate antidepressant treatment. European Psychiatry: the Journal of the Association of European Psychiatrists.
169 Pridmore S. (2000). Substitution of rapid transcranial magnetic stimulation treatments for electroconvulsive therapy treatments in a course of electroconvulsive therapy. Depress Anxiety.
170 Pridmore S, Bruno R, TurnierShea Y, Reid P, Rybak M. (2000). Comparison of unlimited numbers of rapid transcranial magnetic stimulation (rTMS) and ECT treatment sessions in major depressive episode. Int J Neuropsychopharmacol.
171 Pridmore S, Rybak M, TurnierShea Y, Reid P, Bruno PR, Couper D. (1999). A naturalistic study of response in melancholia to transcranial magnetic stimulation (TMS). German Journal of Psychiatry.
172 Rasmussen KG. (2008). Electroconvulsive therapy versus transcranial magnetic stimulation for major depression: A review with recommendations for future research. Acta Neuropsychiatrica.
173 Ray S, Nizamie SH, Akhtar S, Praharaj SK, Mishra BR, ZiaulHaq M. (2011). Efficacy of adjunctive high frequency repetitive transcranial magnetic stimulation of left prefrontal cortex in depression: A randomized sham controlled study. J Affect Disord.
174 Reti IM. (2013). A rational insurance coverage policy for repetitive transcranial magnetic stimulation for major depression. J ECT.
175 Richieri R, Guedj E, Michel P, et al. (2013). Maintenance transcranial magnetic stimulation reduces depression relapse: A propensity-adjusted analysis. J Affect Disord.
176 Rodriguez-Martin LJ, Barbanoj MJ, Schlaepfer TE, et al. (2009). Transcranial magnetic stimulation for treating depression. Cochrane Database Syst Rev.
177 Rosa MA, Gattaz WF, Pascual-Leone A, et al. (2006). Comparison of repetitive transcranial magnetic stimulation and electroconvulsive therapy in unipolar non-psychotic refractory depression: a randomized, single-blind study. Int J Neuropsychopharmacol.
178 Rosa MA, Picarelli H, Teixeira MJ, Rosa MO, Marcolin MA. (2006). Accidental Seizure with Repetitive Transcranial Magnetic Stimulation. Convuls Ther.
179 Rosenberg O, Shoenfeld N, Zangen A, Kotler M, Dannon PN. (2010). Deep TMS in a resistant major depressive disorder: a brief report. Depression & Anxiety.
180 Rumi DO, Gattaz WF, Rigonatti SP, et al. (2005). Transcranial magnetic stimulation accelerates the antidepressant effect of amitriptyline in severe depression: a double-blind placebo-controlled study. Biol Psychiatry.
181 Rybak M, Bruno R, TurnierShea Y, Pridmore S. (2005). An Attempt to Increase the Rate and Magnitude of the Antidepressant Effect of Transcranial Magnetic Stimulation (TMS). A Pilot Study. German Journal of Psychiatry.
182 Schiffer F, Glass I, Lord J, Teicher MH. (2008). Prediction of clinical outcomes from rTMS in depressed patients with lateral visual field stimulation: A replication. J Neuropsychiatry Clin Neurosci.
183 Schiffer F, Stinchfield Z, PascualLeone A. (2002). Prediction of clinical response to transcranial magnetic stimulation for depression by baseline lateral visual-field stimulation. Cogn Behav Neurol.
184 Schule C, Zwanzger P, Baghai T, et al. (2003). Effects of antidepressant pharmacotherapy after repetitive transcranial magnetic stimulation in major depression: an open follow-up study. J Psychiatr Res.
185 Schulze-Rauschenbach SC, Harms U, Schlaepfer TE, Maier W, Falkai P, Wagner M. (2005). Distinctive neurocognitive effects of repetitive transcranial magnetic stimulation and electroconvulsive therapy in major depression. Br J Psychiatry.
186 Schutter DJLG. (2009). Antidepressant efficacy of high-frequency transcranial magnetic stimulation over the left dorsolateral prefrontal cortex in double-blind sham-controlled designs: a meta-analysis. Psychol Med.
187 Schutter DJLG. (2010). Quantitative review of the efficacy of slow-frequency magnetic brain stimulation in major depressive disorder. Psychol Med.
188 Schutter DJLG, Laman DM, van Honk J, Vergouwen AC, Koerselman GF. (2009). Partial clinical response to 2 weeks of 2 Hz repetitive transcranial magnetic stimulation to the right parietal cortex in depression. Int J Neuropsychopharmacol.
189 Shajahan PM, Glabus MF, Steele JD, et al. (2002). Left dorso-lateral repetitive transcranial magnetic stimulation affects cortical excitability and functional connectivity, but does not impair cognition in major depression. Prog Neuropsychopharmacol Biol Psychiatry.
190 Simpson KN, Welch MJ, Kozel FA, Demitrack MA, Nahas Z. (2009). Cost-effectiveness of transcranial magnetic stimulation in the treatment of major depression: a health economics analysis. Adv Ther.
191 Slotema CW, Blom JD, Hoek HW, Sommer IEC. (2010). Should we expand the toolbox of psychiatric treatment methods to include Repetitive Transcranial Magnetic Stimulation (rTMS)? A meta-analysis of the efficacy of rTMS in psychiatric disorders. J Clin Psychiatry.
192 Sobis J, Jarzab M, Hese RT, et al. (2010). Therapeutic efficacy assessment of weak variable magnetic fields with low value of induction in patients with drug-resistant depression. J Affect Disord.
193 Speer AM, Benson BE, Kimbrell TK, et al. (2009). Opposite effects of high and low frequency rTMS on mood in depressed patients: relationship to baseline cerebral activity on PET. J Affect Disord.
194 Speer AM, Kimbrell TA, Wassermann EM, et al. (2000). Opposite effects of high and low frequency rTMS on regional brain activity in depressed patients. Biol Psychiatry.
195 Speer AM, Repella JD, Figueras S, et al. (2001). Lack of adverse cognitive effects of 1 Hz and 20 Hz repetitive transcranial magnetic stimulation at 100% of motor threshold over left prefrontal cortex in depression. J ECT.
196 Speer AM, Wassermann EM, Benson BE, Herscovitch P, Post RM. (2014). Antidepressant efficacy of high and low frequency rTMS at 110% of motor threshold versus sham stimulation over left prefrontal cortex. Brain Stimul.
197 Spronk D, Arns M, Bootsma A, van Ruth R, Fitzgerald PB. (2008). Long-term effects of left frontal rTMS on EEG and ERPs in patients with depression. Clinical EEG & Neuroscience: Official Journal of the EEG & Clinical Neuroscience Society (ENCS).
198 Szuba MP, O'Reardon JP, Rai AS, et al. (2001). Acute mood and thyroid stimulating hormone effects of transcranial magnetic stimulation in major depression. Biol Psychiatry.
199 Tarhan N, Sayar FGH, Tan O, Kagan G. (2012). Efficacy of high-frequency repetitive transcranial magnetic stimulation in treatment-resistant depression. Clinical EEG & Neuroscience: Official Journal of the EEG & Clinical Neuroscience Society (ENCS).
200 Tenev V, Robinson RG, Jorge RE. (2009). Citalopram for continuation therapy after repetitive transcranial magnetic stimulation in vascular depression. Am J Geriatr Psychiatry.
201 Triggs WJ, McCoy KJM, Greer R, et al. (1999). Effects of left frontal transcranial magnetic stimulation on depressed mood, cognition, and corticomotor threshold. Biol Psychiatry.
202 Ullrich H, Kranaster L, Sigges E, Andrich J, Sartorius A. (2012). Ultra-high-frequency left prefrontal transcranial magnetic stimulation as augmentation in severely ill patients with depression: A naturalistic sham-controlled, double-blind, randomized trial. Neuropsychobiology.
203 Valiulis V, Gerulskis G, Dapsys K, Vistartaite G, Siurkute A, Maciulis V. (2012). Electrophysiological differences between high and low frequency rTMS protocols in depression treatment. Acta Biol Exp (Warsz).
204 Vanderhasselt M-A, De Raedt R, Leyman L, Baeken C. (2009). Acute effects of repetitive transcranial magnetic stimulation on attentional control are related to antidepressant outcomes. Journal of Psychiatry & Neuroscience.
205 Wang XM, Yang DB, Yu YF, Huang H, Zhao XQ. (2004). A controlled study of the treatment of repetitive transcranial magnetic stimulation in patients with major depression. Chinese Journal of Clinical Rehabilitation.
206 Yukimasa T, Yoshimura R, Tamagawa A, et al. (2006). High-frequency repetitive transcranial magnetic stimulation improves refractory depression by influencing catecholamine and brain-derived neurotrophic factors. Pharmacopsychiatry.

### EVIDENCE TABLES

#### QUALITY ASSESSMENT OF INCLUDED MULTICENTER TRIALS

#### QUALITY ASSESSMENT OF INCLUDED SYSTEMATIC REVIEWS

#### ONGOING CLINICAL TRIALS

#### UNPUBLISHED CLINICAL TRIALS

### Potential Publication Matches

1 Boutros NN, Gueorguieva R, Hoffman RE, Oren DA, Feingold A, Berman RM. (2002). Lack of a therapeutic effect of a 2-week sub-threshold transcranial magnetic stimulation course for treatment-resistant depression. Psychiatry Res.
2 Fitzgerald PB, Hoy K, McQueen S, et al. (2008). Priming stimulation enhances the effectiveness of low-frequency right prefrontal cortex transcranial magnetic stimulation in major depression. J Clin Psychopharmacol.

Total pulses=(Hz)×(pulse train duration)×(trains per session)×(total number of sessions). For example, the total number of pulses for 40 15-Hz trains of 2-s duration given 5 times a week for 2 weeks would be given by the following calculation: (15 Hz)*(2 s/train)*(40 trains/session)*(10 total sessions)=12,000 total pulses. The total number of pulses for 20 20-Hz trains of 4-s duration given twice a week for 4 weeks would be given by the following calculation: (20 Hz)*(4 s/train)*(20 trains/session)*(8 total sessions)=12,800 total pulses. This is how the total number of pulses was calculated throughout this review.