# Evidence Brief: Effectiveness of Intensive Primary Care Programs

## PREFACE

Quality Enhancement Research Initiative's (QUERI) Evidence-based Synthesis Program (ESP) was established to provide timely and accurate syntheses of targeted healthcare topics of particular importance to Veterans Affairs (VA) managers and policymakers, as they work to improve the health and healthcare of Veterans. The ESP disseminates these reports throughout VA.

QUERI provides funding for four ESP Centers and each Center has an active VA affiliation. The ESP Centers generate evidence syntheses on important clinical practice topics, and these reports help:

- develop clinical policies informed by evidence,
- guide the implementation of effective services to improve patient outcomes and to support VA clinical practice guidelines and performance measures, and
- set the direction for future research to address gaps in clinical knowledge.

In 2009, the ESP Coordinating Center was created to expand the capacity of QUERI Central Office and the four ESP sites by developing and maintaining program processes. In addition, the Center established a Steering Committee comprised of QUERI field-based investigators, VA Patient Care Services, Office of Quality and Performance, and Veterans Integrated Service Networks (VISN) Clinical Management Officers. The Steering Committee provides program oversight, guides strategic planning, coordinates dissemination activities, and develops collaborations with VA leadership to identify new ESP topics of importance to Veterans and the VA healthcare system.

Comments on this evidence brief are welcome and can be sent to Nicole Floyd, ESP Coordinating Center Program Manager, at nicole.floyd@va.gov.

Acknowledgments: We thank Tomiye Akagi, our Program Assistant, for assistance with editing and formatting; Rose Relevo, MLIS, MS, AHIP for searching; Jennifer Winfrey for assistance with article retrieval and data abstraction; and Camber Hansen-Karr for assistance with data abstraction.

## INTRODUCTION

Improving the healthcare of Americans with multiple chronic conditions is one of the top aims of the U.S. national healthcare research agenda. One of the driving forces behind this objective is the disproportionately high concentration of healthcare expenditures that are attributed to this population. The 2009 Medical Expenditure Panel Survey (MEPS) found that the sickest 10 percent of patients account for 65 percent of all health expenses for the U.S. population (from July 2012 meeting of the National Advisory Council for Healthcare Research and Quality, which focused on trends in healthcare costs and the concentration of medical expenditures).1 Further, the MEPS identified a number of chronic conditions that most influence high levels of expenditures, including heart disease, cancer, mental disorders, chronic obstructive pulmonary disease (COPD) and diabetes.

Potentially preventable readmissions are among the disproportionately high concentration of healthcare expenditures attributed to the sickest 10 percent of patients. In their June 2007 report to Congress, the MedPAC (Medical Payment Advisory Commission) estimated that 75 percent of Medicare readmissions are potentially preventable.2

Potentially preventable hospitalizations have been linked to discontinuity of primary care.3 In a 1984 randomized trial, elderly male Veterans who saw a different physician at each visit had a statistically significantly higher rate of emergent hospital admissions and longer average length of stays than those who saw the same primary care doctor at every visit.3

Since the 1980's, the problem of high-risk patients with frequent hospital admissions has persisted despite dramatic changes in the practice environment. One important change is the redesign of primary care. The Veterans Health Administration (VHA) Primary Care Program Office is implementing a Patient Aligned Care Teams (PACT) model at all primary care sites, in which continuous care is delivered by interdisciplinary teams who serve as the first point of contact for a broad range of fully-integrated health services and community resources. The VA's PACT model and other Patient-Centered Medical Home (PCMH) models are based on earlier innovations such as the Chronic Care Model, the Idealized Design of Clinical Office Practices, and Clinical Microsystems. They seek to implement primary care that is continuous, comprehensive, efficient, patient-driven and team-based.4,5 The PCMH models are not primarily aimed at patients who are at high risk of hospital admission, although most include reducing hospitalizations and emergency room use among their secondary aims. In the VA PACT, for example, hospital care and specialized services are provided outside of the PACT, while coordinators focus on smoothing hand-offs between care settings including those involving VA and non-VA providers. A recent Agency for Healthcare Research and Quality (AHRQ) systematic review of 19 comparative studies found that implementation of these models had no effect on hospital admissions (RR 0.96; 95% CI 0.84-1.10), but it reduced emergency room visits (0.81, 0.67-0.98) and modestly improved staff and patient experiences.6

Disease management and care coordination programs have also sought to improve the quality and delivery of care to patients with high-cost chronic illnesses. The U.S. Congressional Budget Office (CBO) issued a brief report (January 2012) on the effects of 34 Medicare demonstration projects on disease management and care coordination programs, and cited the following approaches as helpful in reducing hospital admissions: (1) use of team-based care, especially those with larger teams that include pharmacists; and (2) the smoothing of transitions between a primary care provider and a specialist.7 However, a recent AHRQ review of nurse-led case management programs for adults with medical illnesses and complex care needs found no effect on rates of hospitalization and a variable effect on emergency room use.8 The nurse-led interventions encompassed patient self-management education, health status monitoring, and coordination of care, typified by the Medicare Coordinated Care Demonstration (MCCD).

From the viewpoint of caring for frequently hospitalized patients, the rise of hospitalism also poses a challenge to continuity of care. David Meltzer, MD, PhD, Associate Professor of Medicine and Director of the Hospitalist Program at the University of Chicago Medicine, has studied the changing medical workforce in the United States and found that the trend toward increased medical specialization has had the unintended consequence of increased fragmentation of primary care.9 One of the key challenges for the primary care system in meeting the complex needs of high-risk patients with multiple chronic conditions is adapting to the increased demands of collaborating with a larger number of associated healthcare providers within a decentralized, fee-for-service healthcare delivery system which does not pay for or facilitate communication or coordination among providers.7

Some would say that we have reached a point where we have to decide if we should continue to invest in programs with an increased need for coordination or in different models that reduce the need for coordination in the first place. Applying team theory literature,10 Dr. Meltzer has said “if you're spending all of your time coordinating, you should change the product.”11 For example, Dr. Meltzer has proposed a ‘comprehensive care physician model,’ to reduce the need for coordination between the primary care and hospitalist settings. In this model, a physician with expertise in both inpatient medicine and primary care leads an interdisciplinary team that carries a panel of approximately 200 frequently hospitalized patients, who they will treat both inside and outside of the hospital.11 The Centers for Medicare & Medicaid Services (CMS) have funded a demonstration of this program at the University of Chicago. Others focus on reducing the need for coordination and handoffs between primary care and specialty care. From this viewpoint, admissions from primary care could be reduced through accelerated consults or direct access to intense short stay and complex diagnostic unit services.

The persistence of high inpatient utilizers despite the spread of case management and PCMH models has led to interest in ‘intensive primary care’ models. For example, a new round of CMS-funded demonstration projects focus on intensive models for patients at high risk of using inpatient resources.12 In their Research Brief published by the National Institute for Health Care Reform, Yee et al. proposed a taxonomy for categorizing ‘High-Intensity Primary Care’ programs, also sometimes called ‘Ambulatory Intensive Care Units,’ which use PCMH-based approaches to managing the sickest, highest-cost patients.13 In a ‘freestanding’ model, ongoing care is fully transferred from patients' regular primary care physicians to a dedicated clinic that exclusively or chiefly provides high-intensity primary care to a select group of patients. In contrast, in a ‘practice-based’ model, patients continue to receive care from their regular primary care physician, but are offered additional, high-intensity services, often managed by a care coordinator. In a hybrid model, care is temporarily shifted from the patients' regular primary care physicians to a dedicated clinic, and returned once their conditions stabilize. These approaches, which involve physician-led, team-based discussion and coordination that serve as the source of primary care, were excluded from the two AHRQ reviews mentioned earlier.

As part of the PACT model initiative, the Health Delivery Committee is proposing to develop a primary care intensivist model that deploys well-trained interdisciplinary teams that identify and proactively manage Veterans at highest risk for hospital admission and death. The goal of the model is to reduce emergency department and urgent care utilization, hospitalizations and mortality among complex, high-risk patients.

For healthcare system decision-makers, evidence is only one of many different factors taken into account. If a health system waits until there is traditional hard and fast evidence on the effectiveness of a new healthcare model, they would always be 10 years out of date. However, decision-makers do need to consider the findings of the best available research and the strength and applicability of that evidence.

This report was produced in response to the Health Delivery Committee's request for an evidence brief to assist with their evaluation of the effectiveness of existing intensive primary care programs involving multimodal interventions delivered by interdisciplinary teams. An evidence brief differs from a full systematic review in that the scope of work is more narrowly defined and the traditional review methods are streamlined in order to synthesize evidence within a shortened timeframe. An evidence brief cannot capture the actual day-to-day program operations of evolving programs. While decision-makers can benefit from knowing about the best available research and the strength and applicability of that evidence, an evidence brief cannot encompass the full range of policy options or novel programs, many of which have not been evaluated in formal studies.

## SCOPE

The objective of this evidence brief is to evaluate the effectiveness of interdisciplinary, multicomponent intensive primary care programs in reducing mortality and hospital use among patients identified at highest risk for hospital admission and death while still in the ambulatory care setting.

The Evidence-based Synthesis Program (ESP) Coordinating Center investigators and representatives of the Health Delivery Committee Workgroup worked together to identify the population, intervention, comparator, timing, setting and study design characteristics of interest. The Health Delivery Committee Workgroup approved the following eligibility criteria to guide this review:

- [underlined: P]opulation: Patients identified as high risk for hospital admission and/or death, regardless of whether or not there was a disease-specific focus, such as heart failure.
- [underlined: I]nterventions: Multi-component, interdisciplinary intensive primary care programs.
- [underlined: C]omparator: Usual care (without the utilization of an intensive primary care program).
- [underlined: O]utcomes: All-cause mortality, hospitalization, emergency department use, hospital days.
- [underlined: T]iming: Studies that include a follow-up period of more than 30 days.
- [underlined: S]etting: Ambulatory setting.
- [underlined: S]tudy design: Systematic reviews, controlled clinical trials, observational studies.

## METHODS

We searched for systematic reviews, controlled clinical trials, and observational studies in PubMed (1946 through September 5, 2012), CINAHL (1981 through September 5, 2012), the Cochrane Central Register of Controlled Trials^®^ (3^rd^ quarter 2012), and the Cochrane Database of Reviews of Effects (3^rd^ quarter 2012), using standard search terms (for full search strategy, see Supplemental Materials). Additional citations were identified from reference lists, hand searching, and consultation with content experts. We also searched for unpublished information about additional intensive primary care programs from various gray literature sources (see Appendix A for results and list of sources). We limited the search to articles involving human subjects and available in the English language.

Study selection was based on the eligibility criteria described above. Titles and abstracts and full-text articles were first reviewed by one investigator with methodological expertise and a proportion of the first reviewer's decisions were then checked by a second senior investigator with clinical content expertise. There was a high level of agreement and all disagreements were resolved using consensus.

We used predefined criteria to rate the internal validity of all individual studies. Risk of bias of controlled clinical trials was assessed using the Cochrane Collaboration's tool and judged as low, unclear or high.14 We rated the internal validity (quality) of controlled observational studies as good, fair or poor, using methods of the Drug Effectiveness Review Project (DERP) and based on the adequacy of the patient selection process; completeness of follow-up; adequacy of outcome ascertainment; use of acceptable statistical techniques to minimize potential confounding factors; and whether the duration of follow-up was reasonable to capture investigated events.15 We abstracted data from all included studies on population, intervention, comparator, and timing characteristics and results for each included outcome. All data abstraction and internal validity ratings were first completed by one reviewer and then checked by another. All disagreements were resolved using consensus.

We graded strength of evidence based on the guidance established for the Evidence-based Practice Center Program of AHRQ.16 This approach incorporates four key domains: risk of bias (includes study design and aggregate quality), consistency, directness, and precision of the evidence. It also considers other optional domains that may be relevant for some scenarios, such as a dose-response association, plausible confounding that would decrease the observed effect, strength of association (magnitude of effect), and publication bias. Strength of evidence is graded for each key outcome measure and ratings range from high to insufficient, reflecting our confidence that the evidence reflects the true effect. Brief information on our assessments for all included controlled studies is provided in Table 3.

TABLE 3 CONTROLLED STUDIES: RISK OF BIAS AND STRENGTH OF EVIDENCE

Author Year (Model Name) Study Design | Risk of Bias | Strength of Evidence Rating
Home-Based (3 RCT's; N = 2454)
Hughes 2000^31^ (VA HBPC) Multicenter RCT | Unclear: Unclear blinding of outcome assessors. | Moderate: Medium Risk of Bias; Consistent; Direct; Precise
Hughes 1990^33^ (VA HBPC) Single Center RCT | High: Intervention group was younger (66 vs 69; P = 0.02), more were retired due to health conditions (67% vs 51%; P = 0.01) and more were using non-VA clinics (36% vs 19%; P = 0.01). | Moderate: Medium Risk of Bias; Consistent; Direct; Precise
Melin 1995^30^ RCT | High: Team group had significantly more medical diagnoses (4.5 vs 3.9; P = 0.003). | Moderate: Medium Risk of Bias; Consistent; Direct; Precise
Free-Standing Clinic (1 RCT, 1 observational study; N = 7814)
Beland 2006^25^/Bergman 1997^26^ (SIPA) RCT | Unclear: Uncertainty about whether incomplete data were adequately handled (1% in SIPA group compared with 7% in control discontinued intervention). | Moderate: Medium Risk of Bias; Consistent; Direct; Precise
Meret-Hanke 2011^41^ (PACE) Observational | Unclear: Propensity score matching used, but differences persisted even after matching; but regression used to control for potential additional sources of bias. | Moderate: Medium Risk of Bias; Consistent; Direct; Precise
Practice-Based
Elderly (2 RCT's, 1 observational study; N = 1179)
Coleman 1999^27^ (Chronic Care Clinic) RCT | High: Control patients had higher Chronic Disease Score (CDS) than intervention patients (7.7 vs 7.3; P = 0.06). | High-Risk Group = Low: High Risk of Bias; Inconsistent; Indirect (low applicability); Imprecise Overall=Moderate: Medium Risk of Bias; Consistency N/A; Indirect (low applicability); Precise
Counsell 2007^29^/ Counsell 2006^28^ (GRACE) RCT | Full sample: Unclear Uncertainty about use of adequate allocation concealment methods and the significantly lower rate of county medical assistance use in the GRACE intervention group at baseline (83.7% compared with 89.0%; P = 0.02). High-risk group: High Complete uncertainty about the comparability of baseline characteristics between the GRACE and control groups. As baseline characteristics were not provided for the high-risk subgroup, we can't rule out that potential differences in patient characteristics may have mediated the positive effect of the GRACE intervention on hospital utilization outcomes. | High-Risk Group = Low: High Risk of Bias; Inconsistent; Indirect (low applicability); Imprecise Overall=Moderate: Medium Risk of Bias; Consistency N/A; Indirect (low applicability); Precise
Jiwa 2002^39^ Observational | High: Baseline differences between intervention and control group (e.g., intervention group selected because considered to be at-risk of avoidable hospitalization; control group were not considered to be at risk); inadequate outcome ascertainment; no control for potential confounders. | High-Risk Group = Low: High Risk of Bias; Inconsistent; Indirect (low applicability); Imprecise Overall=Moderate: Medium Risk of Bias; Consistency N/A; Indirect (low applicability); Precise
Younger Patients with High Utilization (1 RCT; N = 96)
Sledge 2006^32^ (PIC) RCT | High: Intervention group had lower proportion of males (26% compared with 41%), unclear allocation concealment. | Low: High Risk of Bias; Consistency N/A; Direct; Imprecise

Abbreviations: GRACE = Geriatric Resources for Assessment and Care of Elders, HBPC = Home-Based Primary Care, N = number, N/A = Not Applicable, PACE = Program of All-Inclusive Care for the Elderly, PIC = Primary Intensive Care, RCT = Randomized Controlled Trial, SIPA = French acronym for “System of Integrated Care for Older Persons,” VA = Veterans Affairs

We used a hierarchy of evidence approach, where the best evidence was the focus of our synthesis. As such, randomized controlled trials (RCTs) and controlled observational studies were preferred over uncontrolled observational studies. To organize our synthesis, we aimed to group studies based on similarities in patient selection methods (e.g., previous hospitalizations, elderly, disability level, etc.) and/or types of high-intensity primary care models (e.g., primary care transferred to freestanding clinics; high-intensity services added to existing primary care practice; home-based; comprehensive care physician model, etc.). Special attention was paid to the applicability of the study populations in comparison to the target high-risk Veteran and military population. To determine the appropriateness of meta-analysis, the risk of bias of the studies and their heterogeneity in design, patient population, interventions, and outcomes were considered.

## RESULTS

### OVERVIEW

Figure 1 provides details on the results of study selection. The primary reason for exclusion at the full-text level was that the model was not multimodal, but instead focused on a single aspect of care, such as case management or telehealth. A full listing of all studies excluded at the full-text level and the reasons for their exclusions is provided in the Supplemental Materials.

Figure 1 Literature Flow Chart

Although we originally sought to rely on evidence from existing high-quality systematic reviews, we did not find any with a focus similar enough to the interests of this review to provide useful information to the requestors. While we searched for studies of patients at high risk of hospital admission and/or death, regardless of whether or not there was a disease-specific focus, such as heart failure, we only found studies of heart failure and chronic obstructive pulmonary disease-specific populations that used traditional disease management models that involved increased patient education and follow-up and aimed at general improvement in the quality of care.17-24 Although these studies mentioned primary care provider involvement, it was limited to attempts to improve communication and ensure reinforcement of information. Because all other non-heart failure conditions were managed as usual by primary care providers, with no crossing of traditional practice boundaries, we excluded these studies from this review.

We included seven randomized controlled trials of intensive primary care programs (in nine publications).25-33 We also included 13 observational studies.34-46 All but two39,41 were uncontrolled before-after studies that did not assess the potential impact of any concurrent events on the outcomes of interest and did not assess whether any observed changes exceeded what would be naturally expected over time. Due to these serious limitations, it is impossible to attribute causation from these uncontrolled studies. Therefore, we focused only on the findings of the two controlled observational studies.39,41 Characteristics (Table 1), results (Table 2) and internal validity and strength of evidence ratings (Table 3) of the controlled studies are summarized in the tables at the end of this report. A table of the complete internal validity ratings of the controlled trials is provided in the Supplemental Materials. Tables of characteristics and results of the uncontrolled studies are also provided as supplemental materials.

TABLE 1 CONTROLLED STUDIES: CHARACTERISTICS

Author Year Care model name Study design Setting Sample size Follow-up | Key patient selection criteria | Role of regular primary care physician | Interdisciplinary team staffing | Key features | Usual care characteristics | Risk: Prior health service use (e.g., hospitalizations, home health, respite, etc.) | Other risk indicators: Functional capacity, comorbidities, etc. | Key patient characteristics
Beland 2006^25^/ Bergman 1997^26^ SIPA (System of Integrated Care for Older Persons) RCT Public community organizations responsible for home care in the province of Quebec N = 1309 19 months | Frail elderly: Aged ≥ 64 years; community dwelling; ≥ moderate disability (score ≤ -10 on SMAF scale) | Patients were encouraged to continue to see their own physician | Case managers, community nurses, social workers, occupational therapists, physiotherapists, homemakers, staff family physician, consultant pharmacists, community organizers | - Comprehensive geriatric assessment upon intake; - Case management; - Care based on evidence-based interdisciplinary protocols; - 24-hour on-call service; - Maintained clinical responsibility and accountability inside and outside of hospital; - SIPA family physicians offered $200 per patient in addition to usual fee-for-service payments to compensate for time communicating with team; - SIPA family physicians each cared for between 1-10 patients; - Visit frequency NR | Offered usual home care services including nursing, rehabilitation, physician, personal, and social services but with limited time and availability and essentially no case management | NR | # of chronic diseases: 4.9 Functional limitations (# performed with difficulty): 3.7 | 82 years 29% male Race NR Medical comorbidities NR Cognitive problems (% with 3+ on SPMSQ): 31% Depressive symptoms (% with 10+ on GDS): 13%
Coleman 1999^27^ Chronic Care Clinic RCT Ambulatory clinic in a large staff-model HMO in western Washington State (Group Health Cooperative) N = 169 24 months | Care transitions program, plus age, lower functional status, cognitive impairment: Aged ≥ 65 years; each practice selected top 36 patients with highest Risk Scores based on validated computer-based predictive index (Coleman 1998) | Continue to provide all care | Nurse, pharmacist, social worker | - Half-day visits with team every 3-4 months, including pharmacist consultations and self-management group session; - Use of systematic health status assessment approach; - Panel size of 19; - Compensation NR | NR | 44% hospitalized in prior year Mean risk score: 0.54 | Chronic Disease Score: 7.7 vs 7.3 | 77 years 52% male 97% White 51% diabetes HF NR COPD NR HTN NR Psychiatric, cognitive comorbidities NR
Counsell 2007^29^ GRACE (Geriatric Resources for Assessment and Care of Elders) RCT 6 community-based health centers affiliated with Wishard Health Services, a university-affiliated urban healthcare system serving medically indigent patients in Indianapolis, Indiana N = 951 24 months | Poverty: Age ≥ 65 years; income < 200% of federal poverty level | - Contribute to care plan development; - Collaborate with support team to implement care plan; - Employ GRACE support team members | Geriatrician, pharmacist, physical therapist, mental social worker, community-based services liaison | - In-home assessment and care management provided by an NP and social work team; - Individualized care plan development with multidisciplinary input; - Protocol-driven care; - Integrated electronic medical record; - Web-based care management tracking tool; - Integration with affiliated pharmacy, mental health, home health, and community-based and inpatient geriatric care services; - Minimum of 1 in-home follow-up visit and 1 telephone or face-to-face contact per month with support team; - Panel size NR; - PCP not directly compensated for involvement, but credited in annual performance review | Access to all existing primary and specialty care services: Outpatient geriatric assessment and multispecialty center, inpatient ACE unit and consult service, skilled nursing facility, physician house call program, psychiatric care | Hospitalizations in past 6 months (mean): 0.2 | Living alone: 47% | 72 years 24% male 41% White 81% HTN 34% diabetes 13% HF 22% chronic lung disease Depression (PHQ-9 score ≥ 10): 11% Dementia (SPMSQ score ≤ 5): 1%
Hughes 1990^33^ VA HBPC RCT Hines VA Hospital, Illinois N = 233 6 months | Need intensive assistance: ≥ 2 ADL impairments | Not described | Physician, nurse, social worker, physical therapist, dietician, health technicians | Comprehensive, continuous care to patients at home; visit frequency; panel size; compensation NR | Customary care; including use of Medicare or other community home care | VA hospital use in past 6 months: 49% Non-VA hospital use in past 6 months: 28% | Katz ADL impairments (mean): 4.5 | 68 years % male NR 78% White Heart disease: 16% Respiratory diseases: 13% Cerebrovascular disease: 9% Psychiatric, cognitive comorbidities NR
Hughes 2000^31^ VA HBPC RCT 16 VA medical centers N = 1966 12 months | Need intensive assistance, plus multiple comorbidities: (1) ≥ 2 ADL impairments OR terminal illness prognosis; OR (2) homebound with primary diagnosis of CHF or COPD; OR (3) outpatients or nursing home residents with same diagnoses, plus hospitalization within past 3 months | Transferred to HBPC physician and medical team until discharge from the program | Social workers, dietitians, therapists, pharmacists, health technicians | - Integrated networks; - Systematic screening; - Emphasis on continuity of care; - Management across organizational boundaries; - Provide 24-hour contact for patients; - Visit frequency, panel size, compensation NR | Access to any VA-sponsored services, except HBPC and non-VA postacute services | 89% hospitalized in past 6 months Mean days of index admission: 31 | Katz ADL impairments (mean): 3.2 82% reside with caregiver 36% of patients had a high score on Smith Comorbidity Index | 70 years 96% male 64% White 55% had any CHF or COPD; diabetes NR Mental status (mean score on SPMSQ): 7.1
Jiwa 2002^39^ Observational Single general practitioner practice in a market town in Nottinghamshire, UK; average deprivation level (Jarman score -4.26) N = 59 Follow-up period not specified | Poverty: Age ≥ 75 years; income < 200% of federal poverty level | Unclear; once a patient was referred to the wider primary care team, a nominated general practitioner or nurse undertook regular visits or telephone calls to patient | General practitioner, dietician, physiotherapist, occupational therapist, district nurse, social worker | - Enhanced support by a multidisciplinary team; specific details not described | NR | 34% social service involvement | 32% admitted to hospital 1/1998-9/2000 | 83 years 26% male Race NR Diabetes: 17% Cerebrovascular disease: 12% Ischemic heart disease: 17% Chronic obstructive airways disease: 13% Congestive cardiac failure: 14% Dementia: 15%
Melin 1995^30^ RCT St. Görans, a county general hospital, and the Serafen Primary Care Center in Stockholm, Sweden N = 249 6 months | Need intensive assistance: Medically stable, but chronically ill, and dependent in 1-5 Katz ADLs | Not described | Project physician, primary care physician, secretary, district nurse, physiotherapist, occupational therapist, nurse assistant | - Physician-led home healthcare; - Assessment of each patient's needs for medical, functional and social care in the home; - Weekly interdisciplinary care-planning conference; - Visit frequency, panel size, compensation NR; - 24-hour telephone service | Continued treatment in an acute or long-stay hospital, followed by standard district nurse-administered care at home | NR | Katz ADL impairments (mean): 2.4 Instrumental ADLs (mean): 6.0 Medical diagnoses (mean): 4.3 | 81 years 31% male Race NR Primary cardiovascular disease: 22%; others NR Folstein MMSE (mean): 22.2 Psychiatric disorders (mean): 5.6
Meret-Hanke 2011^41^ PACE (Program of All-Inclusive Care for the Elderly) Observational Variety of U.S. urban and rural settings N = 3889 2 years | Need intensive assistance: Nursing home-eligible individuals who are aged ≥ 55 years and live within the programs' catchment areas | Not described | Primary care physicians, nurse practitioners, onsite and home health nurses, social workers, occupational/physical therapists, dietitians, health workers, recreation therapists, and transportation workers | - Fully integrating the financing and delivery of acute and long-term care services; - Services delivered in programs' adult day centers, in enrollees' homes, as well as inpatient settings; - Financing integrated through capitated payments; - Interdisciplinary teams responsible for managing enrollees' care across all settings; - Shared decision-making; - Typical staff: enrollee ratio is 60-80:120-150; - Visit frequency NR | NR (control group from Medicare Current Beneficiary Survey) | PACE pre-baseline mean hospital use 1.58 days/month vs 1.04 days/ month | 3 or 4 ADL limitations .5 vs .26 | 80.2 years 27% male 52% White Medical comorbidities NR 55% dementia
Sledge 2006^32^ PIC (Primary Intensive Care) RCT Within primary care center of an urban, academically affiliated hospital in northeastern U.S. N = 96 12 months | ≥ 2 medical or surgical hospital admissions in prior 12 months; but excluded very highest outliers (total hospital cost > 2 SD's of log-transformed mean, Charlson Comorbidity Index > 5) | Continue to provide care | Primary care provider, psychiatric nurse case manager with advanced practice nursing certifications (APRN) in medical and psychiatric, social worker, psychiatrist, general internist | - Comprehensive interdisciplinary medical and psychosocial assessment; - Ambulatory case management for 1 year; - Minimum of monthly telephone call from nurse case manager; phone/pager availability 5 days/week; - Panel size of case manager ≤ 21; - Compensation NR | Usual care directed by PCP; on-site psychiatric consultation available by PCP referral | 100% ≥ 2 hospitalizations in past year | Charlson score: 1.8 | 51 years 33% male 31% White 15% CHF 20% COPD 26% diabetes HTN NR 47% any psychiatric disorder, 33% current major depression; substance use disorders (mean AUDIT-PRIME-MD scores) = 2.6

TABLE 2 CONTROLLED STUDIES: RESULTS

Author Year Care model name Study design Setting Sample size Follow-up | Mortality rate | Hospital admission/readmission | Hospital days | ED visits
Beland 2006^25^/Bergman 1997^26^ SIPA (System of Integrated Care for Older Persons) RCT Public community organizations responsible for home care in the province of Quebec N = 1309 19 months | Deceased (prior to and after baseline): 19% vs 22%; “SIPA had no effect on mortality” (data NR) | Acute hospitalization (“became alternate level of care”): OR 0.52 (95% CI, 0.33 to 0.82) | Inpatient care: OR 0.93 (95% CI, 0.71 to 1.18) | ED visits: OR 0.92 (95% CI, 0.73 to 1.20)
Coleman 1999^27^ Chronic Care Clinic RCT Ambulatory clinic in a large staff-model HMO in western Washington State (Group Health Cooperative) N = 169 24 months | 16% vs 17%; NSD | > 1 Hospitalization (% pts): 36.5% vs 34.3%; adjusted P = 0.72 Hospital admits (mean/yr): 0.58 vs 0.59; adjusted P = 0.91 | Hospital days (mean): 6.4 vs 5.4; adjusted P = 0.57 | Emergency visits (mean/yr): 0.23 vs 0.27; adjusted P = 0.73
Counsell 2007^29^ GRACE (Geriatric Resources for Assessment and Care of Elders) RCT 6 community-based health centers affiliated with Wishard Health Services, a university-affiliated urban healthcare system serving medically indigent patients in Indianapolis, Indiana N = 951 24 months | Full sample: 7.0% vs 7.0%; P = 0.64 High-risk subgroup: NR | Hospital admissions, per-1000: [underlined: Full sample] (cumulative): 700 vs 740; P = 0.66 [underlined: High-risk] (cumulative NR): Year 1: 705 vs 798; P = 0.60 Year 2: 396 vs 705; P = 0.03 | Hospital days, per-1000: [underlined: Full sample] (cumulative): 3749 vs 4069; P = 0.66 [underlined: High-risk] (cumulative NR): Year 1: 3938 vs 4544; P = 0.68 Year 2: 2152 vs 3943; P = 0.13 | [underlined: High risk subgroup] Year 1: 1098 vs 1149; P = 0.79 Year 2: 848 vs 1314; P = 0.03 [underlined: Full sample:] Cumulative 2-year per-1000: 1445 vs 1748; P=0.03 Year 1: 823 vs 937; P = 0.22 Year 2: 643 vs 841; P = 0.01
Hughes 1990^33^ VA HBPC RCT Hines VA Hospital, Illinois N = 233 6 months | NR | NR | Total hospital days: 13.68 vs 13.53; P = NS Non-VA hospital days: 2.11 vs 0.82; P = 0.10 | VA ER visits: 0.76 vs 0.61; P = NS Non-VA ER visits: 0.11 vs 0.10; P = NS
Hughes 2000^31^ VA HBPC RCT 16 VA medical centers N = 1966 12 months | Excluding deaths before discharge: 34.7% vs 34.1%; P = 0.08 Including deaths before discharge: 38% vs 37%; P = NR | % patients readmitted: Months 1-6: 49% vs 53%; P = 0.07 Months 1-12: 61% vs 63%; P = 0.35 Mean # readmissions: Months 1-6: 0.8 vs 0.9; P = 0.06 Months 1-12: 1.3 vs 1.3; P = 0.28 | Mean rehospitalization days: Months 1-6: 9.3 vs 9.5; P = 0.16 Months 1-12: 14.7 vs 13.3; P = 0.95 | NR
Jiwa 2002^39^ Observational Single general practitioner practice in a market town in Nottinghamshire, UK; average deprivation level (Jarman score -4.26) N = 59 Follow-up period not specified | 15% vs 5%; P-value = NS | Hospital admissions: 4 vs 7; P-value = NS | NR | NR
Melin 1995^30^ RCT St. Görans, a county general hospital, and the Serafen Primary Care Center in Stockholm, Sweden N = 249 6 months | 26% vs 27%; P = NR | NR | [underlined: Survivors (N] = [underlined: 183)] Short-term (days): 24 vs 25; P = 0.50 Long-term (days): 16 vs 49; P < 0.001 Rehab. hosp. (days): 2 vs 3; P = 0.87 [underlined: Decedents (N] = [underlined: 66)] Short-term (days): 149.9 vs 179.9; P = 0.93 Long-term (days): 7.4 vs 53.6; P = 0.18 Rehab. hosp. (days): 5.4 vs NR; P = NR | NR
Meret-Hanke 2011^41^ PACE (Program of All-Inclusive Care for the Elderly) Observational Variety of U.S. urban and rural settings N = 3889 2 years | Control group = 24.9%, “almost 5 percentage points higher than PACE sample” (data and analysis NR) OR at 2 year follow-up 3.26 P < .01 Means: Interval 1: .06 Interval 2: .06 Interval 3: .07 Interval 4: .07 | Any hospital use: Adjusted OR 0.16; P = 0.01 (95% CI NR) | Days in hospital per month: Weighted mean difference: -0.54; P < 0.01 (95% CI NR) | NR
Sledge 2006^32^ PIC (Primary Intensive Care) RCT Within primary care center of an urban, academically affiliated hospital in northeastern U.S. N = 96 12 months | 6% vs 10%, P-value = NR | Mean changes (pre-post): Inpatient admissions: -0.1 vs -0.3, NSD | NR | ED visits: -0.52 vs -0.6; NSD

Abbreviations: ADL = Activities of Daily Living, CHF = Congestive Heart Failure, COPD = Chronic Obstructive Pulmonary Disease, ED = Emergency Department, GDS = Geriatric Depression Scale, GRACE = Geriatric Resources for Assessment and Care of Elders, HBPC = Home-based Primary Care, HF = Heart Failure, HTN = Hypertension, N = Number, NP = Nurse Practitioner, NR = Not Recorded, NSD = No Significant Difference, PACE = Program of All-Inclusive Care for the Elderly, PCP = Primary Care Physician, PIC = Primary Intensive Care, RCT = Randomized Controlled Trial, SIPA = System of Integrated Care for Older Persons, SMAF = Functional Autonomy Measurement System, SPMSQ = Short Portable Mental State Questionnaire, VA = Veterans Affairs

Only two studies involved Veteran and military populations.31,33 The majority of the remaining studies involved mostly elderly, non-White females. Only one controlled study selected patients entirely based on high utilization of inpatient services, requiring at least two prior hospital admissions per year in the 12 to 18 months prior to recruitment.32 The remaining studies selected patients who were at least moderately disabled in activities of daily living;25,26,30,31,33 aged above 64,^25^ 65,^27-29^ or 75;^39^ had income below 200 percent of federal poverty level;28,29,39 and/or who met nursing home eligibility criteria.41

Among the included programs evaluated in controlled studies, four used practice-based models where additional high-intensity services are added to ongoing care from their regular primary care physician,27-29,32,39 two used a freestanding model where ongoing care was transferred from the patients' regular primary care physicians to dedicated clinics that exclusively provide high-intensity care to a select group of patients,25,26,41 and three were home-based.30,31,33 We did not pool any data across studies because of the heterogeneity in design, patient population, interventions, and outcome assessment methods.

We did not find any published studies of other types of high-intensity primary care programs, such as Dr. Meltzer's comprehensive care physician model or Dr. Sanjeev Arora's Project ECHO (Extension for Community Healthcare Outcomes). Our search of gray literature sources identified unpublished information about the following additional intensive primary care programs, which are summarized in Appendix A: After Discharge Management of Low Income Frail Elderly (AD-LIFE), AtlantiCare Special Care Center Ambulatory Intensive Care Unit, Boeing Intensive Outpatient Care Program (IOCP), CareMore, HealthCare Partners Comprehensive Care Centers, UNITE HERE Health Center Special Care Center, University of New Mexico Health Sciences Center Project ECHO.

### HOME-BASED MODELS

#### Main Findings

- Home-based care models (3 RCT's; N = 2454)
  ○ This evidence is the most applicable to Veteran/military populations, as two of the three RCTs enrolled mostly White men from VA medical centers.
  ○ The risk of bias of the individual studies is unclear to high, and the strength of the overall body of evidence is moderate.
  ○ Reductions in hospital admission, hospital days, and emergency department use outcomes were inconsistent.

#### Detailed Analysis

The primary criterion for entry into all three studies of home-based care models was at least moderate impairment in activities of daily living.30,31,33 Among the three randomized controlled trials of home-based models, two31,33 examined VA Team-Managed Home-Based Primary Care (TM/HBPC), while the third evaluated a primary home care intervention in Stockholm, Sweden that recruited patients from a county general hospital.30 Together, these trials provided moderate-strength evidence that home-based intensive primary care models do not consistently statistically significantly reduce mortality, hospitalizations, hospital days, or emergency department use.

The first of the trials of VA TM/HBPC involved a six-month follow-up of 233 patients from the Hines VA Hospital in Illinois.33 The second trial involved a 12-month follow-up of 1,966 patients across 16 VA medical centers.31 In both trials, patients were primarily White men in their late sixties or early seventies. Mean Katz activity of daily living impairments were 4.5 out of a possible score of 6 in the single-center trial and 3.2 in the multi-center trial. Information about medical, psychiatric, and cognitive comorbidities was limited in both trials. In the single-center trial, 15 percent had heart disease, 13 percent had respiratory disease, and 8 percent had cerebrovascular disease. In the multi-center trial, 55 percent had any heart failure or COPD and the mean score on the Short Portable Mental Status Questionnaire was 7, indicating moderate cognitive impairment. The VA TM/HBPC model provides a comprehensive array of services in the home setting and the disciplines encompassed by the home care teams typically involve physicians, nurses, social workers, dietitians, physical and mental health therapists, pharmacists and health technicians.

The Swedish trial involved a single center, established within the Serafen Primary Care Center in Stockholm, and followed 255 patients over six months.30 The patients' mean age was 81 years, 31 percent were male and race was not reported. Patients were dependent in a mean of 2.4 personal activities of daily living according to the Katz index and were dependent in a mean of 6.0 instrumental activities of daily living according to another unvalidated index. Patients had a mean of 4.3 medical diagnoses and 22 percent had primary cardiovascular disease, but rates of other specific comorbidities were not provided. A mean score of 22.2 on the MMSE (Mini-Mental State Examination) indicates that this sample was characterized by only mild cognitive impairment and only 6 percent had any psychiatric disorders. Rate of prior hospitalization was not reported. The key feature of the intervention program was that the care was exclusively home-based, delivered by an interdisciplinary team comprised of project and team physicians, a secretary, district nurse, physiotherapist, occupational therapist, and a nurse assistant. Patients in the standard care group received continued treatment in an acute or long-stay hospital, followed by standard district nurse-administered care at home.

No trial found a statistically significant reduction in mortality. Only the Swedish trial found a statistically significant reduction in hospitalizations, hospital days, or emergency department use.30 When survivors (N=183) and decedents (N=66) were analyzed separately, there was a statistically significant reduction in long-term hospital days over six months in the survivor group, but not in the decedent group.30 However, the risk of bias of the Swedish trial was high due to the significantly higher rate of medical diagnoses in the intervention group (4.5 compared with 3.9; P=0.003). Thus, we gave more weight to the findings from the higher quality, larger, multi-center trial of VA TM/HBPC, which provided moderate-strength evidence of no significant reduction in mortality or hospitalizations, hospital days, or emergency department use.31

### PRIMARY CARE TRANSFERRED TO FREESTANDING CLINIC

#### Main Findings

- Free-standing clinic models (1 RCT/1 observational study; N=7814)
  ○ The risk of bias of the individual studies was unclear and the strength of the body of evidence was moderate.
  ○ Both studies found statistically significant reductions in hospital admission.
  ○ Applicability to the high-risk Veteran/military population is unclear. Both studies enrolled mostly elderly females. Race was 50 percent White in the PACE (Program of All-inclusive Care for the Elderly) study and not reported in the SIPA study (French acronym for System of Integrated Care for Older Persons).

#### Detailed Analysis

Two studies of freestanding clinic models targeted elderly populations, with mean ages of 80 years41 and 82 years.25,26 The characteristics, internal validity, main findings and the strength of the evidence of each study are described in detail below, but together these studies provide moderate-strength evidence that freestanding clinic models statistically significantly reduce odds of acute hospitalization by 48 percent (OR 0.52; 95% CI, 0.33 to 0.82)25,26 and any hospital use by 84 percent (OR 0.16; P=0.01; 95% CI not reported).41

The observational study was conducted in the United States and compared two-year hospital use among enrollees of the PACE model to a comparison group of similarly frail community-dwelling older adults from the Medicare Current Beneficiary Survey (MCBS). The comparison group was selected using propensity score matching on a variety of variables, including sociodemographics, need for long-term care, need for acute care, prior hospital use, market factors, geographic factors, historic variables, and mortality.41 This study involved a national, population-based sample of patients receiving care across a variety of urban and rural settings. Mean demographics after matching were age of 80 years, 74 percent female and 53 percent White. Half of patients had three or four limitations in activities of daily living and just over half had dementia (55%) and no prior hospitalization use (56%). Medical comorbidities were not reported. The PACE model fully integrates the financing and delivery of all acute and long-term services into single, full-service medical clinics across the U.S. Care management is provided collectively by a team of interdisciplinary staff, comprised of primary care physicians, nurse practitioners, onsite and home health nurses, social workers, occupational/physical therapists, dietitians, health workers, recreation therapists, and transportation workers. The comparison group was a nationally representative Medicare population whose care characteristics would be expected to reflect a broad range of Medicare-benefitted services. To minimize potential between-group differences in important patient characteristics, this study used propensity-score matching, as well as regression analysis to adjust for additional market, geographic and historical factors that could not be matched. However, this study still had an unclear risk of bias, primarily due to concerns about the validity of event ascertainment. The events were not well-defined, there was no mention of blinding of ascertainers, and no information was provided about the general reliability of the data sources. Because of the unclear risk of bias, the strength of the evidence from this study is moderate. The results of this study suggest that the PACE model effectively reduces any hospital use and number of days in the hospital per month (Table 2).

The randomized trial was conducted in Montréal and allocated 656 patients to the SIPA project and 653 to usual care. It was carried out in two public community home-care organizations in Québec.25,26 Mean follow-up was 572 days. Patients' mean age was 82 years, 29 percent were male and race was not reported. Mean number of functional limitations performed with difficulty was 3.7. Mean number of chronic diseases was 4.9, but rates of specific medical comorbidities were not reported. A minority of patients had cognitive problems (31% had a score ≥ 3 on the Short Portable Mental Health Status) or depressive symptoms (13% had a score of ≥ 10 on the Geriatric Depression Scale). No information on prior hospitalizations was provided. In the SIPA program, full clinical responsibility was shifted to interdisciplinary teams who coordinated and delivered care from a dedicated SIPA center, including liaising with patients' regular family physicians. Key features of SIPA include comprehensive geriatric assessment upon intake; case management; maintenance of clinical responsibility both inside and outside of the hospital; care based on evidence-based, interdisciplinary protocols; and 24-hour on-call service. The interdisciplinary team was comprised of case managers, community nurses, social workers, occupational therapists, physiotherapists, homemakers, staff family physician, consultant pharmacists, and community organizers. The study publications did not specify who led the interdisciplinary team or the particular role of the case manager. The usual care group was offered usual home care services including nursing, rehabilitation, physician, personal, and social services but with limited time and availability and essentially no case management. Patients in the SIPA program had 48 percent lower odds of acute hospitalizations (95% CI, 0.33 to 0.82), but their mortality rate, hospital days and ER visits were not significantly different compared to the control group. The strength of this evidence was downgraded to moderate primarily because of unclear risk of bias due to our uncertainty about whether incomplete data were adequately handled (1% in SIPA group compared with 7% in control discontinued intervention).

### INTERDISCIPLINARY TEAM ADDED TO REGULAR PRIMARY CARE (PRACTICE-BASED MODELS)

#### Main Findings

- Practice-based models (3 RCTs/1 observational study; N=1275)
  ○ The risk of bias of the individual studies was generally high and the strength of the body of evidence was generally low.
  ○ The only evidence of significant reductions in hospitalization and/or emergency room outcomes for practice-based models comes from a randomized trial of 951 patients that evaluated the Geriatric Resources for Assessment and Care of Elders (GRACE) model and found reduced hospitalizations in year two in a high-risk subgroup (N=226) and reduced ER visits in year two in the overall and high-risk groups.
  ○ At baseline, the target population in GRACE was poor and had low access to services. Additional social work and case management services may have more impact in this setting than in the VA primary care setting, in which frequently admitted patients may already have these services.

#### Detailed Assessment

Among the four clinic-based, practice-based models, three targeted elderly high-risk populations aged either 65 years or above27-29 or aged 75 years or above,39 whereas the fourth targeted patients of any age (mean of 51 years) with a high utilization of inpatient services.32 The models were heterogeneous in terms of their interdisciplinary team staffing and the key components of the interventions. Likewise, the usual care characteristics were either variable28,29,32 or not described.27,39 The patient populations were heterogeneous in terms of their gender (proportion of males ranged from 24% to 52%), race (proportion of Whites ranged from 31% to 97%) and prevalence of diabetes (range, 26% to 51%) and heart failure (range, 13% to 15%). Patient populations also differed in their risk of mortality. In the randomized trial of Primary Intensive Care (PIC), which targeted younger patients with high inpatient service utilization, the all-cause mortality rate in the control group was 10 percent over the 12 months of follow-up,32 whereas in the two trials with 24 months of follow-up, all-cause mortality in the control group ranged from 8 percent28,29 to 17 percent.27 All-cause mortality in the control group of the observational study was 5 percent, but whether this difference is clinically meaningful is unclear as the mean follow-up period was not described and the control group patients were preferentially selected because they were deemed to be at lower risk of hospital admission.39

The risk of bias of these studies was generally high, primarily due to significant imbalances in important patient characteristics at baseline. That, coupled with their limited precision due to small sample sizes, renders their evidence to be of generally low-strength. No study found any statistically significant differences between the intervention and control groups in all-cause mortality; in most cases likely due to their small sample sizes with limited statistical power.27,32,39

Only one study found a statistically significant reduction in any hospitalization or emergency room visit.28,29 This was the randomized trial of the GRACE model of primary care, which was evaluated in 951 low-income seniors across six community-based health centers in Indianapolis, Indiana.28,29 The majority of patients were women (76%) and Black (59%), with a mean age of 72 years. Just under half of patients were living alone, and mean scores on measures of both basic and instrumental activities of daily living suggested many patients were having at least a little to a lot of difficulty. In terms of medical comorbidities, 81 percent had hypertension, 34 percent had diabetes, 22 percent had chronic lung disease, and 13 percent had heart failure. The mean number of hospitalizations in the prior six months was 0.2. Few patients had significant depression or dementia. One of the key features of the GRACE model is that it is practice-based, meaning that it is fully integrated into patients' existing primary care providers' practices. Participating primary care practices employ a GRACE support team, consisting of an advanced practice nurse and social worker, who collaborate with the primary care physician and the interdisciplinary team to develop and implement individualized care plans. The control group received usual care, with access to all standard primary and specialty care services. In addition to the primary analysis of the full sample of 951 patients, preplanned secondary analyses were conducted in a subgroup of 226 patients who were at high-risk of hospitalizations (PRA [Probability of Repeat Admission] score of 0.4 or higher). For hospitalizations per-1000 patients, there was a statistically significant reduction in year two in the high-risk subgroup (396 compared with 705; P=0.03), but not for the full sample (Table 2). For emergency department visits, there were statistically significant reductions both in the full sample (643 compared with 841; P=0.01) and the high-risk subgroup (848 compared with 1314; P=0.03). For the full sample, the strength of evidence was downgraded to moderate due to the unclear risk of bias resulting from uncertainty about use of adequate allocation concealment methods and the significantly lower rate of county medical assistance use in the GRACE intervention group at baseline (83.7% compared with 89.0%; P=0.02). However, for the subgroup of high-risk patients, the strength of evidence was further downgraded to low, due to our complete uncertainty about the comparability of baseline characteristics between the GRACE and control groups. As baseline characteristics were not provided for the high-risk subgroup, we can't rule out that potential differences in patient characteristics may have mediated the positive effect of the GRACE intervention on hospital utilization outcomes.

## LIMITATIONS

The lack of a standard taxonomy for describing models of intensive primary care in the literature made this topic particularly difficult to search for. Although we attempted to use an exhaustive list of search terms, our search may have missed some relevant studies. The applicability of the evidence on the clinic-based models to the highest risk Veteran population is unclear as the study samples were comprised mostly of females who were 72 years of age and older. The study settings were largely limited to urban locations, and they do not provide much information about the effectiveness of such intensive primary care programs in other healthcare environments. It was impossible to distinguish the effects of specific model components, such as composition of the interdisciplinary team, due to limitations in the descriptions of the programs and their heterogeneity.

Additionally, there are some general methodological limitations of this Evidence Brief associated with streamlining the traditional systematic review methods in order to synthesize the evidence within a shortened timeframe of two months. One main limitation is that the findings of this review relate to a narrower range of outcomes than may be of interest to broader audiences of healthcare providers and policymakers. Within the given timeframe, we could only adequately evaluate a limited number of effectiveness outcomes including mortality, hospitalizations, hospital days and emergency room use. Additionally, we must acknowledge the potential biases that may have been introduced by excluding studies published in languages other than English, and from generally employing only one reviewer for the majority of study selection and assessment of overall strength of evidence. Brief or rapid review methodology is still developing and there is not yet consensus on what represents best practice.

## CONCLUSIONS

- No program evaluated in this review statistically significantly reduced mortality.
- No program evaluated in this review reported any statistically significant unintended harms. Only one small controlled observational study with high risk of bias reported a clinically significantly higher rate of all-cause mortality in the intervention group (15% compared with 5%), but the difference was not statistically significant due to the small sample size (N=59).
- Evidence from home-based models is most applicable to Veteran/military populations, but found inconsistent reductions in hospitalization, hospital days and emergency department use outcomes.
- The best evidence of the effectiveness of any intensive primary care program comes from the PACE (Program of All-Inclusive Care for the Elderly) model, which uses a free-standing clinic approach and statistically significantly reduced two-year hospital use and days in hospital per month. However, patients in this study were mostly women in their eighties and it is unclear how applicable this evidence is to the target high-risk Veteran/military population.
- The only model that specifically focused on patients with high utilization of inpatient services was the Primary Intensive Care (PIC) model. But, the best evidence available to evaluate this model was low strength as it was limited to one randomized trial of 96 patients with a high risk of bias and it did not find statistically significant reductions in hospitalizations, hospital days or emergency department use.
- The best evidence of the effectiveness of practice-based models comes from the GRACE program, which found a statistically significant reduction in emergency room visits per-1,000 patients in year two. However, the study sample was mostly Black women in their seventies who had a broad range of baseline predicted risk of hospitalization and a lower level of social and clinical services than many (but not all) VA patients. Therefore, it is unclear how applicable this evidence is to the target high-risk Veteran/military population.

## APPENDIX A ADDITIONAL INTENSIVE PRIMARY CARE PROGRAMS WITHOUT PUBLISHED EVALUATIONS

After Discharge Management of Low Income Frail Elderly (AD-LIFE)

Characteristic | Details
Implementation date | 2007
Setting | Summa Health System in Akron, Ohio
Role of regular primary care physician | Primary care physician is paid to participate in a face-to-face office visit during which the nurse case manager presents the care plan to the patient.
Patient population | ≥ 65 years old, confirmed or probable dual eligible (Medicare and Medicaid), have at least 1 chronic illness (i.e., chronic obstructive pulmonary disease, diabetes, cerebrovascular accident, coronary artery disease, hypertension, congestive heart failure, osteoporosis, osteoarthritis), and at least 1 impaired ADL or 2 impaired instrumental activities of daily living (IADL), and must be discharged home
Interdisciplinary team members | Geriatrics-certified advanced practice nurse (APN) and nurse case manager (CM)-led. Core team additionally includes a geriatrician, a social worker from the Area Agency on Aging (AAoA), and a geriatrics-certified pharmacist. Extended team experts, who participate as needed, include a psychologist, cardiologist, pulmonologist, endocrinologist, and occupational therapist
Program components | APN contact within 48 hours of discharge. APN and nurse CM perform comprehensive in-home assessment and delineate patient goals of care within 7 days of discharge. Interdisciplinary team generates individualized care plan. Nurse CM facilitates implementation of the care plan with regular and frequent follow-up. Other features include community linkages, effective self-management support, organizational structure, leadership, incentives and resources, evidence-based decision support, improved information systems.
Data on mortality, hospital admission/readmission, hospital days, emergency department visits | Data not yet available. Randomized controlled trial is still ongoing.
Program information | Allen KR, Hazelett SE, Jarjoura D, et al. The after discharge care management of low income frail elderly (AD-LIFE) randomized trial: theoretical framework and study design. Popul Health Manag. Jun 2011;14(3):137-142. Wright K, Hazelett S, Jarjoura D, Allen K. The AD-LIFE trial: working to integrate medical and psychosocial care management models. Home Healthc Nurse. May 2007;25(5):308-314.

AtlantiCare Special Care Center Ambulatory Intensive Care Unit

Characteristic | Details
Implementation date | 2007
Setting | Dedicated clinic in Atlantic City
Role of regular primary care physician | Not described
Patient population | High-risk patients—those with chronic illnesses or socioeconomic issues that contribute to high healthcare usage
Interdisciplinary team members | Two physicians (one who serves as medical director); a registered nurse (RN); a social worker who manages the clinic; and a team of community health workers, known as health coaches, supervised by the RN
Program components | Not described
Data on mortality, hospital admission/readmission, hospital days, emergency department visits | Not described
Program information | http://pweb1.rwjf.org/reports/grr/056351.htm

Boeing Intensive Outpatient Care Program (IOCP), Seattle, Regence BlueShield of Washington

Characteristic | Details
Implementation date | 2007
Setting | Three physician groups in Seattle, Washington: Everett Clinic, Valley Medical Center IPA, and Virginia Mason Medical Center
Role of regular primary care physician | Prior PCP maintained in 1 clinic; care transferred to new PCP in other 2 clinics
Patient population | Complex patients identified through claims-based algorithms
Interdisciplinary team members | PCP-led, dedicated RN care manager, specialists
Program components | Individual care plan “executed through intensive in-person, telephonic and email contacts – including frequent proactive outreach by an RN, education in self-management of chronic conditions, rapid access to and care coordination by the IOCP team, daily team planning huddles to plan patient interactions, and direct involvement of specialists in primary care contacts, including behavioral health when feasible.”
Data on mortality, hospital admission/readmission, hospital days, emergency department visits | Hospital admissions reduced by 28% over 12 months in 276 patients, compared to a control group of non-participating Boeing-insured that were propensity-score matched based on health spending risk factors. Blog and slides lacked adequate detail to assess validity of methods.
Program information | http://healthaffairs.org/blog/2009/10/20/are-higher-value-care-models-replicable/ http://www.leg.wa.gov/JointCommittees/HRI/Documents/Sept2010/PracticeInnovations.pdf

CareMore, Medicare Advantage Plan HMO

Characteristic | Details
Implementation date | 1993
Setting | Dedicated facilities in California, Arizona and Nevada
Role of regular primary care physician | Patients maintain relationships with their regular primary care physicians, with the Care Center providing enhanced wrap-around care when needed
Patient population | Frail population, 20% of patients who account for 60% of costs
Interdisciplinary team members | RN's, medical assistants, social workers, podiatrists, behavioral health professionals and MD ‘extensivists’
Program components | MD ‘extensivist’-led, “who visit members in the hospital, but also provide preoperative and post-hospital care”; frequent evaluation and follow-up from a multidisciplinary team; electronic health record system to facilitate communication with CareMore providers and community PCP's.
Data on mortality, hospital admission/readmission, hospital days, emergency department visits | Compared to overall Medicare population, lower hospital readmission rates (13.6% vs 20%) and 63% fewer hospital bed days
Program information | http://www.chcf.org/~/media/MEDIA%20LIBRARY%20Files/PDF/C/PDF%20CINQtrMtngReportJun2012.pdf

HealthCare Partners Comprehensive Care Centers

Characteristic | Details
Implementation date | Not described
Setting | Physician-owned medical group and Independent Practice Association (IPA) serving greater Los Angeles and Orange Counties with 600,000+ members insured through commercial plans, Medicare Advantage and many other Medicare and PPO patients
Role of regular primary care physician | Not described
Patient population | High-risk patients; “the 5% of patients who generate 55% of all hospitalizations”; selection process not described
Interdisciplinary team members | MD/NP/PA, nurses, care managers, social workers, and medical assistants
Program components | Offer longer comprehensive visits and take on role of primary provider; closely integrated into community resources and physician offices.
Data on mortality, hospital admission/ readmission, hospital days, emergency department visits | Compared to pre-enrollment, downward trend in hospital days per 1,000 over 12 months post-enrollment (-18.3% to -24.5%; P-value not reported). Sources lacked adequate detail to assess validity of methods.
Program information | http://www.chcf.org/~/media/MEDIA%20LIBRARY%20Files/PDF/C/PDF%20CINQtrMtngReportJun2012.pdf http://www.chcf.org/~/media/MEDIA%20LIBRARY%20Files/PDF/C/PDF%20CINQtrMtngReportOct2011.pdf

UNITE HERE Health Center Special Care Center, New York City

Characteristic | Details
Implementation date | May 2006
Setting | Dedicated clinic in New York City
Role of regular primary care physician | Not described
Patient population | Low-income, largely immigrant population experiencing a high rate of chronic disease
Interdisciplinary team members | 140 staff and providers, including 15 bilingual primary care and OB/Gyn providers; 38 part-time physician specialists; 84 bilingual administrative and support staff including 17 patient care assistants, and 6 health coaches
Program components | Team-based care. Assignment of health coach to deliver education and provide close and continuous follow-up. Routine care is streamlined via use of IT resources and increased reliance on well-trained medical assistants. Physicians and nurse practitioners' services reserved for patients' clinical needs.
Data on mortality, hospital admission/readmission, hospital days, emergency department visits | Not described
Program information | http://futurehealth.ucsf.edu/Public/Publications-and-Resources/Content.aspx?topic=UNITE_HERE_Health_Center—Pioneering_the_Ambulatory_Intensive_Caring%20Unit http://www.newyorker.com/reporting/2011/01/24/110124fa_fact_gawande

University of New Mexico Health Sciences Center Project ECHO (Extension for Community Healthcare Outcomes)

Characteristic | Details
Implementation date | In progress; in May 2012 awarded 3-year U.S. Department of Health and Human Services (HHS) Health Care Innovation awards
Setting | Rural and underserved communities in New Mexico and Washington State
Role of regular primary care physician | Not described
Patient population | 5,000 high-cost, high-utilization, high-severity patients with multiple chronic diseases
Interdisciplinary team members | Community-based providers and a team of university medical center-based primary care “intensivists” trained to care for patients with multiple chronic diseases
Program components | Weekly telemedicine clinics, conducted in the manner of grand rounds to help increase community-based primary care physicians' capacity to treat and manage complex patients
Data on mortality, hospital admission/readmission, hospital days, emergency department visits | Not applicable, project in process
Program information | http://hscapp.unm.edu/calendar/output/index.cfm?fuseaction=main.release&EntryID=10679

Search Methods
- Phrases
  - “Patient care management”
  - “Patient care team”
  - “Home care services”
  - “PACE”
  - “program of all inclusive care for the elderly”
  - “team-managed home based primary care”
  - “intensive primary care”
  - “home based primary care”
  - “interdisciplinary home based primary care program”
  - “Primary care intensivist”
  - “primary care medical home”
  - “patient-centered medical home”
  - “complex care medical home”
  - “ambulatory intensive care unit”
  - “intensive outpatient care program”
  - “coordinated care model”
  - “chronic care model”
  - “accountable care organizations”
- Sources
  - Google
  - Google Scholar
  - AHRQ: evidence reports and technology assessments, USPSTF recommendations, and related DEcIDE projects
    http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/
    http://www.ahrq.gov/clinic/uspstf/uspstopics.htm
    http://www.ncbi.nlm.nih.gov/books
    https://www.kpchr.org/MMA/system/login.aspx
    http://mc.manuscriptcentral.com/ehc
  - NICE Guidelines
    http://guidance.nice.org.uk/
  - NHS Evidence
    http://www.evidence.nhs.uk/default.aspx
  - Cochrane Reviews and Protocols
    http://www.thecochranelibrary.com/view/0/index.html
  - DERP Drug Class Reviews
    http://derp.ohsu.edu/about/final-products.cfm
    http://derp.ohsu.edu/about/draft-products.cfm
  - HTA (CRD database): Health Technology Assessments
    http://www.crd.york.ac.uk/CMS2Web/
  - VA Products - VATAP, PBM and HSR&D publications
    http://www.hsrd.research.va.gov/research/default.cfm
    http://www4.va.gov/vatap/publications.htm
  - NIH Consensus Statement
    http://consensus.nih.gov/previous.htm
    http://consensus.nih.gov/historical.htm
  - CDC Community Guide
    http://www.thecommunityguide.org/index.html
  - CMS Policies
    http://www.cms.gov/
  - CADTH
    http://www.cadth.ca/index.php/en/hta/reports-publications/search
  - UBC Centre for Health Services and Policy Research
    http://chspr.ubc.ca/publications
  - Institute for Clinical Evaluative Sciences
    http://www.ices.on.ca/
  - WHO Health Evidence Network
    http://www.euro.who.int/en/what-we-do/data-and-evidence/health-evidence-network-hen/publications/by-keyword
  - ECRI Institute
    https://www.ecri.org/Pages/default.aspx
  - Bandolier
    http://www.medicine.ox.ac.uk/bandolier/
  - Health Technology Assessment International meta search
    http://www.htai.org/index.php?id=226
  - PubMed health
    http://www.ncbi.nlm.nih.gov/pubmedhealth/
  - PROSPERO
    http://www.crd.york.ac.uk/prospero/
  - Campbell Collaboration
    http://www.campbellcollaboration.org/
  - Institute of Medicine
    http://www.iom.edu/
  - DoPHER
    http://eppi.ioe.ac.uk/webdatabases/Intro.aspx?ID=2
  - Robert Wood Johnson Foundation
    http://www.rwjf.org/

## REFERENCES

1 National Advisory Council. (2012). Trends in Healthcare Costs and the Concentration of Medical Expenditures.
2 Hackbarth G, Reischauer RD, Miller ME. (2007). Report to the Congress: Promoting Greater Efficiency in Medicare.
3 Wasson JH, Sauvigne AE, Mogielnicki RP, et al. (1984). Continuity of Outpatient Medical Care in Elderly Men. JAMA: the journal of the American Medical Association.
4 Nutting PA, Miller WL, Crabtree BF, Jaen CR, Stewart EE, Stange KC. (2009). Initial lessons from the first national demonstration project on practice transformation to a patient-centered medical home. Ann Fam Med.
5 Kilo CM, Wasson JH. (2010). Practice redesign and the patient-centered medical home: history, promises, and challenges. Health Aff (Millwood).
6 Jackson GL, Powers BJ, Chatterjee R, et al. (2013). The Patient-Centered Medical Home, A Systematic Review. Annals of Internal Medicine.
7 Nelson L. (2012). Lessons from Medicare's Demonstration Projects on Disease Management, Care Coordination, and Value-Based Payment.
8 Hickam DH, Weiss JW, Guise J-M, et al. (2013). Outpatient Case Management for Adults with Medical Illness and Complex Care Needs.
9 Mitchum R. Building a New Marcus Welby To Cut Costs Science Life 2012; A blog ofnews and ideas in biomedicine.
10 Dessein W, Santos T. (2006). Adaptive Organizations. Journal of Political Economy.
11 Meltzer D, Best T. (2012). Discrete Event Simulation of a Comprehensive Care Physicians (CCP) Model [slideset].
12 Centers for Medicare & Medicaid Services: Center for Medicare & Medicaid Innovation. (2012). Comprehensive Primary Care Initiative.
13 Yee T, Lechner A, Carrier E. (2012). High-Intensity Primary Care: Lessons for Physician and Patient Engagement.
14 Higgins JPT, Altman D, Antes G, et al. (2008). Chapter 8: Assessing risk of bias in included studies.
15 McDonagh M, Jonas D, Gartlehner G, et al. (2012). Methods for the Drug Effectiveness Review Project. BMC Medical Research Methodology.
16 Owens DK, Atkins D, Treadwell JR, et al. (2010). AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. Journal of Clinical Epidemiology.
17 Fan VS, Gaziano JM, Lew R, et al. (2012). A Comprehensive Care Management Program to Prevent Chronic Obstructive Pulmonary Disease Hospitalizations. Annals of Internal Medicine.
18 Assyag P, Renaud T, Cohen-Solal A, et al. (2009). RESICARD: East Paris network for the management of heart failure: absence of effect on mortality and rehospitalization in patients with severe heart failure admitted following severe decompensation. Arch Cardiovasc Dis.
19 Berger R, Moertl D, Peter S, et al. (2010). N-terminal pro-B-type natriuretic peptide-guided, intensive patient management in addition to multidisciplinary care in chronic heart failure a 3-arm, prospective, randomized pilot study. J Am Coll Cardiol.
20 Del Sindaco D, Pulignano G, Minardi G, et al. (2007). Two-year outcome of a prospective, controlled study of a disease management programme for elderly patients with heart failure. J Cardiovasc Med (Hagerstown).
21 Kasper EK, Gerstenblith G, Hefter G, et al. (2002). A randomized trial of the efficacy of multidisciplinary care in heart failure outpatients at high risk of hospital readmission. J Am Coll Cardiol.
22 McAlister FA, Stewart S, Ferrua S, McMurray JJ. (2004). Multidisciplinary strategies for the management of heart failure patients at high risk for admission: a systematic review of randomized trials. J Am Coll Cardiol.
23 Stewart S, Carrington MJ, Marwick T, et al. (2011). The WHICH? trial: rationale and design of a pragmatic randomized, multicentre comparison of home- vs. clinic-based management of chronic heart failure patients. Eur J Heart Fail.
24 Stewart S, Carrington MJ, Marwick T, et al. (2012). Impact of Home Versus Clinic-Based Management of Chronic Heart Failure: The WHICH? (Which Heart Failure Intervention Is Most Cost-Effective & Consumer Friendly in Reducing Hospital Care) Multicenter, Randomized Trial. Journal of the American College of Cardiology.
25 Beland F, Bergman H, Lebel P, et al. (2006). A system of integrated care for older persons with disabilities in Canada: results from a randomized controlled trial. J Gerontol A Biol Sci Med Sci. Apr.
26 Bergman H, Beland F, Lebel P, et al. (1997). Care for Canada's frail elderly population: Fragmentation or integration. Canada Medical Association Journal.
27 Coleman EA, Grothaus LC, Sandhu N, Wagner EH. (1999). Chronic care clinics: a randomized controlled trial of a new model of primary care for frail older adults. J Am Geriatr Soc.
28 Counsell SR, Callahan CM, Buttar AB, Clark DO, Frank KI. (2006). Geriatric Resources for Assessment and Care of Elders (GRACE): A New Model of Primary Care for Low-Income Seniors. J Am Geriatr Soc.
29 Counsell SR, Callahan CM, Clark DO, et al. (2007). Geriatric care management for low-income seniors: a randomized controlled trial. JAMA.
30 Melin AL. (1995). A randomized trial of multidisciplinary in-home care for frail elderly patients awaiting hospital discharge. Aging (Milan, Italy).
31 Hughes SL, Weaver FM, Giobbie-Hurder A, et al. (2000). Effectiveness of team-managed home-based primary care: a randomized multicenter trial. JAMA.
32 Sledge WH, Brown KE, Levine JM, et al. (2006). A randomized trial of primary intensive care to reduce hospital admissions in patients with high utilization of inpatient services. Dis Manag.
33 Hughes SL, Cummings J, Weaver F, Manheim LM, Conrad KJ, Nash K. (1990). A Randomized Trial of Veterans Administration Home Care for Severely Disabled Veterans. Med Care.
34 Beales JL, Edes T. (2009). Veteran's Affairs Home Based Primary Care. Clin Geriatr Med.
35 Anetzberger GJ, Stricklin ML, Gauntner D, Banozic R, Laurie R. (2006). VNA HouseCalls of greater Cleveland, Ohio: development and pilot evaluation of a program for high-risk older adults offering primary medical care in the home. Home Health Care Serv Q.
36 Brown KE, Levine JM, Fiellin DA, O'Connor P, Sledge WH. (2005). Primary intensive care: pilot study of a primary care-based intervention for high-utilizing patients. Dis Manag.
37 Chang C, Jackson SS, Bullman TA, Cobbs EL. (2009). Impact of a home-based primary care program in an urban Veterans Affairs medical center. Journal of the American Medical Directors Association.
38 Ginsburg IF, Eng C. (2009). On-site mental health services for PACE (Program of All-inclusive Care for the Elderly) centers. J Am Med Dir Assoc.
39 Jiwa M, Gerrish K, Gibson A, Scott H. (2002). Preventing avoidable hospital admission of older people. Br J Community Nurs.
40 Landi F, Gambassi G, Pola R, et al. (1999). Impact of integrated home care services on hospital use. J Am Geriatr Soc.
41 Meret-Hanke LA. (2011). Effects of the Program of All-inclusive Care for the Elderly on hospital use. Gerontologist.
42 North L, Kehm L, Bent K, Hartman T. (2008). Can home-based primary care cut costs. Nurse Practitioner.
43 Rosenberg T. (2012). Acute Hospital Use, Nursing Home Placement, and Mortality in a Frail Community-Dwelling Cohort Managed with Primary Integrated Interdisciplinary Elder Care at Home. Journal of the American Geriatrics Society.
44 Vedel I, De Stampa M, Bergman H, et al. (2009). A novel model of integrated care for the elderly: COPA, Coordination of Professional Care for the Elderly. Aging Clinical & Experimental Research.
45 Weaver FM, Hickey EC, Hughes SL, et al. (2008). Providing all-inclusive care for frail elderly veterans: evaluation of three models of care. J Am Geriatr Soc.
46 Wieland D, Lamb VL, Sutton SR, et al. (2000). Hospitalization in the Program of All-Inclusive Care for the Elderly (PACE): rates, concomitants, and predictors. J Am Geriatr Soc.

## SUPPLEMENTAL MATERIALS

The following supplemental materials are available on the ESP website with this Evidence Brief at this link:

1. Search Strategy
2. List of Excluded Studies
3. Controlled Studies: Complete Risk of Bias Assessment
4. Uncontrolled Studies: Characteristics
5. Uncontrolled Studies: Results

### SEARCH STRATEGY

MEDLINE (PubMed) searched 9/5/2012

Concept | MeSH | “natural language”
Population N=1061387 | Comorbidity/ Frail elderly/ | “high risk of hospitalization” Multimorbidity Comorbidity “frail elderly”
Population N=1061387 | Comorbidity/ Frail elderly/ | “high utilizers” “highest utilizers” “sickest patients” “complex patients” “High risk patients” “critically ill population”
Population N=1061387 | Comorbidity/ Frail elderly/ | (“high OR highest OR sick OR sickest OR complex OR “high risk” OR high-risk” OR “critically ill”) AND (“utilize” OR utilizers OR patient OR patients OR population OR populations) [title]
Intervention N=518713 | Patient care management/ Patient care team/ Home care services/ | “Patient care management” “Patient care team” “Home care services” “PACE” “program of all inclusive care for the elderly”
Intervention N=518713 | Patient care management/ Patient care team/ Home care services/ | “team-managed home based primary care” “intensive primary care” “intensive primary care” “home based primary care” “interdisciplinary home based primary care program” “Primary care intensivist”
Intervention N=518713 | Patient care management/ Patient care team/ Home care services/ | (“team managed” OR “team-managed” OR “team based” OR “team-based” OR “home based” OR home-based OR intensive OR interdisciplinary OR multidisciplinary OR intensivist OR “all inclusive”) AND (“primary care”) [title]
Comparators
Outcomes N=242535 | Hospitalization/ Patient readmission/ | Hospitalization
Outcomes N=242535 | Hospitalization/ Patient readmission/ | “Hospital use” “patient readmission” “hospital readmission” “Urgent care utilization” “Emergency department utilization”
Outcomes N=242535 | Hospitalization/ Patient readmission/ | (hospital OR patient OR “urgent care” OR “emergency department” OR ER) AND (use OR readmission OR admission OR utilization) [title]
Limits N=4119 | English Not Children
VA Only N=197 (after deduplication) | | ((“Veterans Health”[Mesh])) OR (((VA OR Veteran OR VAMC OR Veterans)) OR (“Veterans”[Mesh] OR “United States Department of Veterans Affairs”[Mesh] OR “Hospitals, Veterans”[Mesh]))
Study type | Systematic Review N=272 (after deduplication) | PubMed SR hedge
| RCT N=898 (after deduplication) | ((((((((groups[tiab])) OR (trial[tiab])) OR (randomly[tiab])) OR (drug therapy[sh])) OR (placebo[tiab])) OR (randomized[tiab])) OR (controlled clinical trial [pt])) OR (randomized controlled trial[pt])
| Case Control N=510 (after deduplication) | “Case-Control Studies”[Mesh] OR “Control Groups”[Mesh] OR (case[TIAB] AND control[TIAB]) OR (cases[TIAB] AND controls [TIAB]) OR (cases[TIAB] AND controlled[TIAB]) OR (case[TIAB] AND comparison*[TIAB]) OR (cases[TIAB] AND comparison* [TIAB]) OR “control group”[TIAB] OR “control groups”[TIAB]
| Program Evaluation N=754 (after deduplication) | evaluation studies[pt] OR evaluation studies as topic[mesh] OR program evaluation[mesh] OR validation studies as topic [mesh] OR (effectiveness[tiab] OR (pre-[tiab] AND post-[tiab])) OR (program* [tiab] AND evaluat*[tiab]) OR intervention* [tiab]

CINAHL(EBSCO) searched 9/5/2012

Concept | Search
Population N=41280 | (MH “Comorbidity”) OR “comorbidity” OR (MH “Frail Elderly”) OR “frail elderly” OR “high risk of hospitalization” OR “risk of hospitalization” OR “High utilizers” OR “highest utilizers” OR “sickest patients” OR “complex patients” OR “high risk patients” OR “critically ill population” OR (MH “Critically I11 Patients”)
Intervention N=52136 | “patient care management” OR (MH “Multidisciplinary Care Team+”) OR “patient care team” OR (MH “Home Health Care+”) OR “home care services” OR patient care management” OR “program of all inclusive care for the elderly” OR “team managed home based primary care” OR “intensive primary care” OR “home based primary care” OR “interdisciplinary home based primary care program” OR “primary care intensivist”
Outcomes N=67849 | (MH “Hospitalization+”) OR “hospitalization” OR (MH “Readmission”) OR “patient readmission” OR “hospital use” OR “hospital readmission” OR (MH “Health Resource Utilization”) OR “urgent care utilization” OR “emergency department utilization” OR (MH “Emergency Service/UT”)
(Population AND Intervention AND Outcome) limited to English deduplicated with previous searches N=164

Cochrane Registry of Controlled Trials searched 9/5/2012

Concept | Search
Population N=4968 | 1. comorbidity.mp. or exp Comorbidity/; 2. frail elderly.mp. or exp Frail Elderly/; 3. high risk of hospitalization.mp.; 4. multimorbidity.mp.; 5. high utilizers.mp.; 6. highest utilizers.mp.; 7. sickest patients.mp.; 8. complex patients.mp.; 9. high risk patients.mp.; 10. critically ill population.mp.; 11. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10
Intervention N= 11264 | 12 patient care management.mp. or exp Patient Care Management/; 13 patient care team.mp. or exp Patient Care Team/; 14 home care services/; 15 program of all inclusive care for the elderly.mp.; 16 team managed home based primary care.mp.; 17 intensive primary care.mp.; 18 home based primary care.mp.; 19 interdisciplinary home based primary care program.mp.; 20 primary care intensivist.mp.; 21 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20
Outcomes N= 12295 | 22 exp Hospitalization/ or Hospitalization.mp.; 23 patient readmission.mp. or exp Patient Readmission/; 24 hospital readmission.mp.; 25 urgent care utilization.mp; 26 emergency department utilization.mp.; 27 22 or 23 or 24 or 25 or 26 (12295)
(Population AND Intervention AND Outcome) limited to English deduplicated with previous searches N=10

### LIST OF EXCLUDED STUDIES

Publications excluded at the full-text level

Publication | Reason for exclusion
Allen KR, Hazelett SE, Jarjoura D, et al. The after discharge care management of low income frail elderly (AD-LIFE) randomized trial: theoretical framework and study design. Popul Health Manag. Jun 2011;14(3): 137-142. | Ongoing study: Results not yet available
Wright K, Hazelett S, Jarjoura D, Allen K. The AD-LIFE trial: working to integrate medical and psychosocial care management models. Home Healthc Nurse. May 2007;25(5):308-314. | Ongoing study: Results not yet available
DM for complex patients tackles hospital utilization in a big way. Dis Manag Advis. Vol 9. 2003/08/19 ed2003:99-101, 93. | Wrong publication type
Benedict L, Robinson K and Holder C. Clinical nurse specialist practice within the Acute Care for Elders interdisciplinary team model. Clin Nurse Spec. Vol 20. 2006/09/19 ed2006:248-51. | Wrong publication type
Berkowitz R, Blank LJ and Powell SK. Strategies to reduce hospitalization in the management of heart failure. Lippincotts Case Manag. Vol 10. 2005/11/30 ed2005:S1-15; quiz S16-7. | Wrong publication type
Bernabei R, Landi F, Zuccala G. Health care for older persons in Italy. Aging Clin Exp Res. Aug 2002; 14(4):247-251. | Wrong publication type
Carpenter I, Gambassi G, Topinkova E, et al. Community care in Europe. The Aged in Home Care project (AdHOC). Aging Clin Exp Res. Vol 16. 2004/12/04 ed2004:259-69. | Wrong publication type
Chan DC, Heidenreich PA, Weinstein MC and Fonarow GC. Heart failure disease management programs: a cost-effectiveness analysis. Am Heart J. Vol 155. 2008/01/25 ed2008:332-8. | Wrong publication type
Cooper DF, Granadillo OR, Stacey CM. Home-based primary care: the care of the veteran at home. Home Healthc Nurse. May 2007;25(5):315-322. | Wrong publication type
De Keulenaer GW and Brutsaert DL. Urgent need to reorganize heart failure management: from paradoxes to heart failure clinics. Acta Cardiol. Vol 60. 2005/05/13 ed2005:179-84. | Wrong publication type
Hughes S, Weaver F, Manheim L, Hurder A, Kubal J, Ulasevich A. Cost-effectiveness of team-managed home care in the VA: an update from a multi-site randomized trial [abstract]. Abstract Book/Association for Health Services Research. 1997;14:110-111. | Wrong publication type
Roland M. Improving management of chronic illness: better identification of effective interventions for high risk patients is needed. Chronic Illn. Vol 3. 2007/12/18 ed2007:196. | Wrong publication type
Smith DM, Giobbie-Hurder A, Weinberger M, et al. Predicting non-elective hospital readmissions: a multi-site study. Department of Veterans Affairs Cooperative Study Group on Primary Care and Readmissions. J Clin Epidemiol. Vol 53. 2000/12/07 ed2000:1113-8. | Wrong publication type
Sacramento hospital boosts outcomes by focusing on high-risk CHF patients. Data Strateg Benchmarks. Vol 5. 2001/06/30 ed2001:68-7, 65. | Wrong intervention model
Disease management program lowers hospital readmission days: study followed chronically, critically ill patients after discharge. Case Management Advisor. Vol 182007:121-124. | Wrong intervention model
Aish H, Didsbury P, Cressey P, Grigor J and Gribben B. Primary options for acute care: general practitioners using their skills to manage “avoidable admission” patients in the community. N Z Med J. Vol 116. 2003/02/26 ed2003:U326. | Wrong intervention model
Assyag P, Renaud T, Cohen-Solal A, et al. RESICARD: East Paris network for the management of heart failure: absence of effect on mortality and rehospitalization in patients with severe heart failure admitted following severe decompensation. Arch Cardiovasc Dis. Vol 102. 2009/02/24 ed2009:29-41. | Wrong intervention model
Berger R, Moertl D, Peter S, et al. N-terminal pro-B-type natriuretic peptide-guided, intensive patient management in addition to multidisciplinary care in chronic heart failure a 3-arm, prospective, randomized pilot study. J Am Coll Cardiol. Vol 55. 2010/02/23 ed2010:645-53. | Wrong intervention model
Bernabei R, Landi F, Gambassi G, et al. Randomised trial of impact of model of integrated care and case management for older people living in the community. BMJ. Vol 316. 1998/06/06 ed1998:1348-51. | Wrong intervention model
Bird SR, Kurowski W, Dickman GK and Kronborg I. Integrated care facilitation for older patients with complex health care needs reduces hospital demand. Aust Health Rev. Vol 31. 2007/08/03 ed2007:451-61; discussion 449-50. | Wrong intervention model
Boult C, Reider L, Frey K, et al. Early Effects of “Guided Care” on the Quality of Health Care for Multimorbid Older Persons: A Cluster-Randomized Controlled Trial. Journal of Gerontology. Vol 63A2008:321-327. | Wrong intervention model
Boyce PS and Feldman PH. ReACH National Demonstration Collaborative: early results of implementation. Home Health Care Services Quarterly. Vol 262007:105-120. | Wrong intervention model
Burns T, Catty J, Dash M, Roberts C, Lockwood A and Marshall M. Use of intensive case management to reduce time in hospital in people with severe mental illness: systematic review and meta-regression. BMJ. Vol 335. 2007/07/17 ed2007:336. | Wrong intervention model
Challis D, Darton R, Johnson L, Stone M and Traske K. An evaluation of an alternative to long-stay hospital care for frail elderly patients: II. Costs and effectiveness. Age Ageing. Vol 20. 1991/07/01 ed1991:245-54. | Wrong intervention model
Chan YK, Stewart S, Calderone A, et al. Exploring the potential to remain “Young @ Heart”: initial findings of a multi-centre, randomised study of nurse-led, home-based intervention in a hybrid health care system. Int J Cardiol. Vol 154. 2010/10/05 ed2012:52-8. | Wrong intervention model
Coleman EA, Wagner EH, Grothaus LC, Hecht J, Savarino J and Buchner DM. Predicting hospitalization and functional decline in older health plan enrollees: are administrative data as accurate as self-report? J Am Geriatr Soc. Vol 46. 1998/04/29 ed1998:419-25. | Wrong intervention model
Davidson PM, Cockburn J, Newton PJ, et al. Can a heart failure-specific cardiac rehabilitation program decrease hospitalizations and improve outcomes in high-risk patients? Eur J Cardiovasc Prev Rehabil. Vol 17. 2010/05/26 ed2010:393-402. | Wrong intervention model
Dawson JI and Critchley L. Community-hospital partnerships. The Quick Response Team. J Nurs Adm. Vol 22. 1992/11/01 ed1992:33-9. | Wrong intervention model
Del Sindaco D, Pulignano G, Minardi G, et al. Two-year outcome of a prospective, controlled study of a disease management programme for elderly patients with heart failure. J Cardiovasc Med (Hagerstown). Vol 8. 2007/04/20 ed2007:324-9. | Wrong intervention model
Dieterich M, Irving CB, Park B and Marshall M. Intensive case management for severe mental illness. Cochrane Database Syst Rev. 2010/10/12 ed2010:CD007906. | Wrong intervention model
Douglas SL, Daly BJ, Kelley CG, O'Toole E and Montenegro H. Chronically critically ill patients: health-related quality of life and resource use after a disease management intervention. Am J Crit Care. Vol 16. 2007/08/29 ed2007:447-57. | Wrong intervention model
Fan VS, Gaziano JM, Lew R, et al. A Comprehensive Care Management Program to Prevent Chronic Obstructive Pulmonary Disease Hospitalizations. Annals of Internal Medicine. Vol 1562012. | Wrong intervention model
Freund T, Peters-Klimm F, Rochon J, et al. Primary care practice-based care management for chronically ill patients (PraCMan): study protocol for a cluster randomized controlled trial [ISRCTN56104508]. Trials. Vol 12. 2011/07/01 ed2011:163. | Wrong intervention model
Friedhoff SG Intensive case management of high-risk patients in a family medicine residency setting. J Am Board Fam Pract. Vol 12. 1999/09/07 ed1999:264-9. | Wrong intervention model
Gary TL, Batts-Turner M, Bone LR, et al. A randomized controlled trial of the effects of nurse case manager and community health worker team interventions in urban African-Americans with type 2 diabetes. Control Clin Trials. Vol 25. 2004/02/26 ed2004:53-66. | Wrong intervention model
Gravelle H, Dusheiko M, Sheaff R, et al. Impact of case management (Evercare) on frail elderly patients: controlled before and after analysis of quantitative outcome data. BMJ. Vol 334. 2006/11/17 ed2007:31. | Wrong intervention model
Hastings SN and Heflin MT A systematic review of interventions to improve outcomes for elders discharged from the emergency department. Acad Emerg Med. Vol 12. 2005/10/06 ed2005:978-86. | Wrong intervention model
Hebert KA, Horswell RL, Dy S, et al. Mortality benefit of a comprehensive heart failure disease management program in indigent patients. Am Heart J. Vol 151. 2006/01/31 ed2006:478-83. | Wrong intervention model
Hemmelgarn BR, Manns BJ, Zhang J, et al. Association between multidisciplinary care and survival for elderly patients with chronic kidney disease. J Am Soc Nephrol. Vol 18. 2007/02/03 ed2007:993-9. | Wrong intervention model
Inglis S, McLennan S, Dawson A, et al. A new solution for an old problem? Effects of a nurse-led, multidisciplinary, home-based intervention on readmission and mortality in patients with chronic atrial fibrillation. J Cardiovasc Nurs. Vol 19. 2004/04/03 ed2004:118-27. | Wrong intervention model
Kasper EK, Gerstenblith G, Hefter G, et al. A randomized trial of the efficacy of multidisciplinary care in heart failure outpatients at high risk of hospital readmission. J Am Coll Cardiol. Vol 39. 2002/02/02 ed2002:471-80. | Wrong intervention model
Killaspy H, Kingett S, Bebbington P, et al. Randomised evaluation of assertive community treatment: 3-year outcomes. Br J Psychiatry. Vol 195. 2009/07/02 ed2009:81-2. | Wrong intervention model
Kim YJ and Soeken KL. A meta-analysis of the effect of hospital-based case management on hospital length-of-stay and readmission. Nurs Res. Vol 54. 2005/07/20 ed2005:255-64. | Wrong intervention model
Kimmelstiel C, Levine D, Perry K, et al. Randomized, controlled evaluation of short- and long-term benefits of heart failure disease management within a diverse provider network: the SPAN-CHF trial. Circulation. Vol 110. 2004/08/18 ed2004:1450-5. | Wrong intervention model
Lairson DR, Yoon SJ, Carter PM, et al. Economic evaluation of an intensified disease management system for patients with type 2 diabetes. Dis Manag. Vol 11. 2008/04/09 ed2008:79-94. | Wrong intervention model
Landi F, Lattanzio F, Gambassi G, et al. A model for integrated home care of frail older patients: The Silver Network project. Aging Clinical & Experimental Research. Vol 111999:262-272. | Wrong intervention model
Landi F, Onder G, Russo A, et al. A new model of integrated home care for the elderly: impact on hospital use. J Clin Epidemiol. Vol 54. 2001/08/25 ed2001:968-70. | Wrong intervention model
Latour CH, van der Windt DA, de Jonge P, et al. Nurse-led case management for ambulatory complex patients in general health care: a systematic review. J Psychosom Res. Vol 62. 2007/02/28 ed2007:385-95. | Wrong intervention model
Leff B, Reider L, Frick KD, et al. Guided care and the cost of complex healthcare: a preliminary report. Am J Manag Care. Vol 15. 2009/08/13 ed2009:555-9. | Wrong intervention model
Leveille SG, Wagner EH, Davis C, et al. Preventing disability and managing chronic illness in frail older adults: a randomized trial of a community-based partnership with primary care. J Am Geriatr Soc. Vol 46. 1998/10/20 ed1998:1191-8. | Wrong intervention model
Lynch JP, Forman SA, Graff S and Gunby MC. High-risk population health management--achieving improved patient outcomes and near-term financial results. Am J Manag Care. Vol 6. 2000/11/07 ed2000:781-91. | Wrong intervention model
Martin-Lesende I, Orruno E, Cairo C, et al. Assessment of a primary care-based telemonitoring intervention for home care patients with heart failure and chronic lung disease. The TELBIL study. BMC Health Serv Res. Vol 11. 2011/03/10 ed2011:56. | Wrong intervention model
Mattke S, Seid M and Ma S. Evidence for the effect of disease management: is $1 billion a year a good investment? Am J Manag Care. Vol 13. 2007/12/12 ed2007:670-6. | Wrong intervention model
McAlister FA, Stewart S, Ferrua S and McMurray JJ. Multidisciplinary strategies for the management of heart failure patients at high risk for admission: a systematic review of randomized trials. J Am Coll Cardiol. Vol 44. 2004/08/18 ed2004:810-9. | Wrong intervention model
McDonald K, Ledwidge M, Cahill J, et al. Elimination of early rehospitalization in a randomized, controlled trial of multidisciplinary care in a high-risk, elderly heart failure population: the potential contributions of specialist care, clinical stability and optimal angiotensin-converting enzyme inhibitor dose at discharge. Eur J Heart Fail. Vol 3. 2001/03/14 ed2001:209-15. | Wrong intervention model
McDonald K, Ledwidge M, Cahill J, et al. Heart failure management: multidisciplinary care has intrinsic benefit above the optimization of medical care. J Card Fail. Vol 8. 2002/07/26 ed2002:142-8. | Wrong intervention model
Melis RJ, Adang E, Teerenstra S, et al. Cost-effectiveness of a multidisciplinary intervention model for community-dwelling frail older people. J Gerontol A Biol Sci Med Sci. Vol 63. 2008/04/01 ed2008:275-82. | Wrong intervention model
Mendoza H, Martin MJ, Garcia A, et al. ‘Hospital at home’ care model as an effective alternative in the management of decompensated chronic heart failure. Eur J Heart Fail. Vol 11. 2009/10/31 ed2009:1208-13. | Wrong intervention model
Naylor MD, Aiken LH, Kurtzman ET, Olds DM and Hirschman KB. The care span: The importance of transitional care in achieving health reform. Health Aff (Millwood). Vol 30. 2011/04/08 ed2011:746-54. | Wrong intervention model
Oddone EZ, Weinberger M, Giobbie-Hurder A, Landsman P and Henderson W. Enhanced access to primary care for patients with congestive heart failure. Veterans Affairs Cooperative Study Group on Primary Care and Hospital Readmission. Eff Clin Pract. Vol 2. 2000/01/06 ed1999:201-9. | Wrong intervention model
O'Toole TP, Pirraglia PA, Dosa D, et al. Building care systems to improve access for high-risk and vulnerable veteran populations. J Gen Intern Med. Nov 2011;26 Suppl 2:683-688. | Wrong intervention model
Pazin-Filho A, Peitz P, Pianta T, et al. Heart failure disease management program experience in 4,545 heart failure admissions to a community hospital. Am Heart J. Vol 158. 2009/08/25 ed2009:459-66. | Wrong intervention model
Peters-Klimm F, Campbell S, Hermann K, et al. Case management for patients with chronic systolic heart failure in primary care: the HICMan exploratory randomised controlled trial. Trials. Vol 11. 2010/05/19 ed2010:56. | Wrong intervention model
Phelan EA, Balderson B, Levine M, et al. Delivering effective primary care to older adults: a randomized, controlled trial of the senior resource team at group health cooperative. J Am Geriatr Soc. Vol 55. 2007/11/06 ed2007:1748-56. | Wrong intervention model
Rasekaba TM, Lim WK and Hutchinson AF. Effect of a chronic disease management service for patients with diabetes on hospitalisation and acute care costs. Aust Health Rev. Vol 36. 2012/05/26 ed2012:205-12. | Wrong intervention model
Smith AA, Carusone SB, Willison K, et al. Hospitalization and emergency department visits among seniors receiving homecare: a pilot study. BMC Geriatr. Vol 5. 2005/07/15 ed2005:9. | Wrong intervention model
Stewart S, Carrington MJ, Marwick T, et al. The WHICH? trial: rationale and design of a pragmatic randomized, multicentre comparison of home- vs. clinic-based management of chronic heart failure patients. Eur J Heart Fail. Vol 13. 2011/05/28 ed2011:909-16. | Wrong intervention model
Stewart S, Carrington MJ, Marwick T, et al. Impact of Home Versus Clinic-Based Management of Chronic Heart Failure: The WHICH? (Which Heart Failure Intervention Is Most Cost-Effective & Consumer Friendly in Reducing Hospital Care) Multicenter, Randomized Trial. Journal of the American College of Cardiology. 2012;60(14): 1239-1248. | Wrong intervention model
The WHICH? (Which Heart Failure Intervention Is Most Cost-Effective & Consumer Friendly in Reducing Hospital Care) Multicenter, Randomized Trial. Journal of the American College of Cardiology. Vol 602012:1239-1248. | Wrong intervention model
Stewart S and Horowitz JD. Detecting early clinical deterioration in chronic heart failure patients post-acute hospitalisation-a critical component of multidisciplinary, home-based intervention? Eur J Heart Fail. Vol 4. 2002/05/30 ed2002:345-51. | Wrong intervention model
Stewart S and Horowitz JD. Home-based intervention in congestive heart failure: long-term implications on readmission and survival. Circulation. Vol 1052002:2861-2866. | Wrong intervention model
Stewart S, Marley JE and Horowitz JD. Effects of a multidisciplinary, home-based intervention on unplanned readmissions and survival among patients with chronic congestive heart failure: a randomised controlled study. Lancet. Vol 354. 1999/10/06 ed1999:1077-83. | Wrong intervention model
Stewart S, Vandenbroek AJ, Pearson S and Horowitz JD. Prolonged beneficial effects of a home-based intervention on unplanned readmissions and mortality among patients with congestive heart failure. Arch Intern Med. Vol 159. 1999/02/16 ed1999:257-61. | Wrong intervention model
Stiefel F, Zdrojewski C, Bel Hadj F, et al. Effects of a multifaceted psychiatric intervention targeted for the complex medically ill: a randomized controlled trial. Psychother Psychosom. Vol 77. 2008/04/30 ed2008:247-56. | Wrong intervention model
Stott DJ, Buttery AK, Bowman A, et al. Comprehensive geriatric assessment and home-based rehabilitation for elderly people with a history of recurrent non-elective hospital admissions. Age Ageing. Vol 35. 2006/06/15 ed2006:487-91. | Wrong intervention model
Takahashi PY, Hanson GJ, Pecina JL, et al. A randomized controlled trial of telemonitoring in older adults with multiple chronic conditions: the Tele-ERA study. BMC Health Serv Res. Vol 10. 2010/09/03 ed2010:255. | Wrong intervention model
Weinberger M, Oddone EZ and Henderson WG. Does increased access to primary care reduce hospital readmissions? Veterans Affairs Cooperative Study Group on Primary Care and Hospital Readmission. N Engl J Med. Vol 334. 1996/05/30 ed1996:1441-7. | Wrong intervention model
Willenbring ML, Olson DH and Bielinski J. Integrated outpatients treatment for medically ill alcoholic men: results from a quasi-experimental study. J Stud Alcohol. Vol 56. 1995/05/01 ed1995:337-43. | Wrong intervention model
Counsell SR, Callahan CM, Tu W, Stump TE and Arling GW. Cost analysis of the Geriatric Resources for Assessment and Care of Elders care management intervention. J Am Geriatr Soc. Vol 57. 2009/08/20 ed2009:1420-6. | Wrong outcome
Kane RL, Illston LH, Miller NA. Qualitative analysis of the Program of All-inclusive Care for the Elderly (PACE). Gerontologist. Dec 1992;32(6):771-780. | Wrong outcome
Suter E, Hyman M and Oelke N. Measuring key integration outcomes: a case study of a large urban health center. Health Care Manage Rev. Vol 32. 2007/08/02 ed2007:226-35. | Wrong outcome
Hansen LO, Young RS, Hinami K, Leung A and Williams MV. Interventions to reduce 30-day rehospitalization: a systematic review. Ann Intern Med. Vol 155. 2011/10/19 ed2011:520-8. | Follow-up < 30 days
Boorsma M, van Hout HP, Frijters DH, Ribbe MW and Nijpels G. The cost-effectiveness of a new disease management model for frail elderly living in homes for the elderly, design of a cluster randomized controlled clinical trial. BMC Health Serv Res. Vol 8. 2008/07/09 ed2008:143. | Wrong setting
Murray MA, Osaki S, Edwards NM, et al. Multidisciplinary approach decreases length of stay and reduces cost for ventricular assist device therapy. Interact Cardiovasc Thorac Surg. Vol 8. 2008/10/23 ed2009:84-8. | Wrong setting
Wright K, Hazelett S, Jarjoura D and Allen K. The AD-LIFE trial: working to integrate medical and psychosocial care management models. Home Healthc Nurse. Vol 25. 2007/05/15 ed2007:308-14. | Ongoing study, no results

### CONTROLLED STUDIES: COMPLETE RISK OF BIAS ASSESSMENTS

#### Randomized controlled trials

#### Observational studies

### UNCONTROLLED STUDIES: CHARACTERISTICS

### UNCONTROLLED STUDIES: RESULTS

### REFERENCES

1 Beland F, Bergman H, Lebel P, et al. (2006). A system of integrated care for older persons with disabilities in Canada: results from a randomized controlled trial. J Gerontol A Biol Sci Med Sci.
2 Bergman H, Beland F, Lebel P, et al. (1997). Care for Canada's frail elderly population: Fragmentation or integration. Canada Medical Association Journal.
3 Coleman EA, Grothaus LC, Sandhu N, Wagner EH. (1999). Chronic care clinics: a randomized controlled trial of a new model of primary care for frail older adults. J Am Geriatr Soc.
4 Counsell SR, Callahan CM, Clark DO, et al. (2007). Geriatric care management for low-income seniors: a randomized controlled trial. JAMA.
5 Hughes SL, Cummings J, Weaver F, Manheim LM, Conrad KJ, Nash K. (1990). A Randomized Trial of Veterans Administration Home Care for Severely Disabled Veterans. Med Care.
6 Hughes SL, Weaver FM, Giobbie-Hurder A, et al. (2000). Effectiveness of team-managed home- based primary care: a randomized multicenter trial. JAMA.
7 Melin AL. (1995). A randomized trial of multidisciplinary in-home care for frail elderly patients awaiting hospital discharge. Aging (Milan, Italy).
8 Sledge WH, Brown KE, Levine JM, et al. (2006). A randomized trial of primary intensive care to reduce hospital admissions in patients with high utilization of inpatient services. Dis Manag.
9 Jiwa M, Gerrish K, Gibson A, Scott H. (2002). Preventing avoidable hospital admission of older people. Br J Community Nurs.
10 Meret-Hanke LA. (2011). Effects of the Program of All-inclusive Care for the Elderly on hospital use. Gerontologist.
11 Anetzberger GJ, Stricklin ML, Gauntner D, Banozic R, Laurie R. (2006). VNA HouseCalls of greater Cleveland, Ohio: development and pilot evaluation of a program for high-risk older adults offering primary medical care in the home. Home Health Care Serv Q.
12 Beales JL, Edes T. (2009). Veteran's Affairs Home Based Primary Care. Clin Geriatr Med.
13 Brown KE, Levine JM, Fiellin DA, O'Connor P, Sledge WH. (2005). Primary intensive care: pilot study of a primary care-based intervention for high-utilizing patients. Dis Manag.
14 Chang C, Jackson SS, Bullman TA, Cobbs EL. (2009). Impact of a home-based primary care program in an urban Veterans Affairs medical center. Journal of the American Medical Directors Association.
15 Ginsburg IF, Eng C. (2009). On-site mental health services for PACE (Program of All-inclusive Care for the Elderly) centers. J Am Med Dir Assoc.
16 Landi F, Gambassi G, Pola R, et al. (1999). Impact of integrated home care services on hospital use. J Am Geriatr Soc.
17 North L, Kehm L, Bent K, Hartman T. (2008). Can home-based primary care cut costs. Nurse Practitioner.
18 Rosenberg T. (2012). Acute Hospital Use, Nursing Home Placement, and Mortality in a Frail Community-Dwelling Cohort Managed with Primary Integrated Interdisciplinary Elder Care at Home. Journal of the American Geriatrics Society.
19 Vedel I, De Stampa M, Bergman H, et al. (2009). A novel model of integrated care for the elderly: COPA, Coordination of Professional Care for the Elderly. Aging Clinical & Experimental Research.
20 Weaver FM, Hickey EC, Hughes SL, et al. (2008). Providing all-inclusive care for frail elderly veterans: evaluation of three models of care. J Am Geriatr Soc.
21 Wieland D, Lamb VL, Sutton SR, et al. (2000). Hospitalization in the Program of All-Inclusive Care for the Elderly (PACE): rates, concomitants, and predictors. J Am Geriatr Soc.