# SUMMARY

For men who have BPH and have a large prostate or a high PSA at baseline, combination therapy can prevent about 2 episodes of clinical progression per 100 men per year over 4 years of treatment. There is no additional benefit within the first year of treatment. Most men who take combination therapy will have no additional benefit, and about 4 additional patients per 100 will become impotent who would not have taking an alpha blocker alone. Combination therapy can also be instituted after clinical progression occurs, but this strategy, while used widely, has not been studied.

Expanding access to combination therapy as an initial option would require higher utilization of ultrasound and PSA testing in BPH patients to assess the risk of progression. The consequences of such a program in a primary care setting has not been studied.

Alpha blockers have similar effectiveness and safety. For combination therapy, doxazosin is the best-studied alpha blocker.