# METHODS

see Appendix.