# INTRODUCTION

Benign prostatic hyperplasia (BPH) causes urinary hesitancy and intermittency, weak urine stream, nocturia, frequency, urgency, and the sensation of incomplete bladder emptying. These symptoms, collectively called “lower urinary tract symptoms,” or LUTS, can significantly reduce quality of life. Approximately 50% of men who have BPH develop moderate to severe symptoms. BPH is the 4^th^ most commonly diagnosed disease among patients ≥50 years, after coronary disease and hyperlipidemia; hypertension; and type 2 diabetes. Among men over 50 years the prevalence of diagnosed BPH in the community is 13.5%.

Reducing symptoms is the main reason to treat BPH. Men with no symptoms or mild symptoms (AUA Symptom Index [SI] score of <7 points), and those who tolerate moderate symptoms well, may be managed without pharmacotherapy (“watchful waiting”). Medical treatments include alpha-1-selective adrenergic receptor (a-1-AR) antagonists, and 5-alpha-reductase inhibitors (5-aRIs).

Several reasons to choose one treatment instead of another have been suggested. A clinician may consider several factors in choosing a treatment:

- expeditious relief of the presenting symptoms and quality of life
- quality of life related to adverse effects of medications such as sexual dysfunction, dizziness, and asthenia
- preventing or delaying progression (especially acute urinary retention) in the long-term
- the risk of developing cancer
- the effect of treatment on hypertension, diabetes, post-traumatic stress disorder, and other conditions common among veterans.

Combination therapy with an alpha blocker plus a 5-aRIs, finasteride, has become increasingly popular [1, 2] since December, 2003, when the NIH-funded Medical Therapy of Prostatic Symptoms (MTOP) trial [3] was published. The trial found that the patients taking a combination of finasteride and doxazosin were less likely to develop acute urinary retention (AUR), an increase in symptom score greater than 4 points on the AUA/IPSS scale, or invasive therapy for BPH.

Wider use of combination therapy raises several issues for the VA:

1. Should the VA change its clinical practice guidelines to increase access to combination therapy?
2. Should the VA increase access to combination therapy by allowing primary care physicians to prescribe it?
3. How should patients taking finasteride or combination therapy be monitored for prostate cancer?

## Current VA Guidance

In September, 2004, the VHA Pharmacy Benefits Management Strategic Healthcare Group and the Medical Advisory Panel published guidelines for the use of combination therapy. This guideline recommended combination therapy in two groups of patients: (A) those who had persistence or clinical progression of BPH symptoms while taking maximal doses of an alpha-blocker and (B) those who present with an AUA score ≥ 12 and have a prostate size >40 ml (see Figure 1). They did not offer specific guidance for PSA testing in patients taking finasteride, but some facilities recommend annual testing.

Figure 1 PBM-MAP Guidance on Combination Therapy

The PBM/MAP has also recommended against the addition of dutasteride and alfuzosin to the National VA Formulary.

## AUA Guidelines

The American Urological Association published guidelines for management of BPH in 2003. It is described as having been updated in 2006, but it is not clear what material was updated. The AUA’s main findings regarding the choice of drug therapies are:

- Alpha blockers are more effective than finasteride in improving symptoms
- Finasteride is not an appropriate treatment for patients who do not have prostate enlargement
- Finasteride is an appropriate treatment for patients who have LUTS and a large prostate
- The combination of an alpha-adrenergic receptor blocker and a 5 alpha-reductase inhibitor (combination therapy) is an appropriate and effective treatment for patients who have a high baseline risk of progression, but a specific threshold of risk cannot be determined.
- Alfuzosin, doxazosin, tamsulosin and terazosin have similar effectiveness
  - While side effect profiles differ, none of these drugs had a clear advantage as initial therapy.

The AUA guidelines also state that “Data are insufficient to support a recommendation for the use of prazosin.” However, data on prazosin were not analyzed in developing the guidelines (page 3–13).

Advocates of wider use of combination therapy argue that “moderate to severely symptomatic patients with larger glands and higher serum PSA levels, however, are best served with combination therapy, as they benefit from the disease modification induced by the 5 alpha reductase inhibitors in addition to the symptomatic improvement due to the alpha blockers.” [4] The AUA guidelines do not specify a threshold risk of progression above which combination therapy is the treatment of choice, but imply that there is such a threshold. Based on the guidance in Figure 1, in the VA combination therapy is an option for initial treatment in men who have at least moderate symptoms and a large prostate; however, within the VA there is no group for which combination therapy is described as the treatment of choice.

The purpose of this review is to compare finasteride in combination with an alpha-blocker to finasteride alone or to an alpha blocker alone, and to compare the efficacy and safety of different alpha-blockers (listed in Table 1). Combination therapy is used variably, within VHA. The balance of benefits and harms of finasteride, and its complex effects on detection of prostate cancer, and on the natural history of cancer, make it important that the VA implement evidence-based approach to treating BPH.

Table 1 Drug Indications and Dosing

Drug | Starting Dosage | Maintenance Dosage | On VA Formulary
Alfuzosin extended release | 10 mg daily | 10 mg qd | No
Doxazosin – Cardura®, generic | 1 mg daily | 2 to 8 mg daily | Yes
Doxazosin Gastro-Intestinal | 4 mg daily | 8 mg qd | No
Therapeutic System Prazosin | 1 mg daily | 2 to 10 mg | Yes
Tamsulosin – Flomax® (Boehringer Ingelheim) | 0.4 mg daily | 0.4 or 0.8 mg | No
Terazosin – Hytrin®, generic | 1 mg daily | 2 to 10 mg | Yes

## Scope and Key Questions

Key Question 1: For patients with BPH, what are the comparative benefits, harms, and efficacy of combination therapy with a 5-alpha-reductase inhibitor plus an alpha blocker versus either treatment alone?

Key Question 2: what are the comparative efficacy and harms of alpha-1-adrenergic antagonists?

Key Question 3: Are there subgroups of patients based on demographics (age, racial groups), other medications, or co-morbidities for which one treatment is more effective or associated with fewer adverse events?

## Eligibility Criteria

Population(s): Adult patients in outpatient settings with the following diagnosis:

1. Benign prostatic hyperplasia (BPH)
2. Lower urinary tract symptoms (LUTS)

### Interventions

1. Terazosin
2. Doxazosin
3. Tamsulosin
4. Prazosin
5. Finasteride
6. Combination of an alpha blocker and a 5-alpha-reductase inhibitor

### Efficacy outcomes

1. Reduction in BPH or LUTS symptoms
  - Improvement in maximum flow rate (Qmax)
  - Reduction in International Prostate Symptom Score (IPSS or AUA score)
  - Reduction in irritative or obstructive symptoms
2. Delaying progression to acute urinary retention, worsening symptoms, or invasive therapy

### Safety and related outcomes

1. Adverse drug reactions
2. Withdrawals due to adverse drug reactions
3. Hypertension, hypotension, sexual dysfunction
4. detection of prostate cancer

### Study designs

For efficacy outcomes

1. controlled clinical trials that directly compared 2 or more of the interventions listed above
2. systematic reviews
3. placebo-controlled trials if they addressed outcomes not adequately addressed in direct comparison studies

For safety outcomes

1. controlled clinical trials and good-quality systematic reviews
2. cohort studies of a defined population

Trials were excluded if they

- ○ evaluated phytotherapeutic agents or drugs that are not available on the VA National Formulary
- ○ were not available in English
- ○ had less than 30 days of follow up