# TRIALS COMPARING ALPHA ANTAGONISTS

Clinical Trial | Inclusion Criteria/Pt. Population | Intervention | Results | Safety/Comments
Cam et al 2003 Prospective clinical study 178 patients doxazosin 4 mg 24 months no financial disclosure Turkish | Men > 50 years old IPSS 18–35 Attendance to a urology department due to: -LUTS -age > 50 -unremarkable medical hx in terms of LUTS -no definitive need for surgery | Doxazosin 1 mg titrated to 4 mg | Reduction in symptom scores from 24 (SD ±7.4) before medication to 17 (SD ±8.4) after 3 months of treatment In the patients reporting doxazosin as ineffective, no change, or effective, 93%, 59% and 15% respectively underwent surgery. Of the 178 patients enrolled 47% underwent surgery. | Evaluation of the efficacy doxazosin was determined by one multiple choice question regarding the satisfaction with the medical treatment in terms of relieving symptoms
Ichioka et al 2004 Prospective 123 patients 43 months Tamsulosin (n = 123) No financial disclosure Japanese | Men 53–88 years old Dx BPH Treated with tamsulosin >12 months | Tamsulosin 0.2 mg titrated up to 0.4 mg as needed to relieve sx. | Predictive for treatment failure: baseline IPSS ≥ 15, months 0–12 lowest IPSS ≥ 13, lowest QoL score of ≥ 3 and lowest BPH impact score of ≥ 4.
Roehrborn et al 1996 Prospective, placebo controlled, randomized, double-blinded 2084 patients 1 year (Terazosin n = 1053 Placebo n = 1031) Funding: Abbot Labratorie American | Men ≥ 55 years old Moderate-severe BPH AUA-Symptom Score (SS) ≥ 13 AUA-Bother Score (BS) ≥ 8 PUF ≤ 15 mL/sec. Voided volume = 150 mL | Terazosin 1 mg x 3 days, 2 mg x 25 days, ↑ 5 mg or 10 mg as tolerated Placebo | Statistically superior improvements were observed in regard to AUA-BS, BPH impact index and the QoL score in terazosin-treated patients. PUF improved Treatment failure was higher in placebo | Withdraw was higher due to ADR was higher in terazosin patients
Okada et al 2000 Single-blind, randomized 61 patients 4 weeks Japanese | Symptomatic BPH | Terazosin 1–2 mg Tamsulosin 0.2 mg | Both meds significantly improved the total IPSS, irritative and obstructive symptom score, and quality of life. There was no significant difference for these variables between groups. There was no significant improvements between groups. | Incidence of ADR was not significantly different between groups. Neither medication affected systolic or diastolic blood pressure.
Lee et al 1997 Single-blind 98 patients randomized 8 weeks Korean | Moderate to severe BPH | Tamsulosin 0.2 mg Terazosin 1 mg ↑ 5 mg | Both medications similarly improved IPSS and Increased Qmax | Terazosin: -systolic and diastolic BP decreased significantly -dizziness, dry mouth were more frequent
Tsuiji et al 2000 Open-label 105 patietns Randomized (Prazosin n= 32, Terazosin n=35, Tamsulosin n=38) 4 weeks | LUTS associated with BPH | Prazosin 1 mg ↑ 2 mg Terazosin 1 mg ↑ 2 mg Tamsulosin 0.1 mg ↑ 0.2 mg | All significantly reduced subjective symptom scores from baseline. Terazosin significantly better improvement than Tamsulosin in 4 of 9 symptom scores (urgency, sense of residual urine, prolonged micturition, intermittency) Significant increase in flow with prazosin | ADR which lead to withdrawal: Prazosin = 1 Terazosin = 3 Tamsulosin = 0
Na et al 1998 Single-blinded, randomized 212 Patients Randomized 4 weeks Chinese | BPH | Terazosin 2 mg Tamsulosin 0.2 mg | Tamsulosin and terazosin: significant improvement in IPSS, Qmax and average urinary flow rate from baseline | Dizziness, hypotension occurred significantly more frequently with terazosin than tamsulosin