# SUMMARY AND DISCUSSION

In this systematic review, we examined the benefits and harms of treating hypertension to lower compared more moderate blood pressure targets in patients over age 60. Table 8 provides a summary of the evidence. Overall, we found high-strength evidence that treating blood pressure in patients over age 60 to current treatment targets (< 150/90 mmHg) substantially reduces mortality, stroke, and cardiac events. Much of this data comes from trials in which the mean baseline SBP was > 160 mmHg. We also found evidence, driven mainly by one large trial, that lower targets (SBP < 140 mmHg or DBP < 85 mmHg) compared to higher targets reduced stroke (moderate strength evidence) and cardiac events (low strength evidence); mortality was also reduced though not significantly (low strength evidence). There is little data that directly helps distinguish benefits between SBP 140 and 150 mmHg. Most of the trials achieving SBP < 140 mmHg were the treat-to-target trials. Only one trial included patients with baseline SBP 140-150 mmHg and found an improvement in mortality, but not other outcome. We found moderate strength evidence that more aggressive blood pressure control (SBP < 140 mmHg) in patients with prior stroke substantially reduced rates of recurrent stroke.

The treat-to-target trials overall support a lower blood pressure treatment target in some patients with high cardiovascular risk. Most of the evidence in support of lower treatment targets comes from one large trial examining an SBP target of < 120 mmHg in which a substantial proportion of intervention patients achieved SBP 120-130 mmHg. Lower targets may prevent (on average, across a population) roughly 10-20 events for every 1000 high-risk patients treated over 5 years (Table 8), but more aggressive treatment is likely associated with a higher medication burden and higher risk of adverse effects such as hypotension and syncope. On the other hand, we found that lower targets are unlikely to increase the risk of dementia, fractures, and falls, or reduce quality of life.

Current guidelines suggest aiming for moderate blood pressure control (< 150/90 mm Hg) in most adults over age 60. We found strong evidence supporting benefit of moderate blood pressure control. The main area of controversy, however, is whether or not there is an additional benefit from more aggressive blood pressure control. Taken as a whole, trials examining lower blood pressure targets suggest there may be some benefit in more aggressive control, though the absolute effect is smaller and there is not a consistent effect on mortality. It is possible that the smaller incremental benefit from more aggressive blood pressure control may be related to the relatively small number of cardiovascular and mortality events in some of the trials.^24,26^ As discussed above, 3 studies found that patients with higher baseline cardiovascular risk had higher event rates and tended to experience more absolute benefit.^41-43^ However, the magnitude of these effects was modest and was not consistent across outcomes.

Part of the answer may depend on consideration of the individual trials. The SPRINT and ACCORD trials are clearly different than the others in that they included patients with reasonable blood pressure control (about 140/90 mm Hg) at baseline and targeted “normal” SBP of 120 mm Hg. However, these 2 trials provide conflicting results: in SPRINT there was a substantial reduction in mortality and cardiac events but not stroke, while in ACCORD there was a reduction in stroke but not the other outcomes. Both trials included patients with substantial cardiovascular risk (and, in fact, the proportion of patients experiencing events was higher in ACCORD), though the mean age was higher in the SPRINT trial. The ACCORD trial included only diabetic patients, while SPRINT excluded diabetic patients. However, it is not immediately clear why results would differ based on diabetes status alone. Of note, the SPRINT trial was stopped early for benefit but it is unclear whether this necessarily accounted for the different results. Sensitivity analyses suggest that SPRINT was the main contributor to the non-significant trend towards reduced mortality and the significant effects on cardiac events.

There was consistent evidence that more aggressive blood pressure control modestly reduced stroke outcomes with or without the inclusion of SPRINT. The modest stroke risk reduction may provide rationale for more aggressive treatment in some patients. The main trade-off in considering more aggressive treatment would be a higher medication burden, and the increased risk of adverse effects seen in some studies such as cough and hypotension. Two of 3 trials found higher rates of syncope in the intervention group suggesting that hypotension is potentially a serious short-term harm. Theoretically, there is also reason to be concerned about more serious long-term adverse effects of lowering blood pressure in older adults in whom arterial stiffness, subclinical cerebrovascular disease, cognitive impairment, and multiple comorbidities can combine to increase risk of falls, fracture, dementia, and poor quality of life. However, we found moderate-strength evidence that blood pressure treatment to SBPs as low as 120 mm Hg did not increase the risk of dementia, fractures, falls, or reduce quality of life.

Table 8 Summary of the Evidence on More vs Less Intensive Treatment for Hypertension in the Elderly

Outcome | N studies (N = total patients combined) | Combined estimates: RR (95% CI) ARR N: events (95% CI) prevented per 1000 high-risk patients over 5 years^a^ | Strength of Evidence^b^ | Summary of findings
Mortality | 9 RCTs^c^ (N = 46,450) | RR 0.90 (0.83-0.98) ARR 1.64 N: 34 (7-58) | High^d^ | Consistent benefit of treating blood pressure to levels < 150/90 mmHg.
Mortality | 6 RCTs^e^ (N = 41,491) | RR 0.86 (0.69-1.06) ARR 0.80 N: 18 (n/a^f^-40) | Low | Lower treatment targets (SBP ≤ 140 mmHg or DBP ≤ 85 mmHg, or lower) associated with nonsignificant mortality reduction compared to higher targets. Findings were inconsistent across studies and estimate was imprecise.
Stroke | 9 RCTs^c^ (N = 46,450) | RR 0.74 (0.65-0.84) ARR 1.13 N: 26 (16-35) | High^d^ | Clear, consistent benefit of treating blood pressure to levels < 150/90 mmHg.
Stroke | 6 RCTs^e^ (N = 41,491) | RR 0.79 (0.59-0.99) ARR 0.49 N: 9 (0-17) | Moderate | Lower treatment targets (SBP ≤ 140 mmHg or ≤ DBP 85 mmHg, or lower) reduced the risk of stroke compared to higher targets; some inconsistency but relatively stable effect across analyses^f^
Cardiac events | 9 RCTs^c^ (N = 46,450) | RR 0.77 (0.68-0.89) ARR 1.25 N: 65 (31-90) | High^d^ | Clear, consistent benefit of treating blood pressure to levels < 150/90 mmHg.
Cardiac events | 6 RCTs^e^ (N = 41,491) | RR 0.82 (0.64-1.00) ARR 0.94 N: 18 (n/a^f^-36) | Low | Lower treatment targets (SBP ≤ 140 mmHg or DBP ≤ 85 mmHg, or lower) may reduce the risk of cardiac events compared to higher targets. Findings were inconsistent across studies and estimate was imprecise.
Short-term adverse events | 19 RCTs (N = 98,964) | --- | --- | Mixed findings: withdrawal due to adverse events was increased in the intervention group by 44-100% in 4 of 10 trials reporting this outcome. Cough and hypotension were the most frequently reported events. The risk of syncope was increased in 2 of 3 trials reporting this outcome. Excessive heterogeneity among trials precluded pooling of results.
Renal outcomes | 13 RCTs (N = 66,607) | --- | Low | More intensive blood pressure treatment did not worsen renal outcomes. Outcome definitions varied, and event rates for clinically significant outcomes such as end stage renal disease were low.
Cognitive outcomes | 7 RCTs (N = 25,901) | Incident dementia in 4 RCTs of patients without prior stroke: OR 0.89 (0.74-1.07) | Moderate | No effect on degree of cognitive decline or incidence of dementia. Loss to follow-up ranged across studies; patients lost to follow-up may differ in risk for dementia.
Falls/fracture | Fracture: 3 RCTs (N = 11,680) | --- | Moderate (fracture) | Mixed findings: 3 trials found no effect of lower blood pressure targets on risk of fracture. Two trials with SBP target of 120 mmHg found no effect on risk of falls, while a 3rd (with achieved SBP < 150 mmHg) found a small increase in risk of fall.
Falls/fracture | Falls: 3 RCTs (N = 17,196) | --- | Low (falls)
Quality of life (QOL) | 4 RCTs (N = 7,154) | --- | Moderate (QOL) Low (functional status) | Moderate BP control (SBP 140-150 mmHg) did not affect QOL. One study found no effect on functional status.
Effects of age | 12 RCTs (N = 76,137) | --- | Low | Similar effects across different age groups in age-treatment interaction analyses, but based on study-level subgroup analyses and dichotomized at a younger age in many studies.
Effects of comorbidity burden | --- | --- | No evidence | No studies reported outcomes based on comorbidity burden; most trials excluded patients with dementia, serious comorbidities, and life-limiting illness.
Effects in the frail elderly | 2 RCTs (N = 5,166) | --- | Insufficient | Treatment effects did not vary with frailty score in post-hoc analyses from 2 trials, one of which had large amount of missing data. Most trials did not assess frailty, and many trials excluded patients who were frail, had dementia, or were institutionalized.
Effects in stroke patients | 2 RCTs (N = 9,125) | Stroke recurrence: RR 0.76 (0.66-0.92) ARR 3.02 Cardiac events: RR 0.78 (0.61-1.08) Mortality: RR 0.98 (0.85-1.19) | Moderate | Targeting SBP < 140 mmHg reduced recurrent stroke.

Abbreviations: ARR = absolute risk reduction; BP = blood pressure; CI = confidence interval; DBP = diastolic blood pressure; N = population size (N total / n subgroup); OR = odds ratio; QOL = quality of life; RCT = randomized controlled trial; RR = relative risk; SBP = systolic blood pressure.

a We used observed control group event rates standardized to 5 years. As poorly controlled blood pressure itself contributes to cardiovascular risk, we used data from the 2 most contemporary trials for each set of analyses. We used the HYVET study (22) to estimate event rates in the higher baseline blood pressure analyses, and data from SPRINT (the older age subgroup since the mean age was comparable to that in HYVET) for the treat to target analyses (50).

b The overall quality of evidence for each outcome is based on the consistency, coherence, and applicability of the body of evidence, as well as the internal validity of individual studies. The strength of evidence is classified as follows:

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Insufficient = Any estimate of effect is very uncertain.

c The analyses presented here are of trials with baseline SBP ≥ 160 mmHg. The achieved SBP in 3 of the trials was < 140 mmHg, but these studies contributed relatively few events. Achieved SBP in all the other studies was ≥ 140 mmHg.

d Most of the evidence comes from trials in which baseline SBP ≥160 mmHg and achieved SBP was 140-150 mmHg. These are large trials providing consistent evidence, and a precise summary estimate.

e All trials that tested strict versus less strict blood pressure targets in which the target blood pressure in the intervention group was SBP < 140 mmHg or DBP < 85 mmHg, or even lower.

f The number of prevented events is not applicable because the upper bound of the confidence interval for relative risk was ≥1.00.

We found no data about the role of comorbidity burden in the relationship between blood pressure targets and the identified outcomes of interest, or between burden of comorbidity and potential harm of differing blood pressure targets. The importance of multimorbidity and the disease-disease and disease-treatment interaction which occurs when multiple chronic conditions co-exist is of critical importance to older adults. Co-existence of multiple comorbidities may lead to burdensome therapy regimens and adverse therapy interactions based on combinations of clinical practice guidelines built around a single focus of disease. ^62-64^ Further, particularly among Veterans, hypertension is the most common comorbidity occurring in over 80% of adults over age 80, and the number of comorbidities for adults is known to increase with advancing age. ^9,65^ The importance of multimorbidity in older adults makes the relationship between hypertension, common comorbidities, and patient-important outcomes an invaluable target for future research. As noted above, exclusion criteria specified by these trials often decreased the relative comorbidity burden in study populations. In particular, patients with renal disease, heart failure, and cancer or comorbid illness likely to limit life expectancy were frequently excluded.

Importantly, the generalizability of our findings to the oldest age groups is limited. Fewer than half of these studies included adults over age 80. The primary exception is HYVET, which included only adults over age 80 and described a decreased risk of stroke with moderate blood pressure reduction (< 150/90 mm Hg).^6^ The HYVET trial was like most of the other trials in implicitly or explicitly excluding patients with dementia or in long-term care, thus limiting the population to relatively high functioning older adults. Given the absence of data on comorbidity burden, the applicability of these data to the most elderly patients is questionable, particularly in adults over age 80 with significant frailty or poor functional status. This limitation may have heightened importance when relevance of these data are considered for the aging Veteran population, which experiences a significant burden of comorbidity and frailty.^9^

A number of recent reviews have also attempted to address the question of optimal blood pressure targets in older adults. Dr. Neal and colleagues with BPLTTC recently presented a patient-level meta-analysis of adults with mild hypertension (baseline SBP 140 to 159 mm Hg).^66^ This review was not limited to older adults, however, and the majority of included patients in the individual-level analysis also had diabetes. A recent meta-analysis found that a drop in SBP of 10 mm Hg was associated with reduced mortality, cardiac events, and stroke in patients with diabetes.^67^ This study also found that most of the benefit was limited to studies in which the baseline blood pressure was ≥ 140 mm Hg. However, the studies included in this meta-analysis were clinically very heterogeneous and included studies of younger patients, trials of normotensive patients with conditions such as heart failure, and comparative effectiveness studies. The most recently published systematic review concluded that more intensive blood pressure treatment was associated with improvements in stroke and cardiovascular outcomes, but not mortality.^68^ However, this review did not focus on older patients, did not include SPRINT, and also did not include several other large trials included in our review.

Our review contributes further to the literature on hypertension management in older adults by specifically limiting study inclusion to populations with mean age over 60 and hypertension, and by focusing on studies that used a treat-to-target strategy for blood pressure goals most commensurate with the controversy of strict versus moderate blood pressure control in older patients. By focusing on treat-to-target studies in addition to studies comparing more versus less intensive therapy we hoped to mitigate potential drug-specific effects which could affect outcomes (eg, more versus less renin angiotensin system blockade) as well as potentially larger and more definitive differences in achieved blood pressures between treatment arms. For similar reasons, we did not include comparative effectiveness studies which might speak more to optimal medication choice in a particular population as opposed to the true benefits or harms of a given level of blood pressure. Finally, our review adds to the existing knowledge base by including a broad examination of potential longer-term harms of blood pressure treatment.

## LIMITATIONS

This review has several potential limitations. We could not determine if any specific medication, medication class, or combination of medications may have played a role in influencing clinical outcomes. The wide variety of medications used across studies and the absence of any pattern between medication types and relative risk provides some reassurance that medication-specific effects are likely minimal. Moreover, we focused on pharmacologic therapy and, therefore, may have missed important effects of nonpharmacological therapy of hypertension.

The populations and study design varied considerably across included trials. We incorporated a number of sensitivity analyses to better understand how different trial characteristics contributed to results. While the relative treatment effects remained fairly consistent across different analyses, the variation in numbers needed to treat were probably clinically important. We therefore strived to remain transparent about the analyses which contributed to the chosen summary estimates, and present a range of numbers needed to treat for outcomes in which there were significant findings.

We report study-level data here, but recognize there may be individuals within a study population who benefit more or less from treatment. We found fairly consistent results across many subgroup analyses. We also are in the process of conducting analyses from 6 trials to see if the results reported here remain consistent in patient-level analyses. We focused on comorbidity burden rather than specific comorbidities such as diabetes, but it is possible that results might be different among certain condition-specific subgroups.

## FUTURE RESEARCH

There is a need for more research examining how the severity of comorbidity and the presence of multiple comorbidities modifies the effects of more intensive blood pressure treatment. Though there have been more recent trials which have included patients over age 80, there is a need for more research in this age group. Moreover, future studies should enroll patients who have not yet been represented in the evidence, including those with cognitive impairment and other causes of frailty. Finally, future reviews using individual patient-level data on medication use could clarify whether or not the findings in this report apply equally across antihypertensive drug class.

## CONCLUSIONS

Lowering blood pressure in adults over age 60 reduces mortality, stroke, and cardiac events. The most consistent and largest effects are seen in studies of patients with higher baseline blood pressures (SBP ≥ 160 mmHg) achieving moderate blood pressure control (< 150/90 mmHg). Lower treatment targets (< 140/85 mmHg) are likely to be beneficial for some patients at high cardiovascular risk, but the results across trials are less consistent. Lower treatment targets are largely supported by findings from one trial which targeted SBP <120 mmHg and in which most intervention patients achieved SBP < 130 mmHg. In patients with cerebrovascular disease, more aggressive blood pressure lowering (SBP <140 mmHg) likely reduces recurrent stroke. Lower treatment targets are associated with higher medication burden and an increased risk of short-term harms such as hypotension. On the other hand, evidence that there is not an increased risk in cognitive impairment, falls, and reduced quality of life may provide some flexibility for providers in crafting an individualized antihypertensive treatment plan. There is little data to assess the risks and benefits of antihypertensive treatment among institutionalized elder patients or those with multiple comorbidities.