# RESULTS

## LITERATURE FLOW

The combined literature searches yielded 11,268 titles and abstracts, including 11,153 from electronic database searches, and 115 from reference lists of systematic reviews and other relevant articles. We applied pre-specified inclusion criteria (Appendix B) in screening the abstracts and selected 330 articles for full-text review. We identified 21 randomized controlled trials (RCTs) and 3 cohort studies that contained primary data relevant to the Key Questions (Figure 1).

Figure 1 Literature Flow Diagram

## KEY QUESTION 1 In adults over age 60, what are the health outcome effects of differing blood pressure targets?

### Overview of Results

We found 21 trials comparing blood pressure treatment targets, or more versus less intensive treatment. Overall, there was clear and consistent evidence that treating blood pressure in older adults reduced mortality, cardiac events, and stroke. We found the most consistent and greatest absolute benefit among trials in which participants had higher baseline blood pressures (SBP ≥ 160 mm Hg) and achieved moderate blood pressure control (< 150/90 mm Hg). Six trials compared more aggressive blood pressure treatment targets (SBP < 140 mm Hg or DBP < 85 mm Hg) to higher targets and found no significant effect on all-cause mortality. More aggressive treatment did reduce the risk of cardiac events and stroke, but the absolute effects were smaller than those seen among trials of patients with higher baseline blood pressures achieving moderate control.

### Trial Characteristics

The 21 included clinical trials varied significantly in study design and primary outcomes. All studies were considered low risk of bias with the exception of 3 studies.^19-21^ Eight studies randomized patients to different blood pressure targets (Table 2).^11,17,21-26^ The remaining 13 trials randomized patients to more versus less intensive hypertensive therapy, which often resulted in different achieved blood pressures across treatment arms (Table 3).^6,8,19,20,27-35^

Table 2 Characteristics of Trials that Compared Blood Pressure Target Goals

Study BP goals (mm Hg), T vs C Mean or median(^*^) length of follow-up | Antihypertensive therapy used to reach targets | Sample size, T vs C Mean age (SD) % Male | Comorbidities % DM % CAD % CVD | Baseline SBP/DBP, T vs C | Achieved SBP/DBP, T vs C | Mean number or % distribution of antihypertensive medications used, T vs C
ACCORD, 2010^22^ SBP < 120 vs < 140 4.7 years | Step 1: a diuretic combined with an ACEI or β-B. Medications that could be added to reach BP target: dihydropyridine and nondihydropyridine CCB, α-B, ARB, sympatholytics, α-B/β-B, and the following combinations: thiazide diuretic + a potassium-sparing diuretic; β-B + diuretic; ACEI + diuretic, ARB + a diuretic; dihydropyridine CCB + ACEI. | 2362 vs 2371 62.2 (6.9) 52.3% | 100% DM 33.7% CAD | 139.0/75.9 vs 139.4/76.0 | 119.3/64.4 vs 133.5/70.5 | Mean 3.5 vs 2.2
Cardio-Sis, 2009^23^ SBP < 130 vs < 140 2.0^*^ years | Diuretics (hydrochlorothiazide + ramipril or telmisartan, furosemide), β-B (bisoprolol), CCB (amlodipine), ACEI (ramipril ± hydrochlorothiazide), ARB (telmisartan ± hydrochlorothiazide), centrally acting sympathetic inhibiting drugs (clonidine), plus drugs previously taken by subjects. | 557 vs 553 67 (7.0) 52.3% | 12% CAD 8.5% CVD | 163.3/89.7 vs 163.3/89.6 | 131.9/77.4 vs 135.6/78.7 | Mean 2.9 vs 2.9 OR (95% CI) at 2-year follow-up, T vs C: Diuretic: 1.36 (1.08 to 1.71) ARB: 1.17 (0.90 to 1.52) β-B, CCB, and ACEI: no difference
HOT, 1998^17^ DBP ≤ 80 vs ≤85 vs ≤ 90 3.8 years | Step 1: low-dose felodipine Step 2: + low-dose ACEI or β-B Step 3: + high-dose felodipine Step 4: + high-dose ACEI or β-B Step 5: + other, mainly thiazide | 6262 vs 6264 vs 6264 61.5 (7.5) 53% | 1.5% MI 1.2% CVD 8% DM | 170/105 vs 170/105 vs 170/105 | By assigned DBP, ≤ 80 vs ≤ 85 vs ≤ 90: 139.7/81.1 vs 141.4/83.2 vs 143.7/85.2 | % using drug per DBP target, ≤ 80 vs ≤ 85 vs ≤ 90: Felodipine: 79 vs 78 vs 77 ACEI: 45 vs 42 vs 35 β-B: 32 vs 28 vs 25 Diuretic: 24 vs 22 vs 19
JATOS, 2008^24^ SBP < 140 vs < 160 2.0 years | Efonidipine, 20-40 mg once daily, increasing to 60 mg once or twice daily if needed. Drugs other than CCB were added if needed. | 2212 vs 2206 73.6 (5.2) 38.8% | 11.8% DM 9.1% CVD 9.9% Renal disease | 171.6/89.1 vs 171.5/89.0 | 139.3/76.1 vs 146.5/ 78.5 | N drugs used by % of patients: 1: 47.7 vs 57.8 (P < .001) 2: 31.6 vs 27.3 (P = .002) 3: 15.1 vs 9.3 (P < .001) 4: 2.9 vs 1.9 (P = .05) 5: 0.1 vs 0.14 (P = 1.0)
SPS3, 2013^25^ SBP < 130 vs 130-149 3.7 years | At the discretion of the physician; at least one drug from each major class was available. | 1501 vs 1519 63 (11.0) 63% | 36.5% DM 100% CVD 10.5% CAD | 142/78 vs 144/79 | SBP 127 vs 138 DBP NR | Mean 2.4 vs 1.8 (P < .001) Drugs used by T vs C (%) at 1 year: Thiazides: 58 vs 43 ACEI/ARB: 80 vs 63 CCB: 43 vs 30 β-B: 31 vs 25 Other: 11 vs 9
SPRINT, 2015^11^ SBP < 120 vs < 140 3.26^*^ years | Thiazide-type diuretic, and/or an ACEI or ARB (but not both) and/or a CCB. Titrate or add therapy not already in use as needed. | 4678 vs 4683 67.9 (9.5) 64.4% | 0% DM 0% CVD 20.1% CAD 28.3% CKD | 139.7/78.2 vs 139.7/78.0 | 121.5/66 vs 134.6/74 | Mean 2.7 (1.2) vs 1.8 (1.1) % using N meds: 0: 2.7 vs 11.3 1: 10.5 vs 31.1 2: 30.5 vs 33.3 3: 31.8 vs 17.2 4+: 24.3 vs 6.9
VALISH, 2010^26^ SBP < 140 vs < 150 3.0^*^ years | Step 1: Valsartan, 40-80 mg once daily Step 2: Increase valsartan up to 160 mg, and/or other agents (diuretics, CCBs) except other ARBs | 1545 vs 1534 76.1 (4.1) 37.6% | 13.0% DM 6.5% CVD 5.0% CAD 1.4% Renal insufficiency | 169.5/81.7 vs 169.6/81.2 | 136.6/74 vs 142/76.5 | % using drug: Valsartan only: 56.1 vs 57.6 (P = ns) Valsartan dose, mg: 91.2 vs 88.1 (P =.0236) CCB: 37.1 vs 36.4 (P = ns) Diuretic: 13.0 vs 11.9 (P = ns) β-B: 6.0 vs 5.0 (P = ns) ACEI: 2.1 vs 2.5 (P = ns)
Wei, 2013^21^ SBP < 140 vs < 150 4.0 years | Step 1: Monotherapy with enalapril 10mg/d; bisoprolol 2.5-5 mg or metoprolol 50-100 mg/d; amlodipine 5-10 mg/d; or indapamide 1.5-2.5 mg/d Step 2: Add 1, 2, or 3 anti-hypertension drugs stepwise Step 3: Increase dosage of anti-hypertension drugs | 363 vs 361 76.6 (4.6) 66% | 23.3% DM 6.6% CVD | 158.8/83.7 vs 160.3/84.8 | 135.7/76.2 vs 149.7/82.1 | % using combination therapy: 53.7 vs 39.1 (P < .01).

Abbreviations: α-B = alpha-blocker; ACCORD = Action to Control Cardiovascular Risk in Diabetes; ACEI = angiotensin converting enzyme inhibitor; ARB = angiotensin II receptor blockers; β-B = beta-blocker; BP = blood pressure; Cardio-Sis = Studio Italiano Sugli Effetti Cardiovascolari del Controllo della Pressione Arteriosa Sistolica; C = comparator/control; CAD = coronary artery disease; CCB = calcium channel blocker; CI = confidence interval; CKD = chronic kidney disease; CVD = cerebrovascular disease; DBP = diastolic blood pressure; DM = diabetes mellitus; HOT = Hypertension Optimal Treatment; JATOS = Japanese Trial to Assess Optimal Systolic Blood Pressure in Elderly Hypertensive Patients; mg = milligram; MI = myocardial infarction; N/n = population size (total/sub); NR = not reported; ns = not statistically significant; OR = odds ratio; SBP = systolic blood pressure; SD = standard deviation; SPRINT = Systolic Blood Pressure Intervention Trial; SPS3 = Secondary Prevention of Small Subcortical Strokes; T = treatment; VALISH = Valsartan in Elderly Isolated Systolic Hypertension.

Table 3 Characteristics of Trials that Compared More vs Less Intensive Antihypertensive Treatment

Study BP goal (mm Hg) Mean or median^*^ length of follow-up | Antihypertensive treatment strategies | Sample size, T vs C Age mean (SD) % Male | Comorbidities % DM % CAD % CVD | Baseline SBP/DBP, T vs C | Achieved SBP/DBP, T vs C | Mean number or % distribution of antihypertensive medications used, T vs C
ADVANCE, 2007^27^ Goal NR 4.3 years | T: Perindopril + indapamide ± physician's discretion C: Placebo ± physician's discretion Not permitted: thiazide diuretics, other ACEI | 5569 vs 5571 66 (6.5) 57% | 100% DM 12% CAD 9% CVD | 145/81 vs 145/81 | 136/73 vs 140/73 | % using drug (at end of follow-up): Any BP lowering drug: 74 vs 83 Perindopril: 45 vs 55 Other ACEI: 5 vs 5 ARB: 10 vs 13 β-B: 31 vs 35 CCB: 32 vs 43 Thiazides: 3 vs 5 Other diuretics: 14 vs 16
BENEDICT-B, 2011^28^ ≤ 120/80 mm Hg 4.5 years | T: VeraTran (Verapamil + trandolapril) ± physician's discretion C: Trandolapril ± physician's discretion | 138 vs 143 62.3 (8.3) 62.4% | 100% DM | 149.5/86.3 overall | 141.0/81.6 vs 141.8/82.3 | % using drug (on follow-up): Any antihypertensive agent: 94.9 vs 92.3 Diuretic: 87.7 vs 84.6 β-B: 14.5 vs 16.1 CCB: 44.2 vs 50.3 Sympatholytic agent: 66.7 vs 69.9 P = ns
EWPHE, 1985^29^ ≤ 160/90 mm Hg 4.7 years | T: Hydrochlorothiazide + triamterene ± methyldopa C: Placebo | 416 vs 424 72 (8.0) 69.8% | 3.5% CAD 1.2% CVD | 183/101 vs 182/101 | 148/85 vs 167/90 | Used by % of treatment group in addition to active study medication: Methyldopa: 35%
FEVER, 2005^30^ < 160/95 mm Hg 3.3 years | T: Felodipine ± physician's discretion C: Placebo ± physician's discretion | 4841 vs 4870 61.5 (7.2) 61% | 12.8% DM 15.5% CAD 14.9% CVD | 158.7/92.4 vs 158.9/92.7 | 138.1/82.3 vs 141.6/83.9 | Add-on medication used by % of group: No add-on: 66.1 vs 57.7 (P < .001) Diuretic: 12.6 vs 19.8 (P < .001) β-B: 7.3 vs 8.8 (P = .008) α-B: 0.2 vs 0.6 (P = .004) ACEI: 16.8 vs 26.0 (P < .001) ARB: 0.9 vs 1.1 (P = .325) CCB: 12.1 vs 12.8 (P = .263) Other antihypertensive medications: 5.5 vs 8.2 (P < .001)
HYVET, 2008^6^ < 150/80 mm Hg 1.8^*^ years | T: Indapamide ± perindopril C: Placebo Patients withdrawn from double-blind follow-up if used additional antihypertensive agents for > 3 months, or had received the maximum dose of the study drugs yet had SBP ≥ 220 mm Hg or DBP ≥ 110 mm Hg on at least 2 consecutive visits ≥ 2 weeks apart. | 1933 vs 1912 83.5 (3.2) 60.5% | 6.9% DM 3.2% CAD 6.8% CVD | 173/90.8 vs 173/90.8 | 143.5/77.9 vs 158.5/84.0 | % using drug or corresponding placebo (at 2-year follow-up): Indapamide only: 25.8 vs 14.2 (corresponding placebo) Indapamide + perindopril (2 mg): 23.9 vs 13.4 (corresponding placebo) Indapamide + perindopril (4 mg): 49.5 vs 71.8 (corresponding placebo)
PROGRESS, 2001^31^ Goal NR 3.9 years | T: Perindopril ± indapamide C: Placebo | 3051 vs 3054 64 (10.0) 70% | 13% DM 100% CVD | 147/86 vs 147/86 | 138/82 vs 147/86 | % of treatment group assigned to use: Perindopril only = 42% Perindopril + Indapamide = 58%
RENAAL, 2001^32^ < 140/90 mm Hg 3.4 years | T: Losartan ± physician's discretion C: Placebo ± physician's discretion Not permitted: ACEIs, ARBs | 751 vs 762 60 (7.0) 63.2% | 100% DM 11% CAD 0.1% CVD | 152/82 vs 153/82 | 140/74 vs 142/74 | A mean of 3.5 different antihypertensive medications were used in addition to the randomized drug to achieve BP goal of < 140/90 mm Hg. % using drug: CCB: 77.9 vs 81.1 Diuretic: 83.8 vs 84.0 α-B: 40.2 vs 45.7 β-B: 34.1 vs 36.7 Centrally acting agent: 18.0 vs 21.7
SCOPE, 2003^33^ < 160/85 mm Hg 3.7 years | T: Candesartan ± physician's discretion C: Placebo ± physician's discretion Not permitted: ACEIs, ARBs | 2477 vs 2460 76.4 (NR) 64.5% | 12% DM 4.5% CAD 3.9% CVD | 166.0/90.3 vs 166.5/90.4 | 145.2/79.9 vs 148.5/81.6 | % using drug: Study drug only: 25 vs 16 Study drug + hydrochlorothiazide: 26 vs 18 Add-on treatment: 49 vs 66 Diuretic: 33 vs 44 β-B: 17 vs 26 CCB: 18 vs 28 ACEI: 8 vs 11 ARB: 3 vs 4
SHEP, 1991^8^ SBP < 160 mm Hg or reduction of ≥ 20 mm Hg^a^ 4.5 years | T: Chlorthalidone ± atenolol or reserpine C: Placebo Upper BP threshold above which active treatment indicated in placebo arm (escape criteria): SBP > 240 mm Hg or DBP > 115 mm Hg at a single visit, or sustained SBP > 220 mm Hg or DBP > 90 mm Hg. | 2365 vs 2371 71.6 (6.7) 64.5% | 10.1% DM 4.9% CAD 1.4% CVD | 170.5/76.7 vs 170.1/76.4 | 143/68 vs 155/72 | 0 (No active drug): 9% vs 53% 1: Chlorthalidone: 46% of treatment group 2: Chlorthalidone + atenolol: 23% of treatment group Other active medication: 21% of treatment group % meeting escape criteria: 3 vs 15 % prescribed active hypertensive therapy in placebo group: 13% at year 1, 33% at year 3, 44% at year 5
STONE, 1996^19^ 140-159/< 90 mm Hg 2.5 years | T: Nifedipene ± captopril ± dihydrochlorothiazide C: Placebo Upper BP threshold above which active treatment (captopril ± dihydrochlorothiazide) indicated in placebo arm: SBP ≥ 200 mm Hg or DBP ≥ 110 mm Hg at 2 subsequent follow-ups. | 815 vs 817 66.4 (5.3) 46.8% | NR | 168/99 vs 168/97 | 146.9/85.0 vs 156.2/89.3 | 0: 98.8% of placebo 1: Nifedipene only was used by 99.1% of treatment group
Syst-China, 2000^20^ SBP < 150 mm Hg (reduction of ≥ 20 mm Hg) 3.0^*^ years | T: Nitrendipine ± captopril ± hydrochlorothiazide C: Placebo | 1253 vs 1141 66.5 (5.5) 65.5% | 4.1% DM 11.2% CVD | 170.5/86.0 overall, T vs C NR | 150.5/81 vs 159.5/84 | 1: Nitrendipine only: 72.3% vs 57.0% (corresponding placebo) 2+: Combination of nitrendipine ± captopril ± hydrochlorothiazide: 20.0% vs 32.9% (corresponding placebo)
Syst-Eur, 2014^34^ SBP < 150 mm Hg (reduction of ≥ 20 mm Hg) 2.0^*^ years | T: Nitrendipine ± enalapril ± hydrochlorothiazide C: Placebo | 2297 vs 2398 70.25 (6.7) 33.2% | 10.5% DM 29.8% CAD | 173.8 vs 85.5 overall, P = ns for T vs C | NR | 0: 14.9% of placebo 1: 55.0% of treatment 2: 26.1% of treatment 3: 16.4% of treatment % using drug or corresponding placebo (at 2-year follow-up): Nitrendipine: 84.4 vs 92.4 (corresponding placebo) Enalapril: 32.6 vs 55.1 (corresponding placebo) Hydrochlorothiazide: 16.2 vs 34.2 (corresponding placebo) % of patients started on multiple drug treatment or proceeding to open follow-up increased faster in the placebo group than active treatment group (P < .001)
TRANSCEND, 2008^35^ Goal NR 4.7^*^ years | T: Telmisartan ± physician's discretion C: Placebo ± physician's discretion | 2954 vs 2972 66.9 (7.4) 57% | 35.7% DM 74.5% CAD 22% CVD | 140.7/81.8 vs 141.3/82.0 | NR | % using drug: Non-study ARB: 5.8 vs 7.6 (P = NR) Diuretic: 33.7 vs 40.0 (P < .0001) CCB: 38.0 vs 45.9 (P < .0001) β-B: 56.6 vs 59.0 (P = .081) α-B: 5.3 vs 7.5 (P = .002)

Abbreviations: α-B = alpha-blocker; β-B = beta-blocker; ACEI = Angiotensin converting enzyme inhibitor; ADVANCE = Action in Diabetes and Vascular Disease; ARB = Angiotensin II receptor blockers; BENEDICT-B = Bergamo Nephrologic Diabetes Complications Trial-B; BP = blood pressure; C = control/comparator; CAD = Coronary artery disease; CCB = calcium channel blocker; CVD = Cerebrovascular disease; DBP = Diastolic blood pressure; DM = diabetes mellitus; EWPHE = European Working Party on High Blood Pressure in the Elderly; FEVER = Felodipine Event Reduction Study; HYVET = Hypertension in the Very Elderly Trial; NR = not reported; ns = not statistically significant; PROGRESS = Perindopril Protection Against Recurrent Stroke Study; RENAAL = Reduction of Endpoints in NIDDM with the Angiotensin II Antagonist Losartan; SBP = Systolic blood pressure; SCOPE = Study on Cognition and Prognosis in the Elderly; SD = standard deviation; SHEP = Systolic Hypertension in the Elderly Program; STONE = Shanghai Trial of Nifedipine in the Elderly; Syst-China = Systolic Hypertension in China; Syst-Eur = Systolic Hypertension in Europe; T = treatment; TRANSCEND = Telmisartan Randomized Assessment Study in ACE Intolerant Subjects with Cardiovascular Disease.

a For individuals with SBP ≥180 mm Hg, the goal was < 160 mm Hg; for those with SBP 160-179 mm Hg, the goal was an SBP reduction of ≥ 20 mm Hg.

Target blood pressures varied widely across studies. The SBP treatment target for the more intensive treatment arm ranged from 120 to 150 mm Hg; one study targeted DBP.^17^ Achieved blood pressures also varied widely; SBP in the more intensive arm (either lower target or more intensive therapy) ranged from 119 to 149 mm Hg and in half the trials achieved SBP was ≥ 140 mm Hg. Three studies had ≤ 2 mm Hg difference in achieved SBP between treatment arms.^28,32,35^ All but 3 trials^25,34,35^ reported DBP at trial end, and 14 of these noted a > 1 mm Hg difference between arms in achieved DBP, but only 3 trials^8,11,22^ reported DBP < 70 mm Hg in the more intensive arm and none of the trials reported achieved DBP > 90 mm Hg in the less intensive arm.

The examined patient populations varied widely across studies, from differences in race to differences in burden of comorbid illness. Three studies included only patients with type 2 diabetes,^22,27,32^ 3 excluded all patients with diabetes,^11,19,23^ and 6 excluded patients with type 1 diabetes or insulin-requiring diabetes.^8,17,22,27,29,32^ Five studies enrolled patients with history of stroke or with high cardiovascular risk.^11,25,27,31,35^

Examined outcomes also varied across included trials. Nine of the 21 studies had a composite outcome for the primary outcome,^11,17,22,24,26,27,33,35^ and 6 had a primary outcome related to stroke.^6,8,20,25,30,31^ The remaining studies had primary outcomes related to renal disease or microalbuminuria^28,32^ or additional outcomes not specified of interest for this review (left ventricular hypertrophy regression).^23^ Use of antihypertensive agents varied widely across studies. Among trials which specified a particular medication as first-line therapy, 7 used ACE inhibitor or angiotensin II receptor blockers, 5 used calcium channel blockers, and 6 used diuretics (Tables 2 and 3).

Not surprisingly, differences between study populations and methodologies yielded differences in event rates. The proportion of patients experiencing an event varied from 0.36% to 35.1% for all-cause mortality, from 0.27% to 13.75% percent for stroke, and from 0.26% to 11.39% for major cardiac events.

### Detailed Study Results

#### All Studies

We found varied results across the 21 included studies, but overall more intensive blood pressure treatment was associated with significant reductions in mortality, major cardiac events, and stroke. However, the marked differences among the studies in their baseline, intended, and achieved blood pressures make it difficult to interpret pooled estimates of all results. Rather, we present analyses according to achieved blood pressure, baseline blood pressure, and then focus on those trials which explicitly compared blood pressure treatment targets. Medication choice varied widely among studies but we found no discernible pattern of antihypertensive choice on treatment effects.

There were 3 trials with almost no difference in achieved blood pressure between intervention and control groups (mean difference SBP < 3 mm Hg).^28,32,35^ Another 3 trials rated as high risk of bias had significant methodologic flaws threatening the validity of their results.^19-21^ We conducted sensitivity analyses with and without these studies. One of the studies with high risk of bias was a treat-to-target trial.^21^ The exclusion of this study lowered absolute effect sizes modestly. Otherwise, these sensitivity analyses did not dramatically alter results, but did reduce heterogeneity. In the following sections we present analyses without these 6 studies. Additional analyses are summarized in Appendix D.

Of the remaining 15 studies presented in the following analyses, relatively few individual studies found statistically significant treatment effects (mortality in 4 studies; stroke in 5 studies; cardiac events in 7 studies).

#### Studies Grouped by Achieved Blood Pressure

We performed meta-analyses separately grouping studies with achieved SBP ≥ 140 mm Hg and studies with achieved SBP < 140 mm Hg (Figures 2 to 4). We found similar relative treatment effects for mortality (RR 0.91, 95% Confidence Interval [CI] 0.84 to 0.99, number needed to treat [NNT] 105; I^2^ = 0% for SBP ≥ 140, and RR 0.88, 95% CI 0.81 to 0.96, NNT 91; I^2^ = 18.4% for SBP < 140 mm Hg). We found similar relative treatment effects, but slightly larger absolute effects on major cardiac outcomes among studies achieving higher blood pressure (RR 0.78, 95% CI 0.68 to 0.93, NNT 74; I^2^ = 35.9% for SBP ≥ 140) than among those achieving lower blood pressure (RR 0.82, 95% CI 0.72 to 0.91, NNT 108; I^2^ = 2.1%). There was a more consistent and slightly larger relative treatment effect on stroke among studies achieving SBP ≥ 140 (RR 0.72, 95% CI 0.62 to 0.82, NNT 76; I^2^ = 0%) than among studies achieving SBP < 140 mm Hg (RR 0.80, 95% CI 0.70 to 0.90, NNT 78; I^2^ = 36.5%).

Figure 2 Relative risk of mortality stratified by mean achieved SBP, combining trials by achieved mean SBP ≥ 140 or < 140 mm Hg in the intervention group

ACCORD = Action to Control Cardiovascular Risk in Diabetes; ADVANCE = Action in Diabetes and Vascular Disease; Cardio-Sis = Studio Italiano Sugli Effetti Cardiovascolari del Controllo della Pressione Arteriosa Sistolica; CI = confidence interval; EWPHE = European Working Party on High Blood Pressure in the Elderly; FEVER = Felodipine Event Reduction Study; HOT = Hypertension Optimal Treatment; HYVET = Hypertension in the Very Elderly Trial; JATOS = Japanese Trial to Assess Optimal Systolic Blood Pressure in Elderly Hypertensive Patients; PROGRESS = Perindopril Protection Against Recurrent Stroke Study; SBP = systolic blood pressure; SCOPE = Study on Cognition and Prognosis in the Elderly; SHEP = Systolic Hypertension in the Elderly Program; SPRINT = Systolic Blood Pressure Intervention Trial; SPS3 = Secondary Prevention of Small Subcortical Strokes; Syst-Eur = Systolic Hypertension in Europe; VALISH = Valsartan in Elderly Isolated Systolic Hypertension

Figure 3 Relative risk of stroke stratified by mean achieved SBP, combining trials by achieved mean SBP ≥ 140 or < 140 mm Hg in the intervention group

ACCORD = Action to Control Cardiovascular Risk in Diabetes; ADVANCE = Action in Diabetes and Vascular Disease; Cardio-Sis = Studio Italiano Sugli Effetti Cardiovascolari del Controllo della Pressione Arteriosa Sistolica; CI = confidence interval; EWPHE = European Working Party on High Blood Pressure in the Elderly; FEVER = Felodipine Event Reduction Study; HOT = Hypertension Optimal Treatment; HYVET = Hypertension in the Very Elderly Trial; JATOS = Japanese Trial to Assess Optimal Systolic Blood Pressure in Elderly Hypertensive Patients; PROGRESS = Perindopril Protection Against Recurrent Stroke Study; SBP = systolic blood pressure; SCOPE = Study on Cognition and Prognosis in the Elderly; SHEP = Systolic Hypertension in the Elderly Program; SPRINT = Systolic Blood Pressure Intervention Trial; SPS3 = Secondary Prevention of Small Subcortical Strokes; Syst-Eur = Systolic Hypertension in Europe; VALISH = Valsartan in Elderly Isolated Systolic Hypertension

Figure 4 Relative risk of major cardiac events stratified by mean achieved SBP, combining trials by achieved mean SBP ≥ 140 or < 140 mm Hg in the intervention group

ACCORD = Action to Control Cardiovascular Risk in Diabetes; ADVANCE = Action in Diabetes and Vascular Disease; Cardio-Sis = Studio Italiano Sugli Effetti Cardiovascolari del Controllo della Pressione Arteriosa Sistolica; CI = confidence interval; EWPHE = European Working Party on High Blood Pressure in the Elderly; FEVER = Felodipine Event Reduction Study; HOT = Hypertension Optimal Treatment; HYVET = Hypertension in the Very Elderly Trial; JATOS = Japanese Trial to Assess Optimal Systolic Blood Pressure in Elderly Hypertensive Patients; PROGRESS = Perindopril Protection Against Recurrent Stroke Study; SBP = systolic blood pressure; SCOPE = Study on Cognition and Prognosis in the Elderly; SHEP = Systolic Hypertension in the Elderly Program; SPRINT = Systolic Blood Pressure Intervention Trial; SPS3 = Secondary Prevention of Small Subcortical Strokes; Syst-Eur = Systolic Hypertension in Europe; VALISH = Valsartan in Elderly Isolated Systolic Hypertension

#### Studies Grouped by Baseline Blood Pressure

To better understand the evidence regarding the thresholds at which to start or intensify blood pressure treatment, we analyzed studies according to baseline blood pressure. Nine studies had higher baseline blood pressures (SBP ≥ 160 mm Hg) including all the studies achieving SBP ≥ 140 mm Hg plus 3 studies which achieved lower blood pressures.^23,24,26^ Intensive blood pressure treatment had a more consistent and greater absolute effect on mortality (RR 0.90, 95% CI 0.83 to 0.98, NNT 61, I^2^ = 0%), stroke (RR 0.74, 95% CI 0.65 to 0.84, NNT 89, I^2^ = 0%), and cardiac events (RR 0.77, 95% CI 0.68 to 0.89, NNT 80, I^2^ = 3.2%) in studies of patients with higher baseline blood pressures than in studies of patients with lower baseline blood pressures (mortality RR 0.85, 95% CI 0.72 to 0.99, NNT 118, I^2^ = 53.1%), stroke (RR 0.80, 95% CI 0.62 to 1.01, NNT = 159, I^2^ =67%), and cardiac events (RR 0.86, 95% CI 0.72 to 0.96, NNT 148, I^2^ = 40.6%) (Figure 5). The subgroup with lower baseline blood pressures did not include the 2 trials of patients with prior stroke.^25,31^

Figure 5 Relative risk of death, stroke, and cardiac events, combining trials by mean baseline SBP ≥ 160 or < 160 mm Hg

ACCORD = Action to Control Cardiovascular Risk in Diabetes; ADVANCE = Action in Diabetes and Vascular Disease; Cardio-Sis = Studio Italiano Sugli Effetti Cardiovascolari del Controllo della Pressione Arteriosa Sistolica; CI = confidence interval; EWPHE = European Working Party on High Blood Pressure in the Elderly; FEVER = Felodipine Event Reduction Study; HOT = Hypertension Optimal Treatment; HYVET = Hypertension in the Very Elderly Trial; JATOS = Japanese Trial to Assess Optimal Systolic Blood Pressure in Elderly Hypertensive Patients; RR = relative risk; SBP = systolic blood pressure; SCOPE = Study on Cognition and Prognosis in the Elderly; SHEP = Systolic Hypertension in the Elderly Program; SPRINT = Systolic Blood Pressure Intervention Trial; Syst-Eur = Systolic Hypertension in Europe; VALISH = Valsartan in Elderly Isolated Systolic Hypertension.

#### Studies Comparing Blood Pressure Treatment Targets

The studies that most directly address the controversy of strict versus more moderate blood pressure control are those that compared treatment targets. We found 8 trials comparing lower and higher blood pressure treatment targets (Table 2). One of these trials, which included only patients with prior stroke, is discussed in the next section and is not included in the analyses in this section.^25^ As mentioned previously, another small study with dramatically higher mortality rates had high risk of bias;^21^ we present the sensitivity analyses without this study here but additional analysis results are available in Appendix D. The 6 remaining treat-to-target studies evaluated a total of 32,312 patients and were all low risk of bias.

The largest study, the Hypertension Optimal Treatment (HOT) trial (N = 18,790), evaluated DBP targets while the remaining 5 studies examined SBP targets of ≤ 140 mm Hg in the more intensive control arm. Two of these 5 studies targeted SBP < 140 mm Hg in the more intensive treatment arm,^24,26^ while the remaining 3 used lower SBP targets (< 120 mm Hg^11,22^ and < 130 mm Hg^23^) for the intensive treatment arm. Among the trials specifying initial therapy, 2 used calcium channel blockers,^17,24^ one used an angiotensin II receptor blocker,^26^ and 2 used a thiazide diuretic in combination with another medication.^11,22^ All trials allowed use of the same 4 core antihypertensive drug classes for additional therapy (renin angiotensin system blockade, thiazide diuretics, calcium channel blockers, and beta-blockers). Again, we did not find a consistent pattern of effects according to choice of first-line antihypertensive therapy.

Taken together, these studies show that blood pressure treatment targets of SBP ≤ 140 mm Hg or lower are associated with a non-significant trend toward lower mortality, and have a marginally significant effect on lowering stroke and major cardiac events (Figure 6). These are large trials with low risk of bias, and the meta-analyses suggest acceptable levels of statistical heterogeneity. Nevertheless, the evidence for mortality and cardiac events should be considered low strength because there are important inconsistencies in results, substantial variation in results in different sensitivity analyses, and because the results are imprecise with relatively wide confidence intervals around the summary estimates encompassing both the possibility of marked risk reduction and no effect. For the outcome of stroke, the direction and magnitude of effect was more consistent across analyses and, therefore, the strength of evidence for this outcome should be considered moderate.

Figure 6 Relative risk of death, stroke, and cardiac events in trials in which the intervention arm had an SBP target < 140 mm Hg or DBP ≤ 85 mm Hg, and the control arm had a less strict blood pressure target

ACCORD = Action to Control Cardiovascular Risk in Diabetes; C = control; Cardio-Sis = Studio Italiano Sugli Effetti Cardiovascolari del Controllo della Pressione Arteriosa Sistolica; CI = confidence interval; DBP = diastolic blood pressure; HOT = Hypertension Optimal Treatment; JATOS = Japanese Trial to Assess Optimal Systolic Blood Pressure in Elderly Hypertensive Patients; RR = relative risk; SBP = systolic blood pressure; T = treatment; VALISH = Valsartan in Elderly Isolated Systolic Hypertension

We found that the absolute treatment effects varied in our sensitivity analyses. The most pronounced differences involved analyses with the HOT trial.^17^ The HOT trial was by far the largest and in some ways the most difficult to assess both because it assessed DBT targets, and because it included 3 arms each with over 6,000 patients. In the analyses in Figure 6, we grouped the 2 HOT arms with DBP targets of ≤ 85 mm Hg or less together because this was the most relevant comparison when considering current guidelines. The numbers needed to treat over 2 to 5 years to prevent one event were 125 (mortality), 204 (stroke), and 106 (major cardiac events). However, the achieved SBP in the group assigned to a DBP target of ≤ 85 mm Hg was > 140 mm Hg (141.4 mm Hg), while the achieved SBP in the group assigned to a target ≤ 80 mm Hg was 139.7 mm Hg. When we excluded this middle group (DBT target of ≤ 85 mm Hg) from our analyses, we found substantially higher NNT (263 for mortality, 286 for stroke, and 238 for major cardiac events).

The Systolic Blood Pressure Intervention Trial (SPRINT)^11^ and ACCORD^22^ trials are different than the other treat-to-target trials both because of the aggressive intervention group SBP target of < 120 mm Hg, and because the mean baseline SBP was just under 140 mm Hg. Both trials enrolled patients with high cardiovascular risk, but excluded patients on more than 3 antihypertensive medications at baseline. There are several important differences between these 2 studies: 1) ACCORD included only diabetic patients while SPRINT excluded diabetic patients, 2) ACCORD mostly excluded patients ≥ 80 years, and therefore had a population slightly younger than SPRINT (mean age 62 vs 68 years), and 3) the SPRINT trial was stopped early for benefit and consequently had a shorter mean duration of follow-up (3.3 vs 4.7 years). Of note, the proportion of control group participants experiencing each outcome was higher in ACCORD than in SPRINT. As Figure 5 shows, intensive treatment did not reduce mortality or cardiac events in ACCORD, but did reduce the risk of stroke. On the other hand, intensive treatment reduced both mortality and cardiac events in SPRINT, but not stroke risk.

When we removed the SPRINT trial in additional sensitivity analyses, effects on mortality (RR 0.96, 95% CI 0.80 to 1.15, I^2^ = 0%) and cardiac events (RR 0.88, 95% CI 0.74 to 1.04, I^2^ = 4.0%) were no longer significant but effects on stroke remained largely unchanged (RR 0.74, 95% CI 0.56 to 0.99, NNT 182, I^2^ = 25.8%).

Of note, there were marked differences in event rates among the studies. The SPRINT and ACCORD trials each enrolled patients with higher cardiovascular risk profiles and, not surprisingly, had higher mortality and cardiac event rates than the other 4 trials. On the other hand, the stroke event rates were more similar among the trials. It is not clear whether differences in event rates entirely explain the nonsignificant mortality reduction since the inconsistency in findings does not clearly follow event rate patterns. For instance, ACCORD and SPRINT have similar event rates but different findings.

#### Treatment Effects According to DBP

It is difficult to determine whether the treatment effects of blood pressure lowering are mediated through impact on SBP or DBP, or both. The majority of evidence applies most closely to the treatment of SBP. In 15 trials, patients had isolated systolic hypertension (ie, SBP > 140 mm Hg with DBP ≤ 90 mm Hg). There were no trials in which patients had isolated diastolic hypertension with mean DBP > 90 mm Hg and mean SBP < 140 mm Hg.

The HOT trial is most directly relevant as it enrolled patients with high DBP (> 100 mm Hg) and compared, as described above, the effects of 3 DBP targets (≤ 80 vs ≤ 85 vs ≤ 90 mm Hg).^17^ Compared to patients assigned to the ≤ 90 mm Hg target, patients assigned to lower DBP targets experienced a reduced risk of cardiac events (RR 0.92, 95% CI 0.42 to 0.92), but not of stroke (RR 0.74, 95% CI 0.4 to 1.36) or mortality (RR 0.77, 95% CI 0.48 to 1.21). Of note, the mean achieved DBP was substantially less than 90 mm Hg in all 3 groups (81.1, 83.2, and 85.2 mm Hg, respectively) and patients also had marked systolic hypertension at baseline (mean baseline SBP 170 mm Hg).

There were 6 trials with baseline DBP > 90 mm Hg.^6,17,19,29,30,33^ One of the trials had high risk of bias.^19^ In 4 of the other 5 trials, the baseline SBP was ≥ 160 mm Hg and in the other trial the mean baseline SBP was 158.8 mm Hg.^30^ The achieved DBP was < 90 mm Hg in all trials. In 4 of the 5 trials, there was a significant reduction in at least one of our outcomes of interest (in the other, there was a nearly significant reduction in stroke risk).^33^

Overall, patients with DBP > 90 mm Hg appear to benefit from blood pressure-lowering treatment, but these patient populations also had marked moderate to severe systolic hypertension at baseline. There was no evidence to assess whether treatment of diastolic hypertension in the absence of systolic hypertension is beneficial.

## KEY QUESTION 1B In patients who have suffered a TIA or stroke, does treatment of blood pressure to specific targets affect outcomes?

Two trials included in this review limited their patient populations to adults with prior history of cerebrovascular accident (stroke or TIA).^25,31^ The Secondary Prevention of Small Subcortical Strokes (SPS3) trial evaluated potential benefit of SBP < 130 mm Hg versus 130 to 149 mm Hg as secondary stroke prevention for 3,020 adults over age 30 (mean age 63 years). This study included patients with magnetic resonance imaging (MRI)-confirmed lacunar stroke, but excluded those with prior intracranial hemorrhage, severely disabling strokes, and cortical ischemic stroke.^25^ The Perindopril Protection Against Recurrent Stroke Study (PROGRESS) included 6,105 adults over age 26 (mean age 64 years) with history of ischemic or hemorrhagic stroke, or TIA.^31^ Participants were randomized to placebo or active treatment including an ACE inhibitor to which a diuretic could be added at the discretion of the treating physician. The achieved SBP in the treatment group ranged from 135 to 138 mm Hg (depending on receipt of single or dual therapy).

Pooled analysis of data from these 2 trials showed more intensive versus less intensive blood pressure management decreased the risk of recurrent stroke (RR 0.76, 95% CI 0.66 to 0.92, NNT 33, I^2^ = 0%), but not cardiac events (RR 0.78, 95% CI 0.61-1.08) or mortality (RR 0.96, 95% CI 0.86 to 1.12) (Figure 7 and Appendix D). Of note, the results from these trials do not apply to the management of acute stroke.

Figure 7 Relative risk of stroke in trials of patients with history of stroke

CI = confidence interval; PROGRESS = Perindopril Protection Against Recurrent Stroke Study; SPS3 = Secondary Prevention of Small Subcortical Strokes

## KEY QUESTION 2 How does age modify the benefits of differing blood pressure targets?

### Overview of Results

Twelve of the 21 included trials conducted age-stratified analyses (Table 4). We found no evidence that age modifies treatment effects: 12 trials found no age-treatment interactions on health outcome effects, and 3 trials found that the rate of harms from more intensive treatment was similar in those age ≥ 75 years and < 75 years.

Table 4 Effects of Age on Outcomes in Trials that Conducted Age-Stratified Analyses

Direction of association | Study Comparison, T vs C Age stratification | Findings
Beneficial effects decrease with age | JATOS^24^ SBP < 140 vs < 160 mm Hg Age: < 75, ≥ 75 | Significant age-treatment interaction: benefit of treatment on stroke, cardiac events, and renal failure was limited to those < 75 years old.
Beneficial effects decrease with age | SPS3^39^ SBP < 130 vs 130-149 mm Hg Age: < 75, ≥ 75 | Benefit of treatment on recurrent stroke was limited to those < 75 years old.
Beneficial effects decrease with age | Syst-China^20^ (Nitrendipine ± captopril ± hydrochlorothiazide) vs placebo Age: < 65, 65-69, ≥ 70 | Benefit of treatment on cardiac events and cardiovascular death was limited to those < 65 years old.
Beneficial effects decrease with age | Syst-Eur^40^ (Nitrendipine ± enalapril ± hydrochlorothiazide) vs placebo Age: 60-69, 70-79, ≥ 80 | Significant age-treatment interaction: benefit of treatment on mortality (all-cause and cardiovascular) and stroke was limited to those < 80 years old.
Beneficial effects increase with age | SHEP^8^ (Chlorthalidone ± atenolol or reserpine) vs placebo Age: 60-69, 70-79, ≥ 80 | Benefit of treatment on stroke was limited to those aged ≥ 70 years old.
Beneficial effects increase with age | SPS3^39^ SBP < 130 vs 130-149 mm Hg Age: < 75, ≥ 75 | Benefit of treatment on vascular death was limited to those aged ≥ 75 years old.
No change in effect with age | ACCORD^37^ SBP < 120 vs < 140 mm Hg Age: < 65, ≥ 65 | Effects of treatment were similar across age groups on composite endpoint (nonfatal MI, nonfatal stroke, or cardiovascular death).
No change in effect with age | ADVANCE^27^ (Perindopril + indapamide) vs placebo Age: < 65, ≥ 65 | Effects of treatment were similar across age groups on combined macrovascular and microvascular events: total death, coronary events, cerebrovascular events, renal events, and eye events (retinopathy and visual deterioration)
No change in effect with age | HOT^38^ DBP ≤ 80 vs ≤ 85 vs ≤ 90 mm Hg Age: < 65, ≥ 65 | Effects of treatment on total death, cardiovascular death, MI/cardiac events, and stroke were similar across age groups
No change in effect with age | HYVET^36^ (Indapamide ± perindopril) vs placebo Age: 80-84, ≥ 85 | Effects of treatment on total death, cardiovascular death, MI/cardiac events, and stroke were similar across age groups.
No change in effect with age | SPRINT^11^ SBP < 120 vs 140 mm Hg Age < 75, ≥ 75 | Benefit of treatment on composite outcome (MI, other acute coronary syndromes, stroke, heart failure, or cardiovascular death) increased from marginally to statistically significant in aged ≥ 75 years old, but age-treatment interaction was not significant.
No change in effect with age | SPS3^39^ SBP < 130 vs 130-149 mm Hg Age: < 75, ≥ 75 | Effects of treatment on MI and total mortality were similar across age groups.
No change in effect with age | TRANSCEND^35^ Telmisartan vs placebo Age: < 65, 65-74, ≥ 75 | Effects of treatment were similar across age groups on composite endpoint (cardiovascular death, MI, or stroke).
No change in effect with age | VALISH^26^ SBP < 140 vs < 150 mm Hg Age: < 75, ≥ 75 | Effects of treatment were similar across age groups on composite endpoint: sudden death, fatal and nonfatal stroke, fatal and nonfatal myocardial infarction, heart failure death, other cardiovascular death, unplanned hospitalization because of cardiovascular diseases, renal dysfunction (doubling of serum creatinine and creatinine, or introduction of dialysis).

Abbreviations: ACCORD = Action to Control Cardiovascular Risk in Diabetes; ADVANCE = Action in Diabetes and Vascular Disease; C = comparator/control; DBP = diastolic blood pressure; HOT = Hypertension Optimal Treatment; HYVET = Hypertension in the Very Elderly Trial; JATOS = Japanese Trial to Assess Optimal Systolic Blood Pressure in Elderly Hypertensive Patients; MI = myocardial infarction; SBP = systolic blood pressure; SHEP = Systolic Hypertension in the Elderly Program; SPRINT = Systolic Blood Pressure Intervention Trial; SPS3 = Secondary Prevention of Small Subcortical Strokes; Syst-China = Systolic Hypertension in China; Syst-Eur = Systolic Hypertension in Europe; T = treatment; TRANSCEND = Telmisartan Randomized Assessment Study in ACE Intolerant Subjects with Cardiovascular Disease; VALISH = Valsartan in Elderly Isolated Systolic Hypertension.

### Detailed Results

We conducted meta-analyses according to mean age and found similar results in studies with mean age ≥ 70 and < 70 for mortality (mean age ≥ 70: RR 0.91, 95% CI 0.84 to 0.99, NNT 133, I^2^ = 0%; mean age < 70: RR 0.86, 95% CI 0.75 to 0.95, NNT 76, I^2^ = 39.4%); stroke (mean age ≥ 70: RR 0.75, 95% CI 0.66 to 0.86, NNT 101, I^2^ = 0%; mean age < 70: RR 0.76, 95% CI 0.66 to 0.86, NNT 68, I^2^ = 42.6%); and cardiac events (mean age ≥ 70: RR 0.79, 95% CI 0.69 to 0.94, NNT 101, I^2^ = 0%; mean age < 70: RR 0.82, 95% CI 0.71 to 0.90, NNT 68, I^2^ = 42.6%). However, we mainly did these analyses to ensure that our findings were not disproportionately driven by studies with lower mean age populations which may have included substantial proportions of patients over age 60. Because of concerns for ecologic fallacy, these analyses cannot reliably estimate age-treatment effects. Rather, we summarize analyses from studies which specifically examined age-treatment interactions.

Of the 12 trials that provided analyses by age subgroups, 5 randomized patients to different blood pressure targets,^17,22,24-26^ and 6 randomized patients to more versus less antihypertensive therapy.^6,8,20,27,34,35^ All of these studies were considered low risk of bias with the exception of one study that used insufficient methods for randomization and allocation concealment.^20^ Seven studies provided age analyses which differentiated adults over age 70 from their younger peers; these analyses were generally for adults ages greater or less than 75 years,^24,26^ or by age bands which included age ≥ 70 as compared to younger patients.^8,35,36^ The remaining 5 studies provided analyses by age greater or less than 65 years.^20,26,27,37-39^ Given that we limited our review to studies with mean population over age 60, these analyses could not meaningfully address our question about the role that advancing age may play in mitigating or modifying the benefits of differing blood pressure targets.

Results were mixed among the 7 studies which performed age-specific analyses for adults ages ≥ 70. The Japanese Trial to Assess Optimal Systolic Blood Pressure in Elderly Hypertensive Patients (JATOS) described an increased risk of cardiovascular disease, cerebrovascular disease, and renal failure when SBP was targeted to be < 140 mm Hg for adults age ≥ 75 but this increase in risk was not demonstrated among their younger peers.^24^ Conversely, in the SHEP trial in which the patient population had a mean SBP of 170 mm Hg, the decreased risk of stroke associated with achieving SBP was < 150 mm Hg was seen in adults over age 70 but not in their younger counterparts.^8^

In the SPRINT trial, participants assigned to an SBP target of < 120 mm Hg experienced a reduction in cardiac events and there was no significant interaction between age and treatment.^11^ This reduction was marginally significant in those under age 75, but statistically significant in the subgroup over age 75, likely because of the substantially higher event rates in this group. The Hypertension in the Very Elderly Trial (HYVET) examined the benefit of blood pressure control among adults aged 80 to 84 years versus aged ≥ 85 years, and demonstrated decreased risk of cardiovascular mortality and stroke for both age groups, but unclear benefit among those aged ≥ 85 on risk of cardiac events and all-cause mortality.^36^ Similarly, in the VALISH study, there was no significant difference in a composite cardiac event outcome for adults older and younger than 75 years.^26^ Age-specific results for the Syst-Eur trial are difficult to interpret because they are presented as unadjusted hazard ratios without 95% confidence intervals,^40^ and the Telmisartan Randomized Assessment Study in ACE Intolerant Subjects with Cardiovascular Disease (TRANSCEND) trial reported only a non-significant P-value of 0.8 for interaction by age.^35^

## KEY QUESTION 3 How does the patient burden of comorbidities modify the benefits of differing blood pressure targets?

### Comorbidity Burden

No studies examined how comorbidity burden modifies blood pressure treatment effects.

Of note, it is likely that patients with a high burden of comorbidity were not included in the overall group of studies. Table 5 details the types of comorbidity that were excluded from each trial. Fourteen trials excluded patients with heart failure, 11 excluded patients with recent cardiac events, 17 excluded patients based on abnormal renal function criteria, 12 trials excluded patients with malignancy or other life-limiting illness, and 15 studies used criteria that would implicitly or explicitly exclude patients with dementia and/or diminished functional status.

Table 5 Patient characteristics used to determine eligibility or exclusion from trial enrollment

Trial; Age mean (SD) | Diabetes status | Chronic Kidney Disease | Heart failure (HF) | Criteria likely to exclude those with dementia or diminished functional status^*^ | Comorbidity
ACCORD^22^ 62.2 (6.9) years | T2 DM required for inclusion; T1 DM excluded | Excluded (Creatinine > 1.5 mg/dL); - Men eGFR no < 45; - Women eGFR no < 33 | Excluded symptomatic HF (NYHA III or IV) | - Excluded for any factors likely to limit adherence to intervention; - Excluded those living in SNF | Excluded for: BMI > 45, LFTs > 2 times the upper limit normal limit, cardiac event/procedure within 3 months, or “any condition likely to limit survival to < 3 years or malignancy” (exclude non-melanoma skin cancer)
ADVANCE^27^ 66 (6) years | T2-DM diagnosis age ≥ 30 required for inclusion. Excluded if “definite indication for long-term insulin therapy at study entry.” | --- | --- | --- | Excluded if definite indication for ACEI not met by perindopril 2 mg or 4 mg.
BENEDICT-B^28^ 62.3 (8.3) years | --- | Excluded for creatinine > 1.5; non-DM renal disease; or history of kidney transplant; - Men no eGFR < 46; - Women no eGFR < 34 | Excluded for HF (NYHA III or IV) | Excluded for “any major clinical condition that may jeopardize study participation.” | Excluded for: history of CVA, AMI, TIA, unstable angina, cancer, “systemic disease,” severe hematologic or liver disorder, malabsorption, valvular disease or heart block.
CARDIO-SIS^23^ 67 (7) years | DM excluded | Excluded (Creatinine > 2 mg/dL); - Men eGFR no < 33; - Women eGFR no < 24 | Unclear; - LVH and valvular heart disease excluded | --- | Excluded for: diabetes, atrial fibrillation/flutter, “clinically significant hepatic or hematologic disorder, alcoholism or drug addiction, valvular heart disease, LVH (or other confounders to EKG interpretation), or any disease causing reduced life expectancy”
EWPHE^29^ 72 (8) years | Excluded DM requiring insulin therapy | Creatinine ≥ 2.5 mg/dL; - Men eGFR no < 25; - Women no eGFR < 19 | Excluded for HF | Inability to achieve a sitting position | Excluded for: hypertensive retinopathy, history of cerebral or subarachnoid hemorrhage, or concurrent disease including hepatitis/cirrhosis, gout, and malignancy.
FEVER^30^ 61.5 (7.2) years | --- | Excluded (Creatinine > 2); - Men eGFR no < 32; - Women no eGFR < 24 | Excluded for cardiomyopathy | - Excluded for “unwillingness to cooperate” | Excluded for: CVA or MI within 6 months, unstable angina, gout, uncontrolled DM, “Serious pulmonary or hepatic disease.”
HOT^17^ 61.5 (7.5) years | Excluded DM requiring insulin therapy | --- | Excluded for HF | --- | Excluded for CVA or MI within 12 months, serious concomitant disease which could affect 2-3 years survival, or requirement for β-B, ACEI or diuretic for reasons other than hypertension.
HYVET^6^ 83.5 (3.2) years | --- | Excluded for creatinine > 1.7; - Men eGFR no < 39; - Women no eGFR < 29 | Excluded for “overt” clinical CHF requiring ACEI or diuretics | - Excluded for dementia; - Excluded those living in SNF; - Excluded for inability to stand up or walk | Excluded for: any condition expected to severely limit survival (terminal illness), cerebral or subarachnoid hemorrhage in past 6 months, gout, hypertensive retinopathy.
JATOS^24^ 73.6 (5.2) years | Excluded for DM if HgA1c > 8 | Excluded for creatinine > 1.5; - Men eGFR no < 44; - Women no eGFR < 33 | Excluded for HF (NYHA II or higher) | - Excluded if “considered unsuitable as subjects.” | Excluded for: history of MI/angioplasty in 6 months prior, atrial fibrillation, hypertensive retinopathy, AST or ALT more than double upper limit of normal, malignant disease or collagen disease.
PROGRESS^31^ 64 (10) years | --- | Unclear. Excluded if had “a definite indication for ACEI” which would include proteinuria. | Unclear. Excluded if had “a definite indication for ACEI” and HF given as example. | - Excluded for “disability that is likely to prevent regular attendance at study clinics.” | ---
RENAAL^32^ 60 (7) years | T2 DM required for inclusion; T1 DM excluded | Excluded relatively severe disease (eGFR < 16 for women and < 21 for men). | Excluded for HF | --- | Excluded for: non-diabetic renal disease, history of MI/CABG within 1 month, CVA within 6 months, TIA within 12 months
SCOPE^33^ 76.4 years (NR) | --- | Excluded for creatinine > 2 in men and > 1.6 in women.; - Men eGFR no < 32; - Women no eGFR< 30 | Excluded for decompensated HF | - Excluded for dementia; - Excluded those with conditions which preclude MMSE (poor vision, aphasia, paralysis, other speech disorders, poor literacy) | Excluded for: CVA or MI within 6 months, LFTs > 3 times the upper limit of normal limit, “serious concomitant disease affecting survival,” alcohol/drug abuse, orthostasis, or disorders likely to affect cognition (including vitamin B12 deficiency, new hypothyroidism, neurosyphilis, AIDS, or severe depression).
SHEP^8^ 71.6 (6.7) years | Excluded DM requiring insulin therapy | Excluded for “history of renal insufficiency” (no additional definition provided) | --- | - Excluded for dementia; - Excluded if “presence of medical management problems.” | Excluded for: atrial fibrillation or flutter, AV block, bradycardia. Recent MI or CVA, CABG within prior 6 months, and history of alcohol abuse
SPRINT^11^ 67.9 (9.5) | DM excluded | Excluded for eGFR < 20 | Excluded; - for symptomatic HF within 6 months or ejection fraction < 35% | - Excluded for dementia; - Excluded those living in SNF; - Excluded for factors judged likely to limit adherence to interventions. | Excluded for history of CVA, or “a medical condition likely to limit survival to less than 3 years or a cancer diagnosed/treated in prior 2 years likely to limit trial completion.
SPS3^25^ 63 (11) | --- | --- | --- | --- | Excluded if ICH from non-trauma, cortical ischemic stroke, or severely disabling stroke.
STONE^19^ 66.4 (5.3) | DM excluded | Excluded for azotemia (BUN > 40) | Excluded for HF | --- | Excluded for: angina, MI, severe arrhythmia, atrial fibrillation, COPD, cirrhosis, cancer, and diabetes.
Syst-China^20^ 66.5 (5.5) | --- | Excluded for creatinine > 2; - Men eGFR no < 33; - Women no eGFR < 24 | Excluded for HF | - Excluded for dementia; - Excluded for “lack of cooperation.” | Excluded for: heart disease, renal or eye manifestations of hypertension, peripheral vascular disease, intracranial hemorrhage or sub arachnoid hemorrhage, MI within 1 year, valvular heart disease, hematologic malignancy or cancer, hyperthyroidism, gout, estrogen hormonal therapy or clotting disorders.
Syst-Eur^34^ 70.25 (6.7) | Excluded DM if blood sugar not “adequately controlled.” | Excluded for creatinine > 2.; - Men eGFR no < 33; - Women eGFR no < 24 | Excluded for other diseases that require continuous use of BP lowering drugs including diuretics, ACEI, CCBs, or β-B. | - Excluded for dementia; - Excluded for any condition which precludes a sitting or standing condition. | Excluded for: severe sequelae of hypertension (retinopathy, dissection), SAH or cerebral hypertension, nosebleeds, if MI in the year prior, malignancy or hepatic dysfunction, or poorly controlled DM.
TRANSCEND^35^ 66.9 (7.4) | --- | Excluded for proteinuria | Excluded for symptomatic CHF | Excluded for significant disability precluding regular follow-up visits. | Excluded for other major non-cardiac illness expected to reduce life expectancy.
VALISH^26^ 76.1 (4.1) | --- | Excluded for creatinine > 2; - Men eGFR no < 32; - Women no eGFR < 24 | Excluded for HF (NYHA III or higher) | - Excluded if “judged to be inappropriate” for the study by the investigator. | Excluded for: history of CVA or MI within 6 months, angioplasty within 6 months or planned, atrial fibrillation /flutter, severe aortic stenosis or valvular disease, or “serious” liver dysfunction.
Wei, 2013^21^ 76.6 (4.6) | --- | Excluded for creatinine > 3; - Men eGFR no < 20; - Women no eGFR < 15 | Excluded for HF (NYHA III or higher) or ejection fraction < 40% | - Excluded for diagnosis of Alzheimer's disease | Excluded for: valvular heart disease, MI or CVA in 6 months prior, hepatic dysfunction, autoimmune disorders, malignant tumor, and “other non-cardiovascular diseases potentially causing death before the end of the study.”

Abbreviations: ACCORD = Action to Control Cardiovascular Risk in Diabetes; ACEI = Angiotensin converting enzyme inhibitor; ADVANCE = Action in Diabetes and Vascular Disease; AIDS = acquired immune deficiency syndrome; ALT = alanine aminotransferase; AMI = acute myocardial infarction; AST = aspartate aminotransferase; AV = atrioventricular; β-B = Beta-blocker; BENEDICT-B = Bergamo Nephrologic Diabetes Complications Trial-B; BMI = body mass index; BP = blood pressure; BUN = blood urea nitrogen; CABG = coronary artery bypass grafting; CCB = calcium channel blocker; CHF = congestive heart failure; COPD = chronic obstructive pulmonary disease; CVA = cerebrovascular accident; DM = diabetes mellitus (T2 = type 2, T1= type 1); EKG = electrocardiogram; EWPHE = European Working Party on High Blood Pressure in the Elderly; FEVER = Felodipine Event Reduction Study; HF = heart failure; HOT = Hypertension Optimal Treatment; HYVET = Hypertension in the Very Elderly Trial; ICH = intracerebral hemorrhage; JATOS = Japanese Trial to Assess Optimal Systolic Blood Pressure in Elderly Hypertensive Patients; LFT = liver function tests; LVH = left ventricular hypertrophy; MI = myocardial infarction; MMSE = mini-mental state examination; NR = not reported; NYHA = New York Heart Association; PROGRESS = Perindopril Protection Against Recurrent Stroke Study; RENAAL = Reduction of Endpoints in NIDDM with the Angiotensin II Antagonist Losartan; SCOPE = Study on Cognition and Prognosis in the Elderly; SD = standard deviation; SAH = subarachnoid hemorrhage; TRANSCEND = Telmisartan Randomized Assessment Study in ACE Intolerant Subjects with Cardiovascular Disease; SHEP = Systolic Hypertension in the Elderly Program; SNF = skilled nursing facility; SPRINT = Systolic Blood Pressure Intervention Trial; SPS3 = Secondary Prevention of Small Subcortical Strokes; STONE = Shanghai Trial of Nifedipine in the Elderly; Syst-China = Systolic Hypertension in China; Syst-Eur = Systolic Hypertension in Europe; TIA = transient ischemic attack; VALISH = Valsartan in Elderly Isolated Systolic Hypertension.

Notes: Specific exclusion criteria related to type of hypertension (ex: excluded based on secondary hypertension) is not noted here. If mean age was provided by treatment group, mean age by active treatment is listed in column 1. Estimated glomerular filtration rate (eGFR) is calculated using approximated upper end of age range for a given study via the 4-variable MDRD equation.

### Cardiovascular Risk

We found subgroup analyses from 4 trials which examined whether treatment effects varied according to cardiovascular risk profile.^41-43^ These studies provide low-strength evidence that there may be greater absolute treatment effects amongst patients with high cardiovascular risk though relative treatment effects are similar across risk groups. Confidence in these conclusions is tempered by the post hoc nature of some of these analyses, the small number of studies, and variation in the outcomes contributing to these findings.

One substudy of SHEP reported outcomes according to quartiles of cardiovascular risk based on the Multiple Risk Factor Assessment Equation.^43^ The number needed to treat for one year to prevent a major cardiac event (myocardial infarction, stroke, or heart failure) ranged from 160 in the lowest risk group to 37 in the highest risk group. A reduction in heart failure incidence appeared to be the major contributor to these findings, while findings for stroke and myocardial infarction were not significant for most of the subgroups.

A substudy grouped participants in the ADVANCE trial into moderate-high and very high 5-year cardiovascular risk according to the Framingham Anderson equation.^41^ Similar to the SHEP substudy, these authors found that relative risks remained similar across subgroups (and were often non- or marginally significant), but absolute risk reductions were higher in the very high cardiovascular risk group. For example, the absolute risk reduction for total coronary events was 0.5% in the moderate-high risk group but 2.0% in the very high risk group.

An analysis of the HOT trial similarly grouped participants into medium-high and very high cardiovascular risk according to a World Health Organization (WHO) risk tool.^42^ This study did not report absolute event rates and found no significant relative risk reduction in either risk group for any outcome, except for myocardial infarction in which there was a significant reduction in the higher risk group (RR 0.77, 95% CI 0.62 to 0.96) but not in the moderate risk group (RR 0.99, 95% CI 0.76 to 1.29).

In the SPRINT trial, the cardiac event risk reduction was actually greater in those without a history of cardiovascular disease (RR 0.71, 95% CI 0.57 to 0.88 vs RR 0.83, 95% CI 0.62 to 1.09) or chronic kidney disease (RR 0.70, 95% CI 0.56 to 0.87 vs RR 0.82, 95% CI 0.63 to 1.07), though the comorbidity-treatment interactions were not significant.^11^

## KEY QUESTION 4 What are the harms of targeting lower blood pressure in older patients? Do the harms vary with age?

### General Adverse Effects

Ten trials compared rates of withdrawal due to adverse events (Table 6). We attempted meta-analysis of these results, but the heterogeneity of treatment effects was excessive (I^2^ = 92.1%, chi-square P < 0.001), precluding the valid estimation of a summary effect. Four trials found more intensive blood pressure treatment was associated with a statistically significant increase in withdrawals due to adverse events, with relative risk increases ranging from 44 to 100%.^8,27,31,35^

Table 6 Renal Outcomes and Other Adverse Effects

Study Comparison, T vs C | Adverse effects that occurred frequently, or differed significantly in frequency, % of T vs C | Renal outcomes, % of T vs C
Trials that compared BP target goals
ACCORD^22^ SBP < 120 vs < 140 | Hypotension: 0.7 vs 0.04 (P < .001) Hyperkalemia: 0.4 vs 0.04 (P = .01) | ESRD or need for dialysis: 2.5 vs 2.4 (P = .93) Elevation in serum creatinine: > 1.5 mg/dl in men: 12.9 vs 8.4 (P < .001) > 1.3 mg/dl in women: 10.9 vs 7.1 (P < .001) Estimated GFR < 30 ml/min/1.73 m^2^: 4.2 vs 2.2 (P < .001)
Cardio-Sis^23^ SBP < 130 vs < 140 | Peripheral edema: 3.2 vs 4.9 (P = .16) Asthenia: 2.3 vs 0.9 (P = .06) Cough: 2.5 vs 1.3 (P = .13) Skin reactions: 2.7 vs 1.4 (P = .21) | NR
HOT^17^ DBP ≤ 80 vs ≤ 85 vs ≤ 90 | AEs that exceeded 2%: Dizziness, headache, leg edema, flushing, and coughing. T vs C not reported. | NR
JATOS^24^ SBP < 140 vs < 160 | Withdrawal due to AE: 1.6 vs 1.6 (P = ns) AEs resulting in discontinuation of treatment: Malignant disease: 0.3 vs 0.5 (P = .31) Psychoneurological symptom: 0.18 vs 0.23 (P = .74) Poor blood pressure control: 0.18 vs 0.23 (P = .74) Cardiac symptom or arrhythmias: 0.32 vs 0.18 (P = .37) Respiratory symptom or disease: 0.18 vs 0.09 (P = .42) | Renal failure: 0.36 vs 0.41 (P = ns)
SPS3^25^ SBP < 130 vs 130-149 | Syncope: 0.7 vs 0.3 (P = .14) | NR
SPRINT^11^ SBP < 120 vs < 140 | Serious AE possibly or definitely related to intervention: 4.7 vs 2.5%; HR 1.88 (P < .001) Hypotension: 2.4 vs 1.4; HR 1.67 (P < .001) Syncope: 2.3 vs 1.7; HR 1.33 (P = .05) Electrolyte abnormality: 3.1 vs 2.3; HR 1.35 (P = .02) Fall resulting in ER visit/hospitalization: 2.2 vs 2.3; HR 0.95 (P = .71) | Acute kidney injury or acute renal failure: 4.1 vs 2.5; HR 1.66 (P < .001)
VALISH^26^ SBP < 140 vs < 150 | Withdrawal due to AE: 1.9 vs 1.2 (P = ns) AEs not otherwise specified. | Renal insufficiency: 0.32 vs 0.13 (P = .267) HR 2.45 (95% CI 0.48 to 12.64), adjusted for sex, age, BMI, smoking, dyslipidemia, diabetes, and anti-hypertension agents used before enrollment.
Wei, 2013^21^ SBP < 140 vs < 150 | Femoral fracture: 0.8 vs 1.3 (P = .716) Vascular dementia: 0.6 vs 0.8 (P = .995) | NR
Trials that compared more vs less intensive antihypertensive treatment
ADVANCE^27^ (Perindopril + indapamide) vs placebo | Withdrawal due to AE: 5.7 vs 2.9 (P < .01) Cough: 3.3 vs 1.3 (P < .01) Hypotension or dizziness: 1.2 vs 0.4 (P < .01) | New or worsening nephropathy: 3.3 vs 3.9 (P = ns) RR reduction: 18% (95% CI, -1 to 32)
BENEDICT-B^28^ VeraTran (verapamil + trandolapril) vs Trandolapril | Withdrawal due to cough: 14.5 vs 9.1 (P = ns) | NR
EWPHE^29^ (Hydrochlorothiazide + Triamterene) vs placebo | Withdrawal due to AE: 6.0 vs 13.2 (P < .01) Withdrawal due to severe increase in BP: 0.5 vs 4.5 (P = .0001) | Death from renal causes: 1.0 vs 0.2 (P = ns) Withdrawn due to 100% increase in serum creatinine: 1.0 vs 0.2 (P = ns) Renal disease: 3.1 vs 0.5 (P < .001) Pyelonephritis: 1.2 vs 0.5 (P = ns) Nephrotic syndrome: 0.2 vs 0 (P = ns) Chronic nephritis: 0.2 vs 0 (P = ns) Renal disease of undetermined origin: 1.4 vs 0 (P = ns)
FEVER^30^ Felodipine vs placebo | AEs reported during treatment: Flushness: 1.4 vs 0.2 (P < .001) Fatigue: 0.64 vs 1.05 (P = .037) Ankle edema: 1.0 vs 0.37 (P < .001) | Renal failure: 0.20 vs 0.16 (P = .5) HR 1.38 (95% CI, 0.54 to 3.52)
HYVET^6^ Indapamide vs placebo | Serious AEs occurred in 18.5 vs 23.4 (P =.001) Types of AEs not specified. | No significant differences between T vs C in changes from baseline in serum creatinine: 3.4 vs 2.3 μmol/L (P =.30) (0.04 vs 0.03 mg/dL)
PROGRESS^31^ (Perindopril ± Indapamide) vs placebo | Withdrawal due to AE: 5.2 vs 3.6 (P < .01) Reasons for discontinuation; Cough: 2.2 vs 0.4 (P < .05) Hypotension: 2.1 vs 0.9 (P < .01) | NR
RENAAL^32^ Losartan vs placebo | Withdrawal due to AE: 17.2 vs 21.7 (P < .05) AEs leading to discontinuation: Increased serum creatinine: 1.5 vs 1.2 (P = ns) Increased serum potassium: 1.1 vs 0.5 (P = ns) | End-stage renal disease: 19.6 vs 25.5 (P = .002); RR 0.77 (95% CI, 0.63 to 0.93) Doubling of serum creatinine: 21.6 vs 26.0 (P = .006) RR 0.83 (95% CI, 0.63 to 0.99)
SCOPE^33^ Candesartan vs placebo | Dizziness/vertigo: 20.9 vs 20.0 (P = ns) Accident/injury: 18.4 vs 18.4 (P = ns) Back pain: 9.2 vs 17.1 (P = ns) Bronchitis: 15.9 vs 16.0 (P = ns) Significant cognitive decline: 13.5 vs 15.2 (P = ns) Dementia: 6.8 vs 6.3 (P = ns) Withdrawal due to AE: 15.0 vs 17.0 (P = .07) | NR
SHEP^8^ Chlorthalidone vs placebo | Chest pain or heaviness: 28.0 vs 21.3 (P < .01) Trouble with memory/concentration: 26.4 vs 20.4 (P < .01) Cold or numb hands: 13.6 vs 9.8 (P < .01) Change in bowel habits: 15.4 vs 11.4 (P < .01) Unusual joint pain: 36.4 vs 31.4 (P < .01) Heart beating unusually slowly: 3.8 vs 2.1 (P < .01) Ankle swelling: 19.5 vs 15.6 (P < .01) Falls: 12.8 vs 10.4 (P < .05) Problems in sexual function: 4.8 vs 3.2 (P < .05) Syncope: 2.2 vs 1.3 (P < .05) Withdrawal due to AE: 13.0 vs 7.0 (P < .05) | Renal dysfunction or death from renal disease: 0.38 vs 0.55 (P = .40) RR 0.65 (95% CI, 0.30 to 1.62)
STONE^19^ Nifedipene vs placebo | NR | NR
Syst-China^20^ (Nitrendipine ± Captopril ± Hydrochlorothiazide) vs placebo | NR | NR
Syst-Eur^44^ Nitrendipine vs placebo | NR | Mild renal dysfunction: 0.22 vs 0.61 (P = .05) Active treatment reduced the rate of dysfunction by 64% (95% CI, 0 to 87%; P = .04) from 2.6 to 0.9 events per 1000 patient-years. In Cox regression with adjustments for sex, age, SBP at entry, previous cardiovascular complications and antihypertensive treatment, body mass index and smoking and alcohol intake at entry, the reduction was 64% (95% CI, 0 to 84%; P < .05). No patient died of renal failure.
TRANSCEND^35^ Telmisartan vs placebo | Withdrawal due to AE: 2.6 vs 1.7 (P < .05) Hypotensive symptoms resulting in withdrawal: 0.98 vs 0.54 (P = .049) | Renal abnormalities that led to study withdrawal: 0.81 vs 0.44 (P = .067)

Abbreviations: ACCORD = Action to Control Cardiovascular Risk in Diabetes; ADVANCE = Action in Diabetes and Vascular Disease; AE = adverse event; BENEDICT-B = Bergamo Nephrologic Diabetes Complications Trial-B; BMI = body mass index; BP = blood pressure; C = comparator/control; Cardio-Sis = Studio Italiano Sugli Effetti Cardiovascolari del Controllo della Pressione Arteriosa Sistolica; CI = confidence interval; DBP = diastolic blood pressure; ER = emergency room; ESRD = end-stage renal disease; EWPHE = European Working Party on High Blood Pressure in the Elderly; FEVER = Felodipine Event Reduction Study; GFR = glomerular filtration rate; HOT = Hypertension Optimal Treatment; HR = hazard ratio; HYVET = Hypertension in the Very Elderly Trial; JATOS = Japanese Trial to Assess Optimal Systolic Blood Pressure in Elderly Hypertensive Patients; NR = not reported; ns = not statistically significant; PROGRESS = Perindopril Protection Against Recurrent Stroke Study; RENAAL = Reduction of Endpoints in NIDDM with the Angiotensin II Antagonist Losartan; RR = relative risk; SBP = systolic blood pressure; SCOPE = Study on Cognition and Prognosis in the Elderly; SHEP = Systolic Hypertension in the Elderly Program; SPRINT = Systolic Blood Pressure Intervention Trial; SPS3 = Secondary Prevention of Small Subcortical Strokes; STONE = Shanghai Trial of Nifedipine in the Elderly; Syst-China = Systolic Hypertension in China; Syst-Eur = Systolic Hypertension in Europe; T = treatment; TRANSCEND = Telmisartan Randomized Assessment Study in ACE Intolerant Subjects with Cardiovascular Disease; VALISH = Valsartan in Elderly Isolated Systolic Hypertension.

Two trials found a trend towards increased adverse events in the intervention group,^26,28^ while 4 trials found the intervention group had the same or lower risk of adverse events.^24,29,32,33^ One trial found a nearly two-fold increase risk of serious adverse events possibly or definitely related to the intervention.^11^ The specific types of adverse events reported varied among trials, though cough or hypotension were among the more frequently reported events (Table 5). There was a higher rate of syncope among those assigned to more aggressive treatment in 2 trials,^8,11^ but not in a third.^25^

### Medication Burden

Tables 2 and 3 list the mean number of antihypertensive medications used in each group when available, or the proportion of each group taking different antihypertensive medications. It is difficult to define the increase in medication burden associated with different treatment targets given variation in reporting. In general, the mean number of medications or the proportion of participants taking multiple medications was higher in the intervention groups.

### Renal Outcomes

We found low-strength evidence from 12 trials that more intensive blood pressure treatment was not associated with worsening of renal outcomes (Table 6). Outcome definitions varied among trials, and event rates of clinically significant outcomes such as end stage renal disease were generally low. Four trials found similar rates of end stage renal disease, need for dialysis, or renal failure in intervention and control groups,^22,24,29,30^ while one trial found that use of an angiotensin II receptor blocker was associated with a lower risk of end stage renal disease.^32^ One trial found an increased risk for acute renal failure with more aggressive blood pressure lowering.^11^

### Cognitive Outcomes

We found moderate-strength evidence from 7 RCTs that use of antihypertensive treatment to achieve moderately strict blood pressure control for up to 5 years does not worsen cognitive outcomes compared to less strict blood pressure control (Table 7). The mean age of trial participants ranged from 62 to 83 years, and baseline cognitive function was generally normal. In most trials, the intervention group achieved SBP in the 140 to 150 mm Hg range, though in one study the intervention group achieved an SBP of 119 mm Hg. Three large-scale trials reported cognitive outcomes for the entire cohort,^45-47^ while 3 other trials prospectively collected cognitive outcomes data for a subpopulation of patients.^8,48,49^ In patients without a prior history of cerebrovascular disease, 3 trials found no difference in rates of incident dementia,^45,47,48^ while one trial found that more intensive blood pressure control was associated with a lower rate of dementia.^46^ A prior meta-analysis of these 4 trials found no significant difference in development of dementia (odds ratio [OR] 0.89, 95% CI 0.74 to 1.07, I^2^ = 17%).^50^ Another trial of patients with a prior history of stroke similarly found no difference in rates of incident dementia (RR 0.88, 95% CI 0.72 to 1.08).^48^ Six of the trials with serial cognitive assessments found the groups did not differ in change in cognitive function over time (Table 6).

Table 7 Cognitive Outcomes Reported in Trials and Prospective Cohort Studies of Hypertension Management in the Elderly

Study Setting | Study overview | Sample size | Age at baseline | Mean or ^*^median follow-up (years) | Baseline cognitive function | Mean achieved BP (mm Hg) T vs C | Results, T vs C | Comments
Randomized controlled trials (RCTs)
ACCORD-MIND^47^ substudy of ACCORD RCT | SBP target < 120 vs SBP target < 140 mm Hg | 1439 | 62 | 3.3 | DSST: 52.28 MMSE: 27.25 | SBP: 119 vs 133.2 DBP: 64 vs 70.2 | Change from baseline: DSST: -1.86 vs -1.61 (P = .55) MMSE: -0.25 vs -0.30 (P = .70) | 199 (13.8%) of enrollees had one or more missing data points, and those with missing follow-up data were slightly older and had slightly lower cognitive function at baseline
Bird, 1990^51^ Medical Research Council multisite outpatient trial, Great Britain RCT | Treat to SBP target < 150 mm Hg if baseline SBP 160-179, or < 160 mm Hg if baseline SBP 180-209; primary intervention medications were hydrochlorothiazide/amiloride or atenolol | 2446 | 70.3 | 0.75 | PALT: 85% scored 16-18 (normal). 14.8% scored 8-15. 25% scored < 8. Trail making test: 63.6% normal (≤ 60 seconds) | SBP: 149 vs 167 DBP: 79 vs 86 | Mean achieved BP atenolol vs hydrochlorothiazide/amiloride vs placebo: 156/79 vs 149/79 vs 167/86 % with abnormal PALT atenolol vs hydrochlorothiazide/amiloride vs placebo: 19.9 vs 21.2 vs 18.5 (P = ns) % with abnormal trail making test (≥ 90 seconds) atenolol vs hydrochlorothiazide/amiloride vs placebo: 5.9 vs 5.7 vs 6.7 (P = ns) | Unclear risk of bias:randomization and allocation concealment procedures not well described; loss to follow-up appears low but poorly reported; little data comparing group baseline characteristics
HYVET-COG^45^ substudy of HYVET RCT | BP target 150/80 vs placebo | 3336 | 83.5 | 2.2 | MMSE: 26 | Mean decrease in SBP: 29.6 vs 14.6 Mean decrease in DBP: 13.1 vs 7.2 | Incident dementia: 126/1687 (7.5%) vs 137/1649 (8.3%) HR 0.86 (95% CI 0.67-1.09) Cognitive decline (fall in MMSE to < 24 or decline of > 3 points in one year): 485/1687 (28.7%) vs 486/1649 (29.5%) HR 0.93 (95% CI 0.82-1.05) | 509 (13.2%) of potentially eligible patients did not meet criteria for inclusion in cognitive substudy because of missing data. However, these patients had similar baseline demographic, education, and cognitive characteristics as included patients.
PROGRESS^48^ Multisite RCT in patients with stroke | Perindopril ± indapamide vs placebo | 6105 | 64 | 3.9 | MMSE: 29 | Reduction in SBP/DBP: 9.0 vs 4.0 | Incident dementia: 193/3051 (6.3%) vs 217/3054 (7.1%) RR 0.88 (95% CI 0.72-1.08) Change in MMSE: -0.05 vs -0.24 (P = .01) Patients with cognitive decline (MMSE decline of 3 or more points): 276/3051 (9.0%) vs 334/3054 (10.9%) RR 0.81 (95% CI 0.68-0.96) | Serial cognitive assessments were available for most patients (96.4%). Dementia assessment done by interviewers blinded to treatment group.
SCOPE^49^ Multisite RCT, cognitive outcomes secondary outcome of parent study | Candesartan vs placebo to achieve BP < 160/90 mm Hg | 4937 | 76.4 | 3.7 | MMSE: 28.5 | SBP: 145.2 vs 148.5 DBP: 79.9 vs 81.6 | Incident dementia: 62/2477 (6.8%) vs 57/2460 (6.3%) (P = ns) Change in MMSE: -0.49 vs -0.64 (P = ns) | Very low loss to follow-up. 99.5% of patients originally randomized were included in analyses. Most (84%) of the control participants also received antihypertensive treatment.
SHEP^8^ Multisite RCT | Thiazide ± atenolol to achieve ≥ 20 mm Hg drop in SBP vs placebo | 4736 | 71.6 | 4.5 | Cognitive impairment score^55^ ≥ 4 (as cited in SHEP^8^), T vs C: 0.3% vs 0.5% | SBP: 144.0 vs 155.1 DBP: 67.7 vs 71.1 | Incident dementia: 37/2365 (1.6%) vs 44/2371 (1.9%) RR 0.84 (95% CI 0.54-1.31) | About 4% in each group referred for dementia evaluation, and about 10% of those referred declined further evaluation. Characteristics of these patients were not described.
Syst-Eur^46^ Dementia substudy of larger multisite European RCT | SBP < 150 mm Hg vs placebo | 2902 | 68 | 3.9^*^ | MMSE: 29 | SBP: 149.1 vs 156.1 DBP: 79.4 vs 82.5 | Incident dementia: 21/1485 (1.4%) vs 43/1417 (3.0%) Rate per 1000 patient-years: 3.3 vs 7.4 (P < .001) Change in MMSE at 3 years: -0.17 vs -0.14 (P = .73) | 326 (10.1%) of eligible cohort did not contribute data to this analysis, but their baseline characteristics are not available.
Prospective cohort studies
Liu, 2013^52^ Indianapolis cohort of the Indianapolis-Ibadan Dementia Project Prospective cohort study | African Americans aged ≥ 65 years with assessment every 2-3 years from 1992-2009 | 2721 | 76 | NR | Median Community Screening Interview for Dementia score (possible score 0-80): 68 (interquartile range 62-72) | NR | Nonlinear association between BP and cognitive function. Optimal cognitive function associated with SBP of about 135 mm Hg and DBP of about 80 mm Hg. | 424 (13.5%) of original cohort had missing data and were excluded. These patients were older and less educated. Used a semiparametric mixed effects model approach in which each patient could contribute several longitudinal observations
Peng, 2014^54^ China Prospective cohort study | Community-dwelling hypertensive participants ≥ 80 years old; no standard treatment protocol | 294 | 84.4 | 85% with complete 4-year follow-up | MMSE: 26 | Baseline: SBP: 176 DBP: 78 4-year mean: SBP: 153 DBP: 75 | % change in MMSE: SBP < 140 mm Hg: -7.78 (SD 8.1) SBP 140-160 mm Hg: -3.51 (SD 7.75) SBP >160 mm Hg: -8.8 (SD 9.27) P-value for differences between groups < .001 % change in MMSE by SBP decline: < 15 mm Hg: -8.94 (SD 9.1) 15-35 mm Hg: -3.77 (SD 7.33); ➢ 35 mm Hg: -7.03 (SD 8.75); P-value for differences between groups < .001 | 44 participants excluded from final analysis due to death/stroke/withdrawal. 250/294 (85%) included in analysis.
Sacktor, 1999^53^ Baltimore Longitudinal Study of Aging Prospective cohort study | Patients ≥ 60 treated for hypertension with serial BP measures and neuropsychologic testing; tested association between maintenance of low (SBP < 135), intermediate (SBP 135-150), and high (SBP > 150) BP and cognitive outcomes | 158 | 74.5 | 5.1 | MMSE: 28.4 | % with Low: 18 Intermediate: 30 High: 51 | Change in Low vs Intermediate vs High BP groups: MMSE: 0.2 vs 0.3 vs 0.2 (P = .77) Trail making test part B: -0.1 vs 5.4 vs 5.2 (P = .19) Total free recall: -0.3 vs 0.0 vs 0.6 (P = .02) Delayed recall: 0.4 vs 0.0 vs 0.1 (P = .04) | 132 (37%) of the original cohort of 354 patients did not receive longitudinal neuropsychologic testing; these excluded patients were younger and less educated.

Abbreviations: ACCORD = Action to Control Cardiovascular Risk in Diabetes; ACCORD-MIND = Action to Control Cardiovascular Risk in Diabetes - Memory in Diabetes; BP = blood pressure; C = comparator/control; CI = confidence interval; DBP = Diastolic blood pressure; DSST = Digit Symbol Substitution Test; HR = hazard ratio; HYVET = Hypertension in the Very Elderly Trial; HYVET-COG = Hypertension in the Very Elderly Trial - Cognitive Function Assessment; MMSE = mini-mental state examination; NR = not reported; ns = not statistically significant; PALT = Paired Associate Learning Test; PROGRESS = Perindopril Protection Against Recurrent Stroke Study; RCT = randomized controlled trial; RR = relative risk; SBP = systolic blood pressure; SCOPE = Study on Cognition and Prognosis in the Elderly; SD = standard deviation; SHEP = Systolic Hypertension in the Elderly Program; Syst-Eur = Systolic Hypertension in Europe; T = treatment.

Six of the trials had low risk of bias, while an older trial had an unclear risk of bias because of poor methods reporting.^51^ The 4 trials reporting incident dementia used robust diagnostic criteria centrally adjudicated by blinded outcomes assessors. Rates of missing data or loss to follow-up ranged from 0.5 to 13.8%, but results were consistent across all studies.

We found 2 observational studies that suggested an SBP range of approximately 135 to 150 mm Hg was associated with the lowest risk of cognitive decline.^52,53^ However, in both studies there were missing data from a large proportion of patients (13.5 to 37%) who were generally less well-educated than those with full data available. A third observational study in patients ≥ 80 years of age similarly found the lowest rate of cognitive decline among those whose 4 year mean SBP was between 140 to 160 mm Hg, while those with lower or higher blood pressures experienced steeper rates of cognitive decline.^54^

### Quality of Life and Functional Status

Overall, we found moderate-strength evidence from prospective substudies of 4 large low risk of bias trials that use of antihypertensive therapy to achieve moderate blood pressure control (SBP 140 to 150 mm Hg) was not associated with a deterioration in quality of life compared to less intensive blood pressure control. We found low-strength evidence from one large low risk of bias trial that moderate blood pressure control was not associated with deterioration in functional status compared to less intensive control.

In the SHEP trial, all participants were included in a longitudinal assessment of functional status.^56^ Most participants (intervention group 95.6%, control group 92.8%) completed baseline and follow-up questionnaires about deterioration in Activities of Daily Living (ADLs). At a mean of 5 years of follow-up, a similar proportion of intervention and control group participants reported a deterioration in basic ADLs (18.6 vs 20.1%, P = .20), moderate ADLs (22.1 vs 23.4, P = .30), and advanced ADLs (46.6 vs 49.1, P = .72).

A smaller pre-specified subpopulation (N = 2,034) of SHEP trial participants was included in a longitudinal behavioral assessment that included 3 questions globally assessing quality of life.56 Baseline and follow-up questionnaires were completed by 1758/2034 (86.4%) of participants. On all 3 measures, quality of life was similar in intervention and control groups at last follow-up. For example, a similar proportion rated their health as good or excellent at follow-up (T vs C, 78.0 vs 76.4%, P = .70).

A subpopulation of 1,348 of the 4,695 patients in the Syst-Eur trial was recruited for a quality of life assessment.^57^ Six hundred and ten of these patients completed a baseline and at least one follow-up questionnaire which included the Sickness Impact Profile (SIP), a quality of life measure examining the effects of poor health on ambulation, social interaction, home work, and sleep and rest. There were no differences in SIP score changes over time between intervention and control groups, although an age-adjusted model showed slightly more intervention patients reported difficulty on the social interaction scale (OR 1.32, 95% CI 1.02 to 1.69).

In the HOT trial (total N = 19,193), of 922 patients recruited into a quality of life substudy, 610 (66%) completed questionnaires consisting of the Psychological General Well-Being index (PGWB) and the Subjective Symptoms Assessment Profile (SSA-P) at baseline and at the 6 month follow-up visit.^58^ There was slightly more improvement in global PGWB scores (potential range 22 to 132) in the group randomized to target DBP of ≤ 80 mm Hg than the 2 less intensive blood pressure target groups (mean change in scores 2.8 vs 0.6 vs 1.3, P < .001). These small improvements are of uncertain clinical significance and were driven by very small changes in the anxiety, general well-being, and vitality subscales.

The SSA-P used 7-point Likert-scale questions to assess various subjective symptoms potentially associated with antihypertensive therapy. Headache, dizziness, and cardiac symptoms such as palpitations improved slightly in all groups (approximately -0.5, -0.2, and -0.2, respectively, P < .01), while sex-life scores deteriorated slightly in males assigned to the 2 more intensive treatment groups (0.2 vs 0.0, P < .01).

The SCOPE trial enrolled 2,850 of its 4,937 in a quality of life substudy.^59^ The PGWB, SSA-P, and European Quality of Life scale (EuroQOL, a 100-point visual analog scale assessing self-rated current health) were completed at baseline and last follow-up by 92.9 and 93.7% of the intervention and control groups, respectively. Quality of life deteriorated slightly less in the intervention than in the control group, though this difference is likely of little clinical significance (-3.1 vs -5.3, mean difference in change -2.19, 95% CI -3.8 vs -0.56). Changes in PGWB and SSA-P scores were similar in the 2 groups.

### Falls and Fractures

We found moderate-strength evidence from 3 large low risk of bias trials that more intensive blood pressure treatment (SBP targets < 120 mm Hg and < 150 mm Hg, and achieved SBP < 150 mm Hg in the third trial) did not increase risk of fracture.^60,61^ We found low-strength evidence that more aggressive blood pressure control did not consistently increase the risk of falls. Two of the trials found that very aggressive blood pressure lowering (SBP < 120 mm Hg) did not increase the risk of falls,^11,60^ while a third trial found that moderate blood pressure control (SBP < 150 mm Hg) was associated with a small increase in the risk of falls.^8^

In meta-analyses of these studies statistical heterogeneity was too high to permit meaningful summary estimates of treatment effects.

In the ACCORD study, 3,099 of the 4,733 participants were enrolled in the ACCORD-BONE substudy.^60^ Participants (mean age 62 years), were asked annually to report falls or non-spine fractures over the prior 12 months. Fracture events were centrally adjudicated using radiology reports by blinded outcome assessors. Over a mean of 3.5 years of follow-up, the rate of falls was similar in the intervention and control groups (62.2/100 person-years vs 74.1/100 person-years, RR 0.84, 95% CI 0.54 to 1.29). A similar proportion of participants in each group had one or more falls (20 vs 21%, OR 0.94, 95% CI 0.84 to 1.05). The risk of non-spine fractures was non-significantly lower in the intervention group (hazard ratio [HR] 0.79, 95% CI 0.62 to 1.01). Interaction terms including age and comorbidities were all P > .05.

In the SHEP study (N = 4,736) more patients in the intervention group reported one or more falls over the 4.5 year follow-up (12.8 vs 10.4%, P < .05), though a similar number in both groups experienced a fracture (2.4 vs 2.0%, P > .05).^8^

All participants (N = 3,845, mean age 83.5) in the HYVET study were included in an analysis of hypertension treatment (with a thiazide diuretic ± ACE inhibitor) on risk of fracture.^61^ Fractures were identified if included in routine serious adverse event reporting. Additionally, at each trial follow-up investigators were asked to report whether participants had experienced an interim fracture. Fracture events were centrally adjudicated by blinded outcome assessors who examined relevant radiological and medical reports. Over a mean of 2.1 years of follow-up, one or more definite or probable fractures occurred in 38/1933 (2.0%) intervention participants compared to 52/1912 (2.7%) control participants (HR 0.69, 95% CI 0.46 to 1.05).

In the SPRINT trial (N = 9,361, mean age 67.9) a similar proportion of participants in the intervention and control groups had a fall leading to an emergency room visit or hospitalization (2.2 vs 2.3%, HR 0.95, P = .71). However, there was a higher risk of syncope among intervention participants (2.3 vs 1.7%; HR 1.33, P = .05).

### Effects of Age

Three studies reported harms associated with more versus less intensive blood pressure treatment according to age. The SPS3 trial compared results in participants ≥ 75 years (N = 494) and < 75 years (N = 2,526).^39^ The rates of adverse events related to blood pressure lowering such as unsteadiness, dizziness, and orthostatic syncope were similar among patients assigned to a lower treatment target (achieved SBP 125 mm Hg) and higher treatment target (achieved SBP 137 mm Hg) in both age groups. Fewer participants assigned to the lower treatment target experienced one or more episodes of postural hypotension (53 vs 65% and 57 vs 62% in the older and younger age groups, respectively; P < .01 in both groups).

In the JATOS study, rates of renal failure were similar in lower and higher treatment target groups in older (≥ 75 years) and younger (< 75 years) participants, though event rates were low.^24^

The SPRINT trial did not directly compare harms in different age groups, but found that the pattern of harms in the subgroup of patients over age 75 was similar to overall study findings. For example, a similar proportion of older patients in the intervention and control groups experienced a fall resulting in an emergency room visit or hospitalization (5.3 vs 6.0%; HR 0.88, P = .42).^11^

Overall, there were very few participants ≥ 80 years included in most of the trials. The major exception was the HYVET trial which only included patients over age 80 and found that use of medication to achieve moderate blood pressure control (150/80 mm Hg) was not associated with an increased risk of adverse events.^6^

### Harms according to DBP

Theoretically, low DBP could also contribute to harms. We found very little data to assess the contribution of low DBP to the harms described above. The only 2 studies in which the achieved DBP was < 70 mm Hg were ACCORD and SPRINT (mean achieved DBP 64.4 and 66 mm Hg), which also examined the effects of aggressive SBP targets of < 120 mm Hg. As described above, these studies found that achieved DBP < 70 mm Hg was not associated with an increased risk of falls, fractures, or cognitive impairment. However, there was an increased risk of symptomatic hypotension in both trials,^11,22^ and an increased risk of syncope in one trial.^11^ Whether these effects were seen primarily in patients with very low DBP, SBP, or both is unclear.

## KEY QUESTION 5 Do the harms of targeting lower blood pressure vary with patient burden of comorbidities?

We found no trials which examined the impact of participants' burden of comorbidities on risk of adverse events. As noted in Key Question 3, patients with severe comorbidities or high comorbidity burden were not well-represented among these studies (Table 5). There is an insufficient body of evidence examining the safety of intensive blood pressure treatment in adults with dementia or other serious illness since these patients were excluded from most trials.