# REFERENCES

1 Nwankwo T, Yoon SS, Burt V, Gu Q. (2013). Hypertension among adults in the United States: National Health and Nutrition Examination Survey, 2011-2012. NCHS data brief.
2 (1967). Effects of treatment on morbidity in hypertension. Results in patients with diastolic blood pressures averaging 115 through 129 mm Hg. Jama.
3 (1992). Medical Research Council trial of treatment of hypertension in older adults: principal results. MRC Working Party. Bmj.
4 (1970). Effects of treatment on morbidity in hypertension. II. Results in patients with diastolic blood pressure averaging 90 through 114 mm Hg. Jama.
5 (1980). The Australian therapeutic trial in mild hypertension. Report by the Management Committee. Lancet.
6 Beckett NS, Peters R, Fletcher AE, et al. (2008). Treatment of hypertension in patients 80 years of age or older. N Engl J Med.
7 Staessen JA, Fagard R, Thijs L, et al. (1997). Randomised double-blind comparison of placebo and active treatment for older patients with isolated systolic hypertension. The Systolic Hypertension in Europe (Syst-Eur) Trial Investigators. Lancet.
8 SHEP Cooperative Research Group. (1991). Prevention of stroke by antihypertensive drug treatment in older persons with isolated systolic hypertension. Final results of the Systolic Hypertension in the Elderly Program (SHEP). Jama.
9 Steinman MA, Lee SJ, John Boscardin W, et al. (2012). Patterns of multimorbidity in elderly veterans. J Am Geriatr Soc.
10 James PA, Oparil S, Carter BL, et al. (2014). 2014 evidence-based guideline for the management of high blood pressure in adults: report from the panel members appointed to the Eighth Joint National Committee (JNC 8). Jama.
11 Wright JT, Williamson JD, Whelton PK, et al. (2015). A Randomized Trial of Intensive versus Standard Blood-Pressure Control. N Engl J Med.
12 Weiss J, Kerfoot A, Freeman M, et al. Benefits and harms of treating blood pressure in older adults.
13 Sundstrom J, Arima H, Woodward M, et al. (2014). Blood pressure-lowering treatment based on cardiovascular risk: a meta-analysis of individual patient data. Lancet.
14 (2008). Chapter 8: Assessing risk of bias in included studies. Higgins JPT, Altman DG, editors. Cochrane Handbook for Systematic Reviews of Interventions. 2008;Version 5.0.1.
15 Hardy RJ, Thompson SG. (1996). A likelihood approach to meta-analysis with random effects. Stat Med.
16 Higgins JP, Thompson SG, Deeks JJ, Altman DG. (2003). Measuring inconsistency in meta-analyses. Bmj.
17 Hansson L, Zanchetti A, Carruthers SG, et al. (1998). Effects of intensive blood-pressure lowering and low-dose aspirin in patients with hypertension: principal results of the Hypertension Optimal Treatment (HOT) randomised trial. The Lancet.
18 Berkman ND, Lohr KN, Ansari M, et al. (2013). Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Comparative Effectiveness Reviews.
19 Gong L, Zhang W, Zhu Y, et al. (1996). Shanghai trial of nifedipine in the elderly (STONE). J Hypertens.
20 Wang JG, Staessen JA, Gong L, Liu L. (2000). Chinese trial on isolated systolic hypertension in the elderly. Systolic Hypertension in China (Syst-China) Collaborative Group. Arch Intern Med.
21 Wei Y, Jin Z, Shen G, et al. (2013). Effects of intensive antihypertensive treatment on Chinese hypertensive patients older than 70 years. J Clin Hypertens (Greenwich).
22 ACCORD Study Group. (2010). Effects of Intensive Blood-Pressure Control in Type 2 Diabetes Mellitus. N Engl J Med.
23 Verdecchia P, Staessen JA, Angeli F, et al. (2009). Usual versus tight control of systolic blood pressure in non-diabetic patients with hypertension (Cardio-Sis): an open-label randomised trial. Lancet.
24 Goto Y, Ishii M, Saruta T, et al. (2008). Principal results of the Japanese trial to assess optimal systolic blood pressure in elderly hypertensive patients (JATOS). Hypertension research: official journal of the Japanese Society of Hypertension.
25 SPS3 Study Group, Benavente OR, Coffey CS, et al. (2013). Blood-pressure targets in patients with recent lacunar stroke: the SPS3 randomised trial. Lancet.
26 Ogihara T, Saruta T, Rakugi H, et al. (2010). Target blood pressure for treatment of isolated systolic hypertension in the elderly: valsartan in elderly isolated systolic hypertension study. Hypertension.
27 ADVANCE Collaborative Group. (2007). Effects of a fixed combination of perindopril and indapamide on macrovascular and microvascular outcomes in patients with type 2 diabetes mellitus (the ADVANCE trial): a randomised controlled trial. The Lancet.
28 Ruggenenti P, Fassi A, Ilieva A, et al. (2011). Effects of verapamil added-on trandolapril therapy in hypertensive type 2 diabetes patients with microalbuminuria: the BENEDICT-B randomized trial. J Hypertens.
29 Amery A, Brixko P, Clement D, et al. (1985). Mortality and morbidity results from the European Working Party on High Blood Pressure in the Elderly trial. The Lancet.
30 Liu L, Zhang Y, Liu G, et al. (2005). The Felodipine Event Reduction (FEVER) Study: a randomized long-term placebo-controlled trial in Chinese hypertensive patients. J Hypertens.
31 Progress Collaborative Group. (2001). Randomised trial of a perindopril-based blood-pressure-lowering regimen among 6,105 individuals with previous stroke or transient ischaemic attack. Lancet.
32 Brenner BM, Cooper ME, de Zeeuw D, et al. (2001). Effects of losartan on renal and cardiovascular outcomes in patients with type 2 diabetes and nephropathy. N Engl J Med.
33 Lithell H, Hansson L, Skoog I, et al. (2003). The Study on Cognition and Prognosis in the Elderly (SCOPE): principal results of a randomized double-blind intervention trial. J Hypertens.
34 Hara A, Thijs L, Asayama K, Jacobs L, Wang JG, Staessen JA. (2014). Randomised double-blind comparison of placebo and active drugs for effects on risks associated with blood pressure variability in the systolic hypertension in europe trial. PLoS ONE.
35 TRANSCEND Investigators, Yusuf S, Teo K, et al. (2008). Effects of the angiotensin-receptor blocker telmisartan on cardiovascular events in high-risk patients intolerant to angiotensin-converting enzyme inhibitors: a randomised controlled trial. Lancet.
36 Beckett N, Peters R, Leonetti G, et al. (2014). Subgroup and per-protocol analyses fromthe hypertension in the very elderly trial. J Hypertens.
37 ACCORD Study Group. (2010). Supplement to: The ACCORD Study Group. Effects of intensive blood-pressure control in type 2 diabetes mellitus. N Engl J Med.
38 Kjeldsen SE, Kolloch RE, Leonetti G, et al. (2000). Influence of gender and age on preventing cardiovascular disease by antihypertensive treatment and acetylsalicylic acid. The HOT study. J Hypertens.
39 White CL, Szychowski JM, Pergola PE, et al. (2015). Can blood pressure be lowered safely in older adults with lacunar stroke? The Secondary Prevention of Small Subcortical Strokes study experience. J Am Geriatr Soc.
40 Staessen JA, Thijs L, Gasowski J, Cells H, Fagard RH. (1998). Treatment of isolated systolic hypertension in the elderly: further evidence from the systolic hypertension in Europe (Syst-Eur) trial. Am J Cardiol.
41 van Dieren S, Kengne AP, Chalmers J, et al. (2012). Effects of blood pressure lowering on cardiovascular outcomes in different cardiovascular risk groups among participants with type 2 diabetes. Diabetes Res Clin Pract.
42 Zanchetti A, Hansson L, Clement D, on behalf of the HOTSG, et al. (2003). Benefits and risks of more intensive blood pressure lowering in hypertensive patients of the HOT study with different risk profiles: does a J-shaped curve exist in smokers?. J Hypertens.
43 Ferrucci L, Furberg CD, Penninx BW, et al. (2001). Treatment of isolated systolic hypertension is most effective in older patients with high-risk profile. Circulation.
44 Voyaki SM, Staessen JA, Thijs L, et al. (2001). Follow-up of renal function in treated and untreated older patients with isolated systolic hypertension. Systolic Hypertension in Europe (Syst-Eur) Trial Investigators. J Hypertens.
45 Beckett N, Forette F, Tuomilehto J, et al. (2008). Incident dementia and blood pressure lowering in the Hypertension in the Very Elderly Trial cognitive function assessment (HYVET-COG): a double-blind, placebo controlled trial. The Lancet.Neurology.
46 Forette F, Seux ML, Staessen JA, et al. (2002). The prevention of dementia with antihypertensive treatment: new evidence from the Systolic Hypertension in Europe (Syst-Eur) study. Arch Intern Med.
47 Williamson JD, Launer LJ, Bryan RN, et al. (2014). Cognitive function and brain structure in persons with type 2 diabetes mellitus after intensive lowering of blood pressure and lipid levels: a randomized clinical trial. JAMA Intern Med.
48 Tzourio C, Anderson C, Chapman N, et al. (2003). Effects of blood pressure lowering with perindopril and indapamide therapy on dementia and cognitive decline in patients with cerebrovascular disease. Arch Intern Med.
49 Skoog I, Lithell H, Hansson L, et al. (2005). Effect of baseline cognitive function and antihypertensive treatment on cognitive and cardiovascular outcomes: Study on COgnition and Prognosis in the Elderly (SCOPE). Am J Hypertens.
50 McGuinness B, Todd S, Passmore P, Bullock R. (2009). Blood pressure lowering in patients without prior cerebrovascular disease for prevention of cognitive impairment and dementia. Cochrane Database Syst Rev.
51 Bird AS, Blizard RA, Mann AH. (1990). Treating hypertension in the older person: an evaluation of the association of blood pressure level and its reduction with cognitive performance. J Hypertens.
52 Liu H, Gao S, Hall KS, et al. (2013). Optimal blood pressure for cognitive function: findings from an elderly African-American cohort study. J Am Geriatr Soc.
53 Sacktor N, Gray S, Kawas C, Herbst J, Costa P, Fleg J. (1999). Systolic blood pressure within an intermediate range may reduce memory loss in an elderly hypertensive cohort. J Geriatr Psychiatry Neurol.
54 Peng J, Lu F, Wang Z, et al. (2014). Excessive Lowering of Blood Pressure Is Not Beneficial for Progression of Brain White Matter Hyperintensive and Cognitive Impairment in Elderly Hypertensive Patients: 4-Year Follow-Up Study. J Am Med Dir Assoc.
55 (1991). Systolic Hypertension in the Elderly Program (SHEP): baseline characteristics of the randomized sample. Black HR, Curb JD, Pressel S, Probstfield JL, Stamler J, editors. Hypertens.
56 Applegate WB, Pressel S, Wittes J, et al. (1994). Impact of the treatment of isolated systolic hypertension on behavioral variables. Results from the systolic hypertension in the elderly program. Arch Intern Med.
57 Fletcher AE, Bulpitt CJ, Thijs L, et al. (2002). Quality of life on randomized treatment for isolated systolic hypertension: results from the Syst-Eur Trial. J Hypertens.
58 Wiklund I, Halling K, Ryden-Bergsten T, Fletcher A. (1997). Does lowering the blood pressure improve the mood? Quality-of-life results from the Hypertension Optimal Treatment (HOT) study. Blood Press.
59 Degl'Innocenti A, Elmfeldt D, Hofman A, et al. (2004). Health-related quality of life during treatment of elderly patients with hypertension: results from the Study on COgnition and Prognosis in the Elderly (SCOPE). J Hum Hypertens.
60 Margolis KL, Palermo L, Vittinghoff E, et al. (2014). Intensive blood pressure control, falls, and fractures in patients with type 2 diabetes: the ACCORD trial. J Gen Intern Med.
61 Peters R, Beckett N, Burch L, et al. (2010). The effect of treatment based on a diuretic (indapamide) +/- ACE inhibitor (perindopril) on fractures in the Hypertension in the Very Elderly Trial (HYVET). Age Ageing.
62 Fried TR, Tinetti ME, Iannone L, O'Leary JR, Towle V, Van Ness PH. (2011). Health outcome prioritization as a tool for decision making among older persons with multiple chronic conditions. Arch Intern Med.
63 Fried TR, McGraw S, Agostini JV, Tinetti ME. (2008). Views of older persons with multiple morbidities on competing outcomes and clinical decision-making. J Am Geriatr Soc.
64 Boyd CM, Darer J, Boult C, Fried LP, Boult L, Wu AW. (2005). Clinical practice guidelines and quality of care for older patients with multiple comorbid diseases: implications for pay for performance. Jama.
65 Boyd CM, Ritchie CS, Tipton EF, Studenski SA, Wieland D. (2008). From Bedside to Bench: summary from the American Geriatrics Society/National Institute on Aging Research Conference on Comorbidity and Multiple Morbidity in Older Adults. Aging Clin Exp Res.
66 Sundstrom J, Arima H, Jackson R, et al. (2015). Effects of blood pressure reduction in mild hypertension: a systematic review and meta-analysis. Ann Intern Med.
67 Emdin CA, Rahimi K, Neal B, Callender T, Perkovic V, Patel A. (2015). Blood pressure lowering in type 2 diabetes: a systematic review and meta-analysis. Jama.
68 Xie X, Atkins E, Lv J, et al. (2016). Effects of intensive blood pressure lowering on cardiovascular and renal outcomes: updated systematic review and meta-analysis. Lancet.
69 Staessen JA, Fagard R, Thijs L, et al. (1998). Subgroup and per-protocol analysis of the randomized European Trial on Isolated Systolic Hypertension in the Elderly. Arch Intern Med.