# METHODS

## TOPIC DEVELOPMENT

This topic was nominated by Dr. Dawn Bravata with the Stroke Quality Enhancement Research Initiative. Additional key stakeholders for this project include the directors for the offices of Neurology, Clinical Analytics and Reporting, the Evidence-based Practice Program, and Preventive Medicine. The research questions for this systematic review were developed after a topic refinement process that included a preliminary review of published peer-reviewed literature, discussion with internal partners and investigators, and consultation with content experts and key stakeholders. A protocol describing the review plan was posted to a publicly accessible website before the study was initiated.^12^

In this report we address the following Key Questions which all apply to adults over age 60:

Key Question 1. What are the health outcome effects of differing blood pressure targets? b) What are the health outcome effects of differing blood pressure targets in patients who have suffered a transient ischemic attack (TIA) or stroke?

Key Question 2. How does age modify the benefits of differing blood pressure targets?

Key Question 3. How does the patient burden of comorbidities modify the benefits of differing blood pressure targets?

Key Question 4. What are the harms of targeting lower blood pressure in older patients? Do the harms vary with age?

Key Question 5. Do the harms of targeting lower blood pressure vary with patient burden of comorbidities?

## SEARCH STRATEGY

We developed a literature search strategy in consultation with a research librarian (Appendix A). We searched MEDLINE^®^, Embase^®^, and Ovid EBM Reviews from database inception through January 2015, and updated the MEDLINE^®^ search in September 2016. We also examined all trials included in the recent JNC-BP review^10^ and the Blood Pressure Lowering Treatment Trialists Collaborative (BPLTTC)^13^ at the full-text level. We conducted an additional search from January 2012 through January 2015 focused specifically on blood pressure treatment trials (because all trials in JNC-BP and BPLTTC were published before 2012). We further evaluated the bibliographies of included primary studies and recent systematic reviews. We also searched ClinicalTrials.gov to identify in-progress or unpublished studies, and identified related publications if in-progress trials were completed through December 2015.

## STUDY SELECTION

The criteria for patient population, intervention, comparator, outcome measures, timeframe for outcomes, and study design (PICOTS) vary by Key Question. Table 1 shows how each parameter in the PICOTS corresponds to the Key Questions. We applied specific inclusion/exclusion codes in screening the literature for relevant studies (Appendix B). We reviewed titles and abstracts and retrieved full-text articles with potential relevance to the Key Questions. Two independent reviewers reviewed the full-text articles to determine a final inclusion/exclusion decision.

Table 1 Key Questions, Inclusion Criteria, and Scope Parameters

Key Question (KQ) In adults over age 60 with hypertension: | KQ1. What are the health outcome effects of differing blood pressure targets? b) What are the health outcome effects of differing blood pressure targets in patients who have suffered a TIA or stroke? | KQ2. How does age modify the benefits of differing blood pressure targets? | KQ3. How does the patient burden of comorbidities modify the benefits of differing blood pressure targets? | KQ4. What are the harms of targeting lower blood pressure in older patients? Do these harms vary with age? | KQ5. Do the harms of targeting lower blood pressure vary with patient burden of comorbidities?
Population | Adults aged ≥ 60 years with hypertension | | Adults aged ≥ 60 years with hypertension and CVA or other existing comorbidity | Adults aged ≥ 60 years with hypertension | Adults aged ≥ 60 years with hypertension and at least one comorbidity
Intervention | Include: Pharmacologic treatment of hypertension to specified targets; or more versus less intensive treatment of hypertension Exclude:; - Interventions for which hypertension management was not the primary objective (Example: studies conducted in patients with heart failure for which vasoactive medications are being used for cardiac remodeling effects.); - Non-pharmacologic interventions for blood pressure control | | | Include: Pharmacologic treatment of hypertension, not necessarily to specified targets Exclude: Management of hypertension in patients with acute stroke; non-pharmacologic interventions for blood pressure control
Comparators | Placebo or a higher blood pressure target
Outcomes | - All-cause mortality; - Mortality related to stroke, coronary heart disease, congestive heart failure, and renal disease; - Morbidity including stroke, coronary heart disease, congestive heart failure, and renal disease | | | - Changes in cognition; - Falls; - Changes to quality of life; - Polypharmacy/medication burden; - Hypotension; - Acute kidney injury (defined as doubling of serum creatinine or requiring renal replacement therapy)
Timing | Long term (> 6 months) outcomes | | | Any
Study design | Include: Controlled study designs (RCT and non-randomized controlled clinical trials) | | | Include:; - Controlled study designs (RCT and non-randomized controlled clinical trials used for KQs 1-3); - Cohort extensions of trials that examined specific blood pressure targets; - Cohort studies that examined the effects of lower blood pressure in the context of antihypertensive medication; - Cohort studies that reported the effects of lower blood pressure despite that hypertension management was not the primary objective of the intervention studied.
Study design | Exclude: Case reports; case series; controlled before/after studies, RCTs with less than 6 month follow-up.

Abbreviations: CVA = cerebrovascular accident; KQ = Key Question; RCT = randomized controlled trials; TIA = transient ischemic attack

Studies were considered for inclusion if the study population had mean age of ≥ 60 years, all participants carried a diagnosis of hypertension at the time of enrollment, and the study design either compared higher versus lower blood pressure targets or more versus less intensive antihypertensive therapy (ie, compared the addition of an antihypertensive medication to placebo). We excluded studies in populations with specific diagnoses in which medications were used primarily for effects other than blood pressure lowering (eg, studies of beta-blockade in patients with systolic heart failure, or studies of acute myocardial infarction). We also excluded studies focused on the management of acute stroke.

We excluded comparative effectiveness trials which directly compared the effects of different antihypertensive drugs to one another. We excluded observational studies in considering our primary health outcomes (mortality, stroke, cardiac events) given the risk of confounding and the existence of many controlled trials. We included observational studies to assess potential harms of antihypertensive therapy. Because harms may be relatively infrequent and are not always immediate, we surmised the larger patient numbers and longer follow-up of cohort studies may be more likely to identify important harms/adverse events of blood pressure management. We only included observational studies in which there was some assessment of blood pressure change over time and in which patients were receiving antihypertensive therapy. We did not include studies examining the relationship between a baseline blood pressure and subsequent outcomes. We included trial extension studies and companion studies which reported subgroup analyses of interest such as treatment effect modifications based on age.

## DATA ABSTRACTION

Data from published reports were abstracted into a customized database by one reviewer and reviewed for accuracy and completeness by a second reviewer. From each study, we abstracted the following characteristics:

- study design
- objectives
- setting
- demographic variables (including sex and age)
- comorbidities (burden of comorbidity, number of medications/burden at baseline, baseline cognitive function)
- subject eligibility and exclusion criteria
- number of subjects
- years of enrollment
- duration of follow-up
- the study and comparator interventions (including screening intervals, antihypertensive agents used, blood pressure targets)
- important co-interventions
- health outcomes (all-cause mortality, mortality/morbidity related to cerebrovascular accident, coronary heart disease, congestive heart failure, renal disease)
- adverse events (including changes in cognitive status, falls, changes in quality of life, polypharmacy, and acute kidney injury)

Additional study result characteristics of interest included achieved blood pressures (systolic and diastolic), documented cognitive changes, and number of antihypertensive medications required.

## QUALITY ASSESSMENT

Two reviewers independently assessed the quality of each trial using a tool developed by the Cochrane Collaboration.^14^ Disagreements were resolved through discussion. Each trial was given an overall summary assessment of low, high, or unclear risk of bias (Appendix C).

## DATA SYNTHESIS

Outcomes of interest for Key Questions 1 to 3 of this review included potential benefits of lower versus higher blood pressure targets: all-cause mortality, cardiovascular mortality, stroke (fatal or non-fatal), and cardiovascular morbidity (myocardial infarction and sudden cardiac death). We do not present cardiovascular mortality data in this report because these data were very similar to the all-cause mortality and cardiac events data. Because hypertension therapy is long-term in both nature and benefit, we were interested only in these outcomes when they occurred at ≥ 6 months of treatment. For each outcome, we abstracted the number of events and total participants from each treatment group to obtain a pooled estimate of relative risk (RR).

Outcomes of interest related to Key Questions 4 and 5 (potential harms of lower versus higher blood pressure targets) included changes in cognition and changes in quality of life, falls and fractures, hypotension, and acute kidney injury (defined as doubling of serum creatinine or requiring renal-replacement therapy). From the included trials, we also reported medication burden (number of antihypertensive medications required in each group), and withdrawals due to adverse events. We did not specifically search for studies reporting well-known drug-specific adverse effects such as angiotensin converting enzyme (ACE) inhibitor-induced cough or thiazide diuretic-induced hypokalemia, but we described the common adverse events leading to withdrawal among the trials.

### Study-level Meta-analysis

We conducted meta-analyses using study-level data to get more precise estimates for several outcomes including death from all causes, cardiovascular death, fatal and nonfatal stroke, major cardiac events and withdrawal due to adverse events. To determine the appropriateness of meta-analysis, we considered clinical and methodological diversity and assessed statistical heterogeneity. For each outcome, we abstracted the number of events and total participants from each treatment group. We used the profile-likelihood random-effects model^15^ to combine risk ratios, while incorporating variation among studies. We assessed the presence of statistical heterogeneity among the studies using the standard Cochran's chi-square test, and the magnitude of heterogeneity using the I^2^ statistic.^16^

We performed a number of sensitivity analyses to help address the heterogeneity of study design and patient populations. We stratified analyses by baseline study characteristics (mean age, enrollment age, SBP) and achieved SBP level. We conducted analyses of studies whose mean population age was ≥ 70 and studies whose inclusion criteria stipulated entry age of ≥ 60 to ensure results were consistent among study populations which most definitively met the age criteria of interest. We conducted analyses grouping studies in which the intervention group did and did not achieve mean SBP < 140 mm Hg to better examine outcomes among patient populations whose achieved blood pressure was genuinely lower than that suggested by current guidelines (SBP < 150 mm Hg). To examine whether blood pressure treatment affected populations with mild to moderate versus more severe hypertension differently, we also conducted analyses of studies with mean baseline SBP > 160 mm Hg and ≤ 160 mm Hg.

We conducted subgroup analyses of trials specifically examining blood pressure targets since these trials are most directly applicable to the clinical questions of interest guiding this report. Analyses included evaluation of those studies which stipulated target SBP ≤ 140 mm Hg or lower for the more intensive treatment arm. We also included one study which compared 3 diastolic blood pressure (DBP) targets.^17^ In order to most directly address current guidelines, we dichotomized data from this study to DBP ≤ 90 mm Hg versus a combination of the 2 lower targets (≤ 85 plus ≤ 80 mm Hg). In an additional sensitivity analysis we incorporated only the 2 more disparate DBP groups from this trial (≤ 80 vs ≤ 90 mm Hg) as this provided the optimal difference between achieved SBP and DBP between groups (Appendix D).

Finally, we conducted analyses excluding trials which achieved negligible differences in SBP (≤ 3 mm Hg) between study arms. We also conducted analyses excluding methodologically flawed studies with a high risk of bias.

All analyses were performed using Stata/IC 13.1 (StataCorp, College Station, TX).

### Individual Patient Data Meta-analysis

In an effort to better understand treatment effects among different age subgroups, we explored the possibility of gathering data to conduct analysis based on individual patient data from blood pressure treatment trials. We contacted authors from all included RCTs. We received responses from 13, and we ultimately received either individual patient data or analyses of outcomes according to age subgroups from 4 trials (Valsartan in Elderly Isolated Systolic Hypertension [VALISH], Systolic Hypertension in Europe [Syst-Eur], European Working Party on High Blood Pressure in the Elderly [EWPHE], Action in Diabetes and Vascular Disease [ADVANCE]). We were also able to obtain study data from the Biologic Specimen and Data Repository Information Coordinating Center (BioLINCC) of the National Heart, Lung, and Blood Institute on 2 studies: the Action to Control Cardiovascular Risk in Diabetes study (ACCORD) and the Systolic Hypertension in the Elderly Program (SHEP) trial. We anticipate using data from these 6 trials to conduct meta-analyses examining blood pressure treatment benefits and harms in those aged 60 to 69 years, 70 to 79 years, over age 80 years. We will also conduct analyses examining the impact of comorbidity burden on outcomes if this data is available. We anticipate these analyses will be completed and published at a later date.

## RATING THE BODY OF EVIDENCE

We assessed the overall quality of evidence for each outcome using a method developed by the Agency for Healthcare Research and Quality (AHRQ).^18^ We considered the consistency, coherence, and applicability of the body of evidence, as well as the internal validity of individual studies, to classify the strength of evidence for each outcome as follows:

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Insufficient = Any estimate of effect is very uncertain.

## PEER REVIEW

A draft version of this report was reviewed by 12 individuals with technical expertise and clinical leadership. Their comments and our responses are presented in Appendix E.