# INTRODUCTION

Hypertension is a very common chronic illness in the United States, with an estimated prevalence of 27% among adults over age 18 and as much as 67% in adults over age 60, and possibly a higher prevalence among Veterans.^1^ Hypertension management is known to modify the risk of cardiovascular disease, renal disease, cerebrovascular disease, and death. ^2-5^ The issue is of great relevance to Veterans Affairs (VA) given the very high prevalence of hypertension and other vascular risk factors such as diabetes and hyperlipidemia in Veterans generally and the aging Veteran population more specifically. The benefit of some versus no blood pressure control has been shown to be consistent for older adults (aged ≥ 60 years), even the very elderly (aged ≥ 80 years).^6-8^ The most beneficial blood pressure targets for patients of specific age groups, however, has been a topic of some debate and controversy, stemming from concerns that the ratio of benefit to harm of a given blood pressure level may vary with age. Further, the disease-disease and disease-treatment interactions which can occur when treating hypertension in older adults with multiple chronic comorbidities remain unclear. This holds particular relevance for Veterans over age 65, who experience an average of 5 comorbidities and for whom the most common comorbidity clusters in both men and women include hypertension.^9^

In 2014, the Joint National Committee on the Prevention, Detection, Evaluation, and Treatment of High Blood Pressure (previously JNC-FG8, referred to in this report as JNC-BP) published new guidelines for the treatment of hypertension as well as a new treatment goal for older individuals (age ≥ 60 years) for systolic blood pressure (SBP) of < 150 mm Hg rather than < 140 mm Hg.^10^ The new goal for those ages ≥ 60 years has been very controversial. The recent publication of a trial showing a benefit from aggressive blood pressure treatment in older individuals has further fueled debate about the safest and most beneficial blood pressure goal for older people.^11^ The objectives of this review are to examine the benefits and harms of differing blood pressure targets among older adults (aged ≥ 60 years).