# APPENDIX E PEER REVIEWER COMMENTS AND AUTHOR RESPONSES

Question Text | Reviewer Number | Comment | Response
Are the objectives, scope, and methods for this review clearly described? | 2-10, 12, 15, 16 | All responded: Yes
Is there any indication of bias in our synthesis of the evidence? | 2-10, 12, 15, 16 | All responded: No
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 2, 3, 5, 6, 9, 10, 12, 15, 16 | No
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 4 | Yes - I'm sure it wasn't overlooked, it just hasn't been published yet. SPRINT. NIH held press conference today. because it has not yet been published it cannot be included in the meta-analysis, but it could and probably should be mentioned in the narrative as being a study to consider when results are published. | SPRINT has been included
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 7 | Yes - The SHEP study did report a significant increase in falls in the intervention vs control group (which you note in your table but not the text). | We added this information in the text.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 7 | There is a very small observational study (JAMA Int Med, Mosello, 2015) finding that the combination of multiple blood pressure medications and lowest tertile of BP among patients with dementia was associated with greater loss of MMSE points. | This was published after our search. The results are in line with several other observational studies that fell within our search dates. All of the observational studies of cognition, including this one, have some issues with confounding. Given that there were 7 RCTs examining cognitive outcomes and that we've already included several obs studies with similar findings as this one, it is unlikely that the addition of the Mosello study would alter results.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 7 | There is a very recent trial of withdrawal of blood pressure medications in Leiden (the DANTE trial) Annals Internal Medicine 2015 (last week), by Noonen et al, that did not find short term improvements in cognition. | Interesting study – falls out of the scope of our key questions.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 8 | Yes - I would not say overlooked, but the SPRINT study is obviously going to be influential. | SPRINT has been included
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2 | See comments in the attached file.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2 | A matter not addressed in this review is the important but controversial issue of BP management in the subacute period after stroke. In general, there is fear that dropping BP in the first hours post-stroke (when collaterals may be perfusing at-risk brain) can extend damage in stroke and worsen outcomes, yet a few studies using ACE-I or ARB drugs begun within 24- to 48-hours of stroke decreased recurrence or mortality. I would urge caution in applying the results of long-term trials to the acute post-stroke period. | We have added some language to the methods and results to clarify that we did not examine management of acute stroke.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2 | While no suggestive signal was seen in this review, the issue remains as to whether some anti-hypertensive individual drugs or classes of drugs might have superior outcomes independent of BP targets or actual reduction in BP achieved. This has been suggested for ACE-Is and ARBs for the outcome of initial or recurrent stroke. | Noted. We were not able to identify a clear pattern, but one would really need to look at comparative effectiveness studies and individual level data to answer this question.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | P31 line 21: I would add that the SPS 3 trial showed a statistically significant reduction in intracerebral hemorrhage, a type of stroke with high mortality. | Noted. We've reported the outcome of all strokes. SPS3 reports 5 different stroke outcomes including a variety of hemorrhagic stroke outcomes. The intracerebral hemorrhage outcome was the only one with p < 0.05. Moreover, the rate of disabling or fatal strokes with similar in both groups. It would be misleading for us to report one secondary outcome and not all others.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | P 46, line 52: Discussion: Did any of the studies report sex differences in the benefits of BP lowering? | We did not systematically evaluate this question.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | P 46, line 47: Would add that even though the absolute benefit may be small, the population and health system benefits may be worthwhile | noted
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 6 | Table on page 5,line 11 comment on mortality says “more moderate targets (SBP<140mm Hg). Shouldn't it say (SBP>140)? Page 6: list of abbreviations under the table (line 33) does not include ROB nor is ROB listed in the abbreviations list on pages 8-9. Page 20, line 15 “monotherapy with benzene”--should that be benazepril instead of benzene? page 32, line 33,“described and increased risk” should be “described an increased risk” | Appreciated – all noted and corrected.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 8 | I am including these as attachments.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 9 | The report is well-written. | Thank you
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 9 | Page 2, line 39, did cough and hypotension vary with age? | There were no data on this.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 9 | Table 10 provides information about risk of bias, but little text is provided about how these assessments were made. | We followed standard methods for assessment (ref included). We revised table to include more detail, especially for areas in which we noted flaws.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 9 | Page 31, line 9, SPS3 had a “rigorous” definition of stroke as stated, but it was also restrictive to one type of ischemic stroke (namely only lacunar infarcts); therefore, results may not be generalizable to other stroke types (e.g., hemorrhagic stroke or large artery atherosclerotic ischemic stroke). How may the results be applicable to Veterans with a history of transient ischemic attack? | We've revised the language to be more clear about the inclusion criteria in both the SPS3 and PROGRESS trials. The progress trial did include a broader definition of stroke and TIA.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 9 | Page 45, line 18 (typographical error, errant 6). | noted
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 9 | General comment: consider hyphenating “treat-to-target” studies throughout (there are occasions without use of hyphens. | done
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 9 | Limitations Section: consider including a statement that the included trials used pharmacologic treatment of hypertension and therefore excluded trials that focused on non-pharmacologic approaches to hypertension management. | We have added this.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 9 | A statement about domains where additional research is needed would be of interest. | We have added a brief future research section.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 10 | Although a few studies are of questionable quality, they are adequately handled and don't bias the conclusions. Although this was written before SPRINT was announced, if not mentioned, you could add that it may address this question, or you could comment that it is unpublished at this time, but shows benefots for a population average age 68 years. | SPRINT has been included
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 15 | see attachment for comments
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 16 | A thorough review of evidence regarding intensity of treatment for hypertension that provides guidance but perhaps more notably identifies the need for additional investigation.; 1. Would encourage consistency in the use of abbreviations (i.e. once define use consistently thereafter - risk of bias/ROB).; 2. Would also recommend more consistent use of symbols (i.e. < & >) to define blood pressure targets rather than prose ((i.e. 140 mm HG or less).; 3. Forest plots are somewhat blurred and would benefit from sharpening.; 4. Please include justification for exclusion of comparative effectiveness studies. | Noted and revised accordingly

Additional comments – Reviewer #2 | Response
Page 3, Line 6: It would be useful to state whether the difference was significant or not, and by what p value, given the rather high NNTs. (also insert comma after NNT ##) | As above, all the #'s have changed. We present CI and NNT throughout
Page 11, Line 54: An interesting and controversial topic is whether some anti-hypertensive individual drugs or classes of drugs have superior outcomes independent of BP target or actual reduction in BP. This has been suggested for ACE-Is and ARBs for the outcome of initial or recurrent stroke. I understand this was outside the scope of your review, but did you find enough in the literature to suggest this as a future topic for exploration? | Agree an interesting topic, but outside scope – as we note in limitations partly this would be answered by comparative effectiveness studies which we did not include.
Page 11, Line 59: We surmised the (change “the” to “that”) | Noted
Page 15, Line 37: I gather from the below that no studies were excluded if they targeted DBP rather than SBP? | Correct, we have clarified inclusion/exclusion criteria
Page 15 Line 53: In an effort to better understand treatment effects among different age subgroups, we explored the possibility of gathering data to conduct analysis (change to analyses) based on individual patient data from blood pressure treatment trials. | Noted
Page 16, Line 6: “We anticipate using data from these six trials to conduct meta-analyses examining blood pressure treatment benefits and harms in those age 60-69, 70-79, 80-89, and over age 90.” Will the results be disseminated in a subsequent report? | We anticipate writing up a separate manuscript of these results.
Page 18, Line 11: “Overall, there was little to no consistent evidence of a clinically significant incremental benefit of treating blood pressures to levels substantially below current guideline recommend (change to recommended) levels of 150/90 in patients over age 60.” | Noted
Page 18, Line 41: “The remaining studies had primary outcomes related to renal disease or microalbuminuria27,31 or additional outcomes not specified (delete specified) of interest for this review (LVH regression).20” | Noted
Page 18, Line 43: Among trials which specified a particular medication as first-line therapy, seven used ace (ACE - term should be defined at first use) inhibitors or angiotensin-receptor blockers, 5 used calcium channel blockers, and six used diuretics (Tables 2 and 3). | Noted
Page 23, Line 25: You might want to comment on reduced significance (p value) with population subset. However, it's confusing that CI does not include 1 yet p > 0.05. Is this a mult. comparisons adjustment? | Again, all #'s have changed. We use CI preferentially throughout.
Just a note that all of the figures appear blurry (out of focus) in my copy. | Noted – we have tried to improve the appearance of the figures.
Page 51, Line 18: Another issue not addressed is the important but controversial issue of BP management in the subacute period after stroke. In general, there is fear that dropping BP in the first hours post-stroke (when collaterals may be perfusing at-risk brain) can extend damage in stroke and worsen outcomes, yet a few studies using ACE-I or ARB drugs begun within 24- to 48-hoours of stroke decreased recurrence or mortality. Perhaps a subject for a future ESP review? | Agree – interesting topic, but out of scope (and we added statement clarifying that we did not include acute stroke).

Additional comments – Reviewer #4 | Response
Overall, this is an excellent review of the evidence. These are comments that may help make the review more useful to clinicians:
- It is very helpful that the achieved BPs in the trials has been included.
- The lack of evidence about effect of comorbidity burden is striking and should be a call to clinical trialists to gather more information in that area. | We added this to future research section
- Possibly more could be done with the available information about ADE rates, for example, in one place there is mention that 4 of 10 trials found increased withdrawals due to ADEs in older individuals (particularly cough and hypotension, with hypotension being potentially serious). Page 7 could use more cautions re the ADE statements. | We have added a statement in discussion about potential seriousness of hypotension given the increased rate of syncope in 2 studies.
- There is mention that HYVET study excluded patients with dementia or nursing home; however, my recollection (should be checked with source data) is that the individuals in HYVET were quite healthy for age (not just “not frail” but healthier than average). Since this group is a major contributor to information about lack of impact on adverse events in those over 75, it is important to provide more detail about how health this group was. | We have created a new table focused on exclusion criteria of each trial to better examine this issues of applicability
- In general, I think it would be good to make more visible the issue of to whom the findings may be generalized. Clinicians are looking for guidance. It is important, for example, not to assume that because HYVET had certain findings that these findings would apply to all patients over age 80. | See above
○ It would be helpful to have information in the tables with more detailed descriptions of the study populations at baseline, to make it clearer what where the characteristics of the study populations, so that clinicians managing older Veterans and other older adults can more easily compare the patients in the studies to the patient about whom they are making clinical decisions, to understand how similar (or not) their patient may be to the patients in the clinical trials that form the evidence base. | See above
○ Further along those lines, it would be helpful to describe in the narrative some comparisons of the baseline characteristics and the events in the study groups with the typical prevalence among Veterans (who receive their care in VA) in comparable age groups. For example, there is mention of low stroke or other event rates, but the expected rates in the typical Veteran population are not shown so it is hard to make the comparison. | We have included more about study event rates. The rates in Veterans will vary markedly depending on their risk factor profile. We have added more discussion about risk factor profile and study inclusion in the treat to target trial section
○ Although there were no studies with evidence about the role of comorbidity, it would be helpful at least to describe to the extent the data are available in the study reports the baseline extent of comorbidity. | See above
○ Where ADEs are at low rates, comparison of the rates in general population , or ideally in VA patient population, over time would be helpful for comparison | We have noted comparison of ADEs within trials, but do not have data on these ADEs in general population
- A large study of BP targets is underway in the SPRINT trial. A press briefing by NIH today (9/11/2015) released results. The paper has not yet been peer-reviewed and published, so it cannot be included in the meta-analysis, but some mention of this study should be in this report. Some information from the trial that we would hope to see in the published report: | SPRINT has been included
○ subgroup analysis for the older patients (by decades within the older age groups), with outcomes, length of time in trial, achieved BPs, variability in SBPs, pulse pressures, etc, length of time in trial and at target BP and/or on final number of drugs (i.e., how much time for ADEs to become apparent), quality of life reports, intolerance rates for drugs | These analyses would require individual patient level data – we are working on individual patient data meta-analyses with data from 6 trials to get at some of these issues (eg - outcomes by age decile)
○ baseline data on comorbidities broken down by age group | Most studies did not report comorbidities in this way.
○ analyses of interactions of age and comorbidity and ADEs:; - It may be hard for some clinical readers to understand why some studies were included by the criterion of comparing more intensive to less intensive therapy, but other studies were not. There are several studies that compare drug therapy to placebo, so appear to be studies of impact of treating HTN, or studies of impact of a particular drug, rather than specifically more vs less intensive treatment (although drug therapy vs placebo is certainly more intense vs less intense). Without pulling all the studies and looking at the underlying study design, it isn't easily clear to the reader why these studies of drug vs placebo are included while other studies of drug vs placebo are not. | We have tried to clarify this in the methods section under study selection. We did not exclude any studies of drug vs placebo that met other criteria (age and hypertensive population).
- the Limitations section acknowledges that there may be specific medication effects that are not part of the analyses in this ESP. this is an important point. There are specific drugs with more effect on outcomes (as in ALLHAT) and there are specific drugs that may, at least theoretically, have lower rates of particular ADEs (for example, thiazide diuretics may block calcium loss and may theoretically decrease risk of osteopenia). I agree that with the already limited number of studies with which to examine the key questions it would seem to be impossible to disentangle the effects of particular drugs. | Noted
- In addition to evidence regarding comorbidities, it would be useful to have evidence about the impact of the total number of medications that patient has apart from antihypertensives. As another descriptive factor about the study populations, information about total number of meds at baseline, as compared with total number of meds for VA patients of same age, would help clinicians with knowing how well the study patients resemble the patients they are seeing every day. | Most studies did not report this information.
- with the NNT of 10,000 given on page 28, seems that any conclusions about stroke should be very cautious. | We have re-run analyses as noted elsewhere and these numbers have changed.

Additional comments – Reviewer #8 | Response
I appreciate the concise executive summary. I was surprised that there was no discussion of how to handle HOT, which used DBP targets and the emphasis on achieved BP rather than target BP. In many cases, the studies were described as not having a target BP, but usually there was some information about the approach, though it was not used in this summary, presumably because the details were not precisely defined. I also did not find a justification for combining very disparate intervention and control interventions. Beyond the general idea that one arm achieved at least a tiny bit lower BP than the other in every study, there seems little justification for combining a placebo controlled study where the control arm had only a target SBP of less than 219 mm Hg to a study like HOT, where everyone targeted a DBP below 90, and some lower still. It does not appear the authors considered generating a more qualitative summary or at least some discussion of the implications of combining these very different studies. I did appreciate they looked at a number of more homogeneous subgroups, but the criteria were limited to baseline characteristics or achieved control in the intervention group, it seems. The fact that some of the studies had almost no difference in achieved BP, or had very different BP goals/permitted levels for the less intensive group was not addressed. | Appreciate the insightful comments. We have markedly changed much of the results section and the summary of evidence table both because we re-ran all analyses with SPRINT and in part to respond to these comments. Most of the RR/ARR have changed. We have clarified the rationale for synthesizing the data the way we did – hopefully it will be clear that we examined the data from different directions and that we clarified that the treat to target trials are distinct from the others. We revamped the way we analyzed and discussed the HOT trial. We also, hopefully, more clearly present the rationale and results of the numerous sensitivity analyses which should get at some of the issues noted here. For instance, we ran analyses excluding trials with minimal achieved differences in BP. We also included more detail under the “trial characteristics” section. Finally, we agree that the combination of all studies is relatively meaningless – we've explained this in results and deleted the combined analysis.
The table on page 5 has some useful numbers, though I found some confusing. In the first, mortality, row the point estimates of RR are actually very significant, even though they are not statistically significant. I think that the large N of the studies suggests that they pretty definitively ruled out an important benefit, but actually, the ARR seen in the subset is a pretty important change – the idea of preventing one death for every 100 persons treated is huge. It is a little hard to interpret since you use % when most people would have events per 100 pt – years. Here I can't tell if is 1% a year, or 1% over 20 years of treatment – pretty different things. | See above - these numbers have changed with new analyses
The stroke row is a really confusing one. The apparently statistically significant RR of 0.72 seems like it would be clinically important – a 28% RR reduction is as good as or better than we see with statins and MI in people with CVD!! But then the ARR is 0.01% - that is 1/10000. For me to reconcile these two numbers, I have to have an event rate of 3.6/10,000 compared to an event rate of 2.6/10,000. This seems like the stroke rate per week in some high risk groups and makes the NNT of 10,000 not so unimpressive after all!!! Again, the use of percentages is confusing in an ARR presentation. I think that a statistical explanation of these numbers would help me. I recognize that they likely come from different approaches to synthesizing data, and therefore can't be quite as simplistically interpreted as if they came from a single trial, but the relationship between ARR and RR needs to be transparent. | See above – numbers have changed.
Overall, it seems very hard to say that the evidence justifies the conclusion “Overall, we found moderate-strength evidence that using a systolic blood pressure target of 140 mm Hg or less did not appreciably improve outcomes in older patients compared to slightly higher targets.” Rather, I would say you “found little evidence that using a target of 140 mm Hg or less appreciably improve outcomes, but (you) cannot exclude as much as a 1/3 reduction in most important cardiovascular outcomes.” If you disagree, you need to reconcile your point estimates and 95% CI with the conclusions in some way that I don't see in the current version. | See above – we have revised the conclusions based on newer analyses
I think the conclusion on stroke is not very useful because it does nto discuss a target but a range. And the range is wide enough that people are going to wonder – “so what do you mean? Do you want them below 130 or do you want them below 140?” It is going to take an extra drug to get someone from 139 to 129, in most cases. So you need to describe what the data say iin a little more detail. Are you saying that <130 was better than < 150 and < 140 was better than < 150, but we can't tell if 130 or 140 are any different? Then it seems to me you are saying you can't tell if any further reduction below 140 is worth it. When you discussed the overall numbers, it seems you would not endorse < 140 as better because there was no studies where you took people in the 140-160 range and pushed some lower and left some above 140. So to me, you should say you don't have any studies of people < 140 that showed any additional benefit. So the benefit of <130 is not shown at all. | Agree – we have tried to clarify exactly what each trial showed.
FULL SYNTHESIS
I won't complain about the summary or the referring to the ‘rate’ of events without any evidence of a time frame, since I already said I found it confusing. I think that given the persistent references to the relative unimportance of a relative risk reduction of 25% some discussion of why they have that opinion is appropriate. It is greater than the benefit seen in some statin trials for primary and even secondary prevention, and similar to that seen with treatment in younger individuals. I can't account for some of the ARR calculations that suggest a remarkably small ARR in the setting of a significant event rate and a reasonably large summary estimate of RRR. But at least a reasonable approach would be to apply the observed RRR to a typical event rate in the target population and consider whether that would be considered a little more important than they consider the statistically significant drops in mortality and stroke, based solely on the quantitative combined analysis. | As above, we have redone our analyses with SPRINT and with the HOT subgroups combined differently so the RR and ARR have changed substantially as a result.
The comment on less heterogeneity in mortality among the 3 trials comparing <140 to higher targets, while I assume is mathematically true, is counterintuitive, since they include both the study with highest RR and the study with the lower RR among the 6 in Table 2. It really reflects the fact that with these smaller trials the fact that the results are quite disparate is not as statistically unlikely. Maybe you could tone that comment down. And the summary OR is really just the impact of the Wei study, which has 138 of the 164 deaths. I wonder if you should be making some comment on the Wei study, which is quite influential both in this analysis, and in the overall comparison of less intensive to more intensive trgets. The Wei study has a mortality in the less intensive arm that is more than 20% over 4 years. In contrast, the VALISH study has lower than 2% mortality over 3 years. The ages are roughly comparable, the amount of CAD is comparable, and the baseline BP is actually higher in VALISH. There is 10% more DM in the Wei study. But the difference in mortality is ENORMOUS. And the control group ends up with mean SBP around 150 in Wei, but 142 in VALISH even though both are trying to keep the control below 150 mm Hg (to keep a person reliably below 150, one must have a mean quite a bit below 150). The delta in SBP between the groups is 14 compared to less than 5 mm Hg. | We have revised this section substantially and no longer include this statement. Also, there were several peer review comments about the Wei study – we agreed that it seems an unusual study and and was an outlier. We conducted sensitivity analyses with and without this study.
The surprising stroke ARR versus RR numbers are again seen here, again without comment. I can't figure out the math on the ARR. Being a simple person, I see VALISH, a study in Japan, where in 3 years of follow up, in people mean age 76 years old, all with hypertension, the stroke rate is 1/100. Here, the ARR is 7/1000, about 10 times the estimated summary ARR – in the other studies the ARR is even higher, often much higher, except in JATOS, a study of 4000 participants, also from Japan, where there is no benefit for stroke. Yet the summary estimate is < 1/10,000? This makes no sense. The funny treatment of HOT, where you throw the <85 people in the <90 group makes it a little harder to interpret. As I recalled, when I looked up the actual hot numbers, the <85 did the worst of anyone, so it did not obscure a big benefit of BP lowering to put them in the <90 group – just the opposite – but it does not make sense, since it is targeting a number less than current guidelines, which is what you said you wanted to count as the intensive group. | As above, we have revamped our analyses of HOT. Agree that it made more sense to dichotomize 80/85 vs 90. We also conducted additional analyses without the middle group. Because the HOT was such a large trial, these changes had a large impact on results. We added a paragraph to results focused on HOT and the different analyses.
The table 3 would benefit from some information about the targets in the intervention group versus controls. Thus, in SHEP the comparison is a target SBP of 140 versus no target SBP, but both groups were treated for a target DBP of <90 – i.e., no matter how high the SBP don't treat the control group unless DBP > 90 mm Hg. In the Sys-Eur study, the control group was treated if they got above 219/99. In other studies in this table, e.g., TRANSCEND, all patients were fairly well controlled and the intervention simply added a drug. Thus, I don't see this analysis as very amenable to combination. | See above. We have examined the data quantitatively from several different angles, and added more description of the differences in studies and how these prompted various sensitivity analyses.
The cardiac event data (Figure 8) is also kind of interesting in that the three Asian studies have zero benefit in reducing an already incredibly low cardiac event rate – again, note how old they are and still very few events. In the American/European studies, lots of benefit. ACCORD is harder to interpret and also had a really low SBP target. Recall that recently we learned that high risk Japanese people don't benefit from aspirin in primary prevention of MI. Although you note the heterogeneity, you don't try to interpret it. I think you have a little freedom, and perhaps obligation to think about why there is heterogeneity, even though you are trying to make this part of the review a quantitative synthesis. | We have added a paragraph to the results and statements to the discussion describing the differences in event rates and speculating whether or not these may have accounted for some of the heterogeneity.
I am not sure why the DBP< 85 group is included with the DBP < 90 group in the HOT study. I would just drop the <85 people if you don't want to consider them separately. | See above
The ARR being greater with greater age is an artifact of higher event rates, not a bigger effect – note the RR are essentially the same. | See above
In the discussion of the results of the trials comparing more and less intensive therapy rather than competing targets, they note that the trials showing the largest ARR are ones with achieved SBP > 140. I would have noted that they are the ones with the largest delta SBP and the ones with the highest even rate in the control groups. | These #'s have changed. We focus now on the baseline BP subgroups (which overlap substantially with achieved BP groups) – the event rates are actually not higher in the higher baseline BP groups (overall).
The analysis of post stroke intensive versus less intensive is interesting in that it is positive and the ARR is considered nontrivial by the authors. I note that the event rate in both trials was over 10% for stroke alone and the delta SBP was 9 mm Hg and 11 mm Hg in the PROGRESS and SPS3 respectively | Noted
I found that the discussion of Key Question 2 was much more forthcoming about the difficulty of quantitatively combining very different studies and (perhaps consequently) very different results. | Noted
The discussion of KQ 3 found that ARR is higher when event rates are higher. This seems consistent with what one sees if one looks at BP Rx in general. Studies like STOP (Swedish Trial in Old People) and EWPHE (included in this review), with high event rates and studies like the MRC I and II trials, with low event rates, have similar RR (and RRR) but STOP and EWPHE had much larger ARR. | Noted
I found the discussions of KQ 4 and 5 similarly well calibrated to the relatively scant evidence. | Noted

Additional comments – Reviewer #15 | Response
General comments: This is an excellent and helpful report. Very well written. | Thank you.
Executive summary:
Next to last line intro---leave out “proposed” since it is done | Done
Last line ----- I would be more specific about what older is in this report (eg age> 60) | done
Quality assessment---were observational studies reviewed for quality? | We noted methodologic deficiencies of the few included observational studies in the cognitive study section.
Key findings---line 2----need “with” between compared and more | done
Line7---leave out “more” and state direction (what is the effect?) | done
Introduction:
∼ line 8---I think it should read “age” rather than “ages” groups | done
Table 1---GREAT TABLE | Thank you
Data synthesis:
I would rewrite 2^nd^ sentence----“We do not present CVD mortality data in this report since …..” | done
Study level meta-analysis sxn----last line 2^nd^ p---what currently defines mild htn? Do you want to include a lower boundary? I thought mild was 160-180? | Done
Detailed study results:
1^st^ p---I think you should say something like “Among 20 studies, X showed benefit from treating more intensely/to target. When data from these studies was combined in meta-analysis, more intensive……” | We revised the results section and have added some more detail to overview section re: # studies showing benefit
I don't understand how you can have a RR of 0.89 with CI 0.83-0.96 and 0 ARR | These #'s have changed with re-analysis
3^rd^ paragraph, last sentence----would be helpful to add the range of bp's (160, range 166-174). Also in 3^rd^ p, how much absolute risk difference do these 4 studies acct for? | We've revamped the entire results section and have included more information about the sensitivity analyses and resultant changes in ARR.
I think adding a figure/forrest plot for CVA and CAD for those younger/older than 70 as you do for total mortality would be very helpful (like figure 2) | We have revised KQ2 and included the age meta-analysis results here. However, because of concerns for ecologic fallacy we did not include the forest plots as we can't really use them to examine age-treatment effects with any degree of confidence
The Wei study stands out both for its results and control event rate. Note that the number of cardiovascular events is similar, the number of strokes 15 less in the I group and 36 total differences in death between the 2 groups. I am worried about the randomization. What are they dying of? Review of the quality ratings doesn't suggest this has low risk of bias to me. | Agree. We have revised accordingly. We also re-ran analyses without 2 other high risk of bias studies (we had overlooked this in first draft)
Page 28----the ARR of 1% for total mortality seems fairly big. | Numbers have all changed with SPRINT and additional analyses
Figure 9----title----add in “comparing x to x” | Done
Note the format of KQ 2 differs from KQ1 | We've added subheaders to make more similar
3^rd^ p, line 3 - “an” rather than “and” | Noted
SHEP description in p 3. I might state this: “conversely, the SHEP trial identified a decreased risk of stroke when the treated systolic blood pressures in patients with baseline bp's above 170 was less than 150 (mean X)” to be really clear. | Done
Renal outcomes ----- I am uncertain about this but it might be helpful to provide some numbers for changes in creatinine/GFR since this is such a common occurrence in practice. | Specific renal outcomes and numbers are presented in Table 6
Cognitive outcomes ----- in general (and this is true throughout) I recommend being more specific about bps rather than stating “moderately tight” as in first P of this section. Similarly, in the last paragraph “large proportion”----what % -this might matter. | The specific BPs are listed in following sentence. Re: large proportion with missing data – these numbers are in table –added the numbers into paragraph as well.
Falls/fractures----thoughts on the non-spine fractures? NSS but interesting. ? thiazides? | Unclear – mainly looking at this as potential harm – the trend towards benefit was seen in 2 studies but not in a third. Not sure we can much of the potential reduction in fracture risk.
The orthostatic hypotension stuff d/n make sense to me. Thoughts? | As we note, a number of trials found increased rates of hypotension. Three trials looked at syncope and 2 found a higher rate. We added sentence to discussion suggesting that the hypotension has potential to be serious given the excess rate of syncope in 2 trials.
Summary/discussion:
Line 2 “compared with….” | Noted
Need to discuss the 1% absolute mortality reduction a little bit more when you note that move aggressive treatment didn't “appreciably” improve outcomes | As above, all numbers have changed
Mid paragraph 1 ----- can you be more explicit rather than say “modest” effect? | We have put in NNT throughout
Paragraph 3. It would be interesting to find out usual stroke rates in the general age specific population given the low event rates you note. | Added a paragraph to discussion about event rates.
Tables 2 and 3----it might be helpful to add publication dates in column 1. I think there is a wide range | Agree. Done.