# APPENDIX C QUALITY ASSESSMENT

Table 11 Assessment of Randomized Controlled Trials for Potential Risk of Bias

Study | Allocation sequence adequately generated? | Allocation adequately concealed? | Knowledge of the allocated intervention adequately prevented during the study? | Incomplete outcome data adequately addressed? | Free of suggestion of selective outcome reporting? | Free of other problems that could put it at a high risk of bias? | Summary assessment High/Low/Unclear Risk of Bias | Funder
ACCORD^22^ | Yes: central, computer-based randomization | Yes | Yes: non-blinded study, but they used dual, blinded outcome adjudicators | Missing data assumed to be random, sensitivity analysis performed and outcome measures not significantly changed | Yes | Yes | Low | National Heart, Lung, Blood Institute; NIH agencies
ADVANCE^27^ | Yes: central, computer-based, randomization | Yes | Yes: participants, providers, outcome assessors all blinded | Yes: extremely low loss-to follow-up, 15 patients in a sample of >11,000 | Yes | Yes | Low | Servier; National Health and Medical Research Council of Australia
BENEDICT-B^28^ | Yes: central, computer-based randomization | Yes | Yes: participants, providers, outcome assessors all blinded | Yes: all censored events included in analysis, power and statistical significance were adequate | Yes | Yes | Low | Mario Negri Institute for Pharmacolo gic Research/Ins titute for Rare Diseases
Cardio-Sis^23^ | Yes: central, computer-based randomization | Yes | Yes: open-label study, but outcome adjudicators were blinded | Yes: only one patient lost to follow-up | Yes: Primary outcome was left ventricular hypertrophy, but cardiovascular and mortality endpoints were prespecified secondary outcomes | Yes | Low | Heart Care Foundation; Boehringer-Ingelheim, Sanofi-Aventis; Pfizer
EWPHE^29^ | Probably: patients were randomized and allocated by a central coordinating center, but exact method of randomization was not reported | Yes: central allocation | Yes: providers, patients, and outcome assessors all blinded | Yes: similar loss to follow-up in both groups (14 vs 16%), ITT analysis for mortality outcome | Yes, though ITT analysis was only performed for mortality outcome | Yes | Low | Belgian National Research Foundation; Merck, Sharp and Dohme and Smith; Kline and French
FEVER^30^ | Yes: central, computer-based randomization | Yes | Yes | Yes: life-status could not be obtained at study end but number was low (0.3%) | Yes | Yes | Low | National Science and Technology Ministry; Beijing Hypertension League Institute and Shanxi Kangbao Pharmaceutical Company
HOT^17^ | Yes: central, computer-based randomization | Yes | Yes: open-label but outcome adjudicators were blinded | Yes: 2.6% of patients lost to follow-up; total of 1.8% of all patient-years analyzed contained in censored group; analysis conducted up to time of loss and BP or prior morbidity not found to be significantly different | Yes | Yes | Low | Astra AB, Sweden; Astra Merck Inc, USA; TEVA, Israel; Hoechst, Argentina
HYVET^6^ | Yes: central, computer-based randomization | Yes | Yes: providers, patients, outcome assessors blinded | Yes: very low loss to follow-up (0.3% overall); ITT analysis | Yes | Yes: though of note inclusion criteria changed over time | Low | British Heart Foundation; Institut de Recherches International es Servier
JATOS^24^ | Yes: central, computer-based randomization | Yes | Yes: outcome assessors blinded; providers and patients likely not blinded but not clearly reported | Yes: censored events reported but no sensitivity analysis performed; ITT analysis | Yes | Unclear: there was not enough precision in protocol information describing outcome definitions | Low | Shionogi and Co. LTD
PROGRESS^31^ | Yes: central computer-based randomization | Yes | Yes: providers, patients, and outcome assessors blinded | Yes: very low loss to follow-up, though it is unclear whether this refers to vital status outcome or patients attending follow-up visits; ITT analysis | Yes | Yes | Low | Servier; Health Research Council of New Zealand; National Health and Medical Research Council of Australia
RENAAL^32^ | Yes: central, computer-based randomization | Yes | Yes: providers, patients, outcome assessors blinded | Yes: very low loss to follow-up; ITT analysis | Yes | Unclear - study was stopped early because of new data that ACE inhibitors were beneficial for population similar to that under study (considered unethical to continue) | Low | Merck
SCOPE^33^ | Yes: central randomization by fax | Yes | Yes: placebo control | Yes: losses to follow-up accounted for, multiple outcomes reported, ITT analysis | Yes | Yes: dual independent qualitative assessment reviews; sufficiently powered; prospective | Low | AstraZeneca
SHEP^8^ | Yes: central randomization and allocation | Yes | Yes: providers, patients, outcome assessors blinded | Yes: only 5 patients in each group were unavailable for follow-up; ITT analysis | Yes | Yes | Low | National Heart, Lung, Blood Institute; National Institute on Aging
SPRINT^11^ | Yes: central computer-based randomization | Yes | Yes: open-label, but outcomes were centrally adjudicated by blinded assessors | Yes: losses to follow-up accounted for, multiple outcomes reported, ITT analysis | Yes | Unclear: trial was stopped early by DSMB for benefit | Low | National Institutes of Health
SPS3^25^ | Yes: central, computer-based randomization | Yes | Yes: open-label, but outcome assessors blinded | Yes: though details on those lost to follow-up not available, overall rate low (3%); ITT analysis | Yes | Yes | Low | NIH-NINDS
STONE^19^ | No: patients were allocated alternately by entry order number | No | Yes: placebo control, but patients in placebo whose DBP >110 after the run-in period were switched by their physicians to active treatment | Yes: 2% loss to follow-up; ITT analysis | Yes: outcomes appear to be fully reported, but with methodological flaws earlier in study protocol | Yes: none others detected; randomization issues are serious | High | Ministry of Health of People's Republic of China; Bayer Canada
Syst-China^20^ | No: eligible patients at each center were alternatingly assigned to type A or type B medication | No | Yes: placebo control | Yes: ITT analysis; patients who withdrew remained in open follow-up; patients without any report within the year before the trial ended classified as lost to follow-up, but included in analysis up to the most recent evaluation of health status | Yes | Yes: randomization and allocation flaws have unclear effect on effectiveness estimates; methodological flaws significant | High | State Planning Commission of the People's Republic of China
Syst-Eur^34^ | Yes: central randomization and allocation | Yes | Yes: patients, providers, outcome assessors blinded | No: losses to follow-up and adverse events incompletely discussed, no illustrating figures | Yes | Yes | Low | Bayer; National Fund for Scientific Research
TRANSCEND^35^ | Yes: central, computer-based randomization | Yes | Yes: patients, providers, outcome assessors blinded | Yes: 99.7% had vital status ascertained; primary analysis included all patients, used time-to-event approach, counting the first occurrence of any component of the composite outcome | Yes | Yes | Low | Boehringer Ingelheim
VALISH^26^ | Yes: Centralized computer randomization | Yes | No: open label | Yes: 181 (5.5%) patients lost to follow-up; censored patients analyzed up to censoring event; ITT analysis | Yes | Yes | Low | Japan Cardiovascular Research Foundation
Wei, 2013^21^ | Yes: random numbers table computer-generated | Unclear whether allocation itself was concealed | No: open label and not enough detail about outcome adjudication procedure | No: concerning that those lost-to-follow-up are not mentioned in analysis; ITT analysis | Yes | No: small sample size, generalizability; no limitations section; inadequate description of how they obtained outcome information such as mortality or how they assessed cardiac events | High | Not disclosed