# APPENDIX B STUDY SELECTION

Table 9 Inclusion Codes, Code Definitions, and Criteria Corresponding to the Key Questions

Code | Definition | KQ1.What are the health outcome effects of differing blood pressure targets? | KQ2. How does age modify the benefits of differing blood pressure targets? | KQ3a. How does the patient burden of comorbidities modify the benefits of differing blood pressure targets? KQ3b. In patients who have suffered a TIA/stroke, does treatment of blood pressure to specific targets affect outcomes? | KQ4. Do the harms of targeting lower blood pressure vary with age? | KQ5. Do the harms of targeting lower blood pressure vary with patient burden of comorbidities?
I – Trial | Trials with ≥ 6 months of follow-up that address any of KQs 1-5. | [underlined: Population:] Adults aged ≥60 with hypertension [underlined: Intervention]: Pharmacologic treatment of hypertension [underlined: Comparator]: Usual care, or another specified SBP target. [underlined: Primary outcomes:]; - All-cause mortality; - Mortality related to stroke, CHD, CHF, and renal disease; - Morbidity including stroke, CHD, CHF, and renal disease; [underlined: Timing:] Published 2012 or later. Incidence of outcomes ≥ 6 months of hypertension treatment. [underlined: Study design:] Controlled trials (randomized or non-randomized) with ≥ 6 months of follow-up. | | | PICTS as for KQs 1-3, but with harms outcomes:; - Changes in cognition; - Falls; - Changes to quality of life; - Hypotension; - Acute kidney injury; Code B: large (n>10k) cohort studies that only report; - All-cause mortality; - Cardiovascular outcomes
I – Cohort | Cohort studies are included for KQs 4-5 only if they report harms.; - Large (N>10,000) multi-center cohort studies.; - Cohort extensions of major trials. | Data on the primary outcomes listed above will not be abstracted from cohort studies. | | | - Controlled study designs (RCT and non-randomized controlled clinical trials used for KQs 1-3); - Cohort extensions of trials that examined specific blood pressure targets; - Cohort studies that examined the effects of lower blood pressure in the context of antihypertensive medication; - Cohort studies that reported the effects of lower blood pressure despite that hypertension management was not the primary objective of the intervention studied.
I – Stroke | Trials of any duration that address KQ3a. | [underlined: Population KQ3b:] Aged ≥60 with hypertension and recent cerebrovascular accident (≤ 6 months). [underlined: Intervention KQ3b:] Pharmacologic treatment of hypertension within the first 6 months post-stroke. [underlined: Additional outcomes of interest for KQ3b:] Recurrent cerebrovascular accident; Functional status; Disability
I – SR | Systematic review or meta-analysis on any of the KQs

Table 10 Exclusion Codes, Code Definitions, and Criteria Corresponding to the Key Questions

Code | Definition | KQ1.What are the health outcome effects of differing blood pressure targets? | KQ2. How does age modify the benefits of differing blood pressure targets? | KQ3a. How does the patient burden of comorbidities modify the benefits of differing blood pressure targets? KQ3b. In patients who have suffered a TIA or stroke, does treatment of blood pressure to specific targets affect outcomes? | KQ4. Do the harms of targeting lower blood pressure vary with age? | KQ5. Do the harms of targeting lower blood pressure vary with patient burden of comorbidities?
X1 | Non-English publication | Note: most foreign language studies will be filtered out during initial library cleaning.
X2 | Article does not pertain in any way to hypertension -Rx treatment in older adults
X3 | Study population is not in scope for any of the KQs | [underlined: Include:] Adults with hypertension aged ≥ 60 or mean age ≥60. For KQ3: existing comorbidity or recent cerebrovascular accident (≤ 6 months). [underlined: Exclude:] Studies with mean age < 60.
X4 | No primary data, or study design not in scope | [underlined: Exclude:]; - Controlled before/after studies; - Case reports/case series; - RCTs with less than 6 month follow-up
X5 | Intervention modality or study objectives are not in scope | [underlined: Exclude:]; - Trials for which hypertension management was not the primary objective, despite that secondary effects on hypertension may be reported, eg, TNT for the j-curve effect.; - Non-pharmacologic interventions for blood pressure control; - Blood pressure interventions during the acute phase post-stroke (KQ3a). | | | Note: For KQs 4- 5, cohort studies that report harms of lower blood pressure may be included even if hypertension management was not the primary objective of the intervention studied.
X6 | None of the reported outcomes are in scope | [underlined: Primary outcomes of interest:]; - All-cause mortality; - Mortality related to stroke, CHD, CHF, and renal disease; - Morbidity including stroke, CHD, CHF, and renal disease | | | [underlined: Harms of interest:]; - Changes in cognition; - Falls; - Changes to quality of life; - Polypharmacy
X7 | Other reason, specify
B | Background | Add ‘B’ any of the above X codes (eg, ‘X6–B’) if the article contains information that may be useful for the introduction, discussion, limitations, future research, or other contextual purposes. Add comments or keywords as needed.

B = background; KQ = key question; CHD = congenital heart disease; CHF = congestive heart failure; RCT = randomized controlled trials; TIA = transient ischemic attack; TNT = treat to new targets