# APPENDIX A SEARCH STRATEGIES

## Databases Searched

- Ovid Medline
- PubMed [Publisher status segment]
- Embase
- Cochrane Library (Ovid EBM Reviews): Cochrane Central Register of Controlled Trials; Cochrane Database of Systematic Reviews; Database of Abstracts of Reviews of Effects; Health Technology Assessment; NHS Economic Evaluation Database

## Grey Literature Sources

- ClinicalTrials.gov
- World Health Organization International Clinical Trials Registry Platform (WHO ICTRP)
- International Standard Randomised Controlled Trials Number registry (ISRCTN)
- Conference Papers Index

Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) 1946 to January Week 4 2015

Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations January 29, 2015

Date of search: January 30, 2015

1 | Hypertension/ | 193547
2 | hypertension, malignant/ | 2172
3 | hypertension, renal/ | 12991
4 | hypertension, renovascular/ | 6296
5 | (hypertensive or hypertension or ((high or elevated or raised) adj2 blood pressure)).ti,ab. | 333658
6 | blood pressure/ | 238359
7 | systole/ | 16952
8 | diastole/ | 14899
9 | (blood pressure^*^ or arterial pressure^*^ or systole^*^ or (systol^*^ and (pressure^*^ or mm Hg or mm Hg)) or diastole^*^ or (diastol^*^ and (pressure^*^ or mm Hg or mm Hg)) or BP or DBP or (SBP not spontaneous bacterial peritonitis)).ti,ab. | 401649
10 | or/1-9 | 757490
11 | antihypertensive agents/ or acebutolol/ or alprenolol/ or amlodipine/ or atenolol/ or bendroflumethiazide/ or bepridil/ or betaxolol/ or bethanidine/ or bisoprolol/ or bupranolol/ or captopril/ or carteolol/ or celiprolol/ or chlorisondamine/ or chlorothiazide/ or chlorthalidone/ or cilazapril/ or clonidine/ or cyclopenthiazide/ or diazoxide/ or dihydralazine/ or diltiazem/ or doxazosin/ or enalapril/ or enalaprilat/ or felodipine/ or fosinopril/ or guanabenz/ or guanfacine/ or hydralazine/ or hydrochlorothiazide/ or hydroflumethiazide/ or indapamide/ or indoramin/ or isradipine/ or labetalol/ or lisinopril/ or losartan/ or methyldopa/ or metipranolol/ or metolazone/ or metoprolol/ or mibefradil/ or minoxidil/ or nadolol/ or nicardipine/ or nimodipine/ or nisoldipine/ or nitrendipine/ or oxprenolol/ or pempidine/ or penbutolol/ or perindopril/ or pinacidil/ or pindolol/ or polythiazide/ or prazosin/ or propranolol/ or ramipril/ or reserpine/ or timolol/ or todralazine/ or trichlormethiazide/ or xipamide/ or (antihypertensive or anti-hypertensive).ti,ab. | 191932
12 | adrenergic alpha-antagonists/ or adrenergic alpha-1 receptor antagonists/ or doxazosin/ or indoramin/ or labetalol/ or prazosin/ or adrenergic alpha-2 receptor antagonists/ or adrenergic beta-antagonists/ or alprenolol/ or bunolol/ or bupranolol/ or carteolol/ or dihydroalprenolol/ or iodocyanopindolol/ or levobunolol/ or metipranolol/ or nadolol/ or oxprenolol/ or penbutolol/ or pindolol/ or propranolol/ or sotalol/ or timolol/ or adrenergic beta-1 receptor antagonists/ or acebutolol/ or atenolol/ or betaxolol/ or bisoprolol/ or celiprolol/ or metoprolol/ or practolol/ or adrenergic beta-2 receptor antagonists/ or adrenergic beta-3 receptor antagonists/ or (adrenergic alpha-antagonist^*^ or adrenergic alphaantagonist^*^).ti,ab. | 93013
13 | angiotensin-converting enzyme inhibitors/ or captopril/ or cilazapril/ or enalapril/ or enalaprilat/ or fosinopril/ or lisinopril/ or perindopril/ or ramipril/ or angiotensin-converting enzyme inhibitor^*^.ti,ab. | 43990
14 | angiotensin receptor antagonists/ or angiotensin ii type 1 receptor blockers/ or losartan/ or saralasin/ or angiotensin ii type 2 receptor blockers/ or angiotensin receptor antagonist^*^.ti,ab. | 17586
15 | calcium channel blockers/ or amlodipine/ or amrinone/ or bencyclane/ or bepridil/ or cinnarizine/ or diltiazem/ or felodipine/ or fendiline/ or flunarizine/ or gallopamil/ or isradipine/ or lidoflazine/ or mibefradil/ or nicardipine/ or nifedipine/ or nimodipine/ or nisoldipine/ or nitrendipine/ or tiapamil hydrochloride/ or verapamil/ or calcium channel blocker^*^.ti,ab. | 70143
16 | diuretics/ or acetazolamide/ or amiloride/ or bendroflumethiazide/ or bumetanide/ or chlorothiazide/ or chlorthalidone/ or clopamide/ or cyclopenthiazide/ or ethacrynic acid/ or ethoxzolamide/ or furosemide/ or hydrochlorothiazide/ or hydroflumethiazide/ or indapamide/ or mefruside/ or methazolamide/ or methyclothiazide/ or metolazone/ or muzolimine/ or polythiazide/ or spironolactone/ or ticrynafen/ or triamterene/ or trichlormethiazide/ or xipamide/ or diuretics, osmotic/ or isosorbide/ or diuretics, potassium sparing/ or epithelial sodium channel blockers/ or mineralocorticoid receptor antagonists/ or sodium chloride symporter inhibitors/ or sodium potassium chloride symporter inhibitors/ or diuretic^*^.ti,ab. | 77139
17 | vasodilator agents/ or acetylcholine/ or adenosine/ or “adenosine-5′-(n-ethylcarboxamide)”/ or alprostadil/ or amiodarone/ or amrinone/ or amyl nitrite/ or bencyclane/ or bepridil/ or betahistine/ or bradykinin/ or calcitonin gene-related peptide/ or celiprolol/ or chromonar/ or colforsin/ or cromakalim/ or cyclandelate/ or diazoxide/ or dihydroergocristine/ or dihydroergocryptine/ or dilazep/ or diltiazem/ or dipyridamole/ or dyphylline/ or enoximone/ or ergoloid mesylates/ or erythritol/ or erythrityl tetranitrate/ or flunarizine/ or hexobendine/ or iloprost/ or isosorbide dinitrate/ or isoxsuprine/ or isradipine/ or khellin/ or lidoflazine/ or mibefradil/ or milrinone/ or minoxidil/ or molsidomine/ or moxisylyte/ or nafronyl/ or niacin/ or nicardipine/ or nicergoline/ or nicorandil/ or nicotinyl alcohol/ or nifedipine/ or nimodipine/ or nisoldipine/ or nitrendipine/ or nitroglycerin/ or nitroprusside/ or nonachlazine/ or nylidrin/ or oxprenolol/ or oxyfedrine/ or papaverine/ or pentaerythritol tetranitrate/ or pentoxifylline/ or perhexiline/ or phenoxybenzamine/ or pinacidil/ or pindolol/ or pituitary adenylate cyclase-activating polypeptide/ or polymethyl methacrylate/ or prenylamine/ or s-nitroso-n-acetylpenicillamine/ or s-nitrosoglutathione/ or s-nitrosothiols/ or sodium azide/ or suloctidil/ or theobromine/ or theophylline/ or thiouracil/ or tolazoline/ or trapidil/ or trimetazidine/ or vasoactive intestinal peptide/ or verapamil/ or xanthinol niacinate/ or endothelium-dependent relaxing factors/ or nitric oxide/ or vasodilator^*^.ti,ab. | 350538
18 | Aldosterone/ | 21964
19 | Chlorisondamine/ | 543
20 | Mineralocorticoids/ or Desoxycorticosterone/ or Desoxycorticosterone Acetate/ | 8175
21 | Pempidine/ | 163
22 | Renin-Angiotensin System/ | 14256
23 | or/11-22 | 632178
24 | exp Cardiovascular Diseases/ | 1901992
25 | exp Heart Failure/ | 88568
26 | exp Kidney Diseases/ or exp Kidney Failure, Chronic/ | 415035
27 | hypotension/ | 17869
28 | stroke/ or brain infarction/ or brain stem infarctions/ or lateral medullary syndrome/ or cerebral infarction/ or dementia, multi-infarct/ or infarction, anterior cerebral artery/ or infarction, middle cerebral artery/ or infarction, posterior cerebral artery/ or stroke, lacunar/ | 88131
29 | polypharmacy/ | 2517
30 | exp cognition disorders/ | 63655
31 | exp dementia/ | 121166
32 | accidental falls/ | 15941
33 | exp fractures, bone/ | 142161
34 | “quality of life”/ | 121510
35 | (death^*^ or mortalit^*^ or morbidit^*^ or comorbidit^*^ or co-morbidit^*^ or multimorbidit^*^ or multi-morbidit^*^ or coexist^*^ or co-exist^*^ or stroke^*^ or infarct^*^ or multiinfarct^*^ or multi-infarct^*^ or transient ischemic attack^*^ or TIA or cerebrovascular or (heart adj (disease^*^ or failure^*^)) or ((renal or nephro^*^ or kidney) adj2 (disease^*^ or failure^*^ or disorder^*^ or injury or injuries)) or AKI or fracture^*^ or falls or cognit^*^ or dementia^*^ or hypotension or hypotensive or polypharm^*^ or “quality of life”).ti,ab. | 2265610
36 | or/24-35 | 3913057
37 | and/10,23,36 | 120955
38 | limit 37 to “all aged (65 and over)” | 30492
39 | (elder^*^ or aged or old or older or oldest or senior^*^ or geriatric^*^ or gerontolog^*^ or sexagenarian^*^ or septuagenarian^*^ or octogenarian^*^ or nonagenarian^*^).ti,ab. | 1436775
40 | 37 and 39 | 15236
41 | 38 or 40 | 38096
42 | cohort studies/ or follow-up studies/ or longitudinal studies/ or prospective studies/ or retrospective studies/ or ((cohort^*^ or trial^*^) adj3 extension^*^).ti,ab. | 1387757
43 | and/41-42 | 7501
44 | limit 43 to (comment or editorial or letter) | 77
45 | 43 not 44 | 7424
46 | limit 45 to english language [OBSERVATIONAL STUDY RESULTS] | 6655
47 | limit 41 to (meta analysis or systematic reviews) | 643
48 | 47 not 46 | 541
49 | limit 48 to english language [META-ANALYSIS AND SYSTEMATIC REVIEW RESULTS] | 474
50 | and/10,23 | 162820
51 | (201212^*^ or 2013^*^ or 2014^*^ or 2015^*^).ed. or (201212^*^ or 2013^*^ or 2014^*^ or 2015^*^).dc. | 2570599
52 | and/50-51 | 10390
53 | limit 52 to (clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or pragmatic clinical trial or randomized controlled trial) | 1037
54 | limit 53 to english language | 988
55 | remove duplicates from 54 [RCT/CCT RESULTS] | 956

## EMBASE (Elsevier)

http://embase.com

Date of search: January 30, 2015

Search Strategy | | Results
44 | #41 OR #42 OR #43 | 2,594 (http://www.embase.com/)
43 | #39 AND ([controlled clinical trial]/lim OR [randomized controlled trial]/lim) AND [english]/lim NOT [medline]/lim | 1,138 (http://www.embase.com/)
42 | #39 AND [english]/lim AND ([cochrane review]/lim OR [systematic review]/lim OR [meta analysis]/lim) NOT [medline]/lim | 186 (http://www.embase.com/)
41 | #40 AND [english]/lim NOT ([editorial]/lim OR [letter]//lim OR [medline]/lim) | 1,475 (http://www.embase.com/)
40 | #39 AND (‘cohort analysis’/de OR ‘observational study’/de OR ‘prospective study’/de OR ‘retrospective study’/de OR ‘longitudinal study’/de OR ‘follow-up study’:ab,ti OR ‘follow-up studies’:ab,ti OR ((cohort^*^ OR trial^*^) NEAR/3 extension^*^):ab,ti) | 6,637 (http://www.embase.com/)
39 | #37 OR #38 | 65,498 (http://www.embase.com/)
38 | #7 AND #22 AND #35 AND (elder^*^:ab,ti OR aged:ab,ti OR old:ab,ti OR older:ab,ti OR oldest:ab,ti OR senior^*^:ab,ti OR geriatric^*^:ab,ti OR gerontolog^*^:ab,ti OR sexagenarian^*^:ab,ti OR septuagenarian^*^:ab,ti OR octogenarian^*^:ab,ti OR nonagenarian^*^:ab,ti) | 37,068 (http://www.embase.com/)
37 | #7 AND #22 AND #35 AND ([aged]/lim OR [very elderly]/lim) | 42,220 (http://www.embase.com/)
36 | #7 AND #22 AND #35 | 251,536 (http://www.embase.com/)
35 | #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #33 OR #34 | 5,706,843 (http://www.embase.com/)
34 | death^*^:ab,ti OR mortalit^*^:ab,ti OR morbidit^*^:ab,ti OR comorbidit^*^:ab,ti OR ‘co-morbidity’:ab,ti OR ‘co-morbidities’:ab,ti OR multimorbidit^*^:ab,ti OR ‘multi-morbidity’:ab,ti OR ‘multi-morbidities’:ab,ti OR coexist^*^:ab,ti OR ‘co-existing’:ab,ti OR stroke^*^:ab,ti OR infarct^*^:ab,ti OR multiinfarct^*^:ab,ti OR ‘multi-infarction’:ab,ti OR ‘multi-infarctions’:ab,ti OR ‘transient ischemic attack’:ab,ti OR ‘transient ischemic attacks’:ab,ti OR tia:ab,ti OR cerebrovascular:ab,ti OR (heart NEXT/1 (disease^*^ OR failure^*^)):ab,ti OR ((renal OR nephro^*^ OR kidney) NEAR/2 (disease^*^ OR failure^*^ OR disorder^*^ OR injury OR injuries)):ab,ti OR aki:ab,ti OR fracture^*^:ab,ti OR falls:ab,ti OR cognit^*^:ab,ti OR dementia^*^:ab,ti OR hypotension:ab,ti OR hypotensive:ab,ti OR polypharm^*^:ab,ti OR ‘quality of life’:ab,ti | 2,969,107 (http://www.embase.com/)
33 | ‘quality of life’/de | 268,408 (http://www.embase.com/)
32 | ‘fracture’/exp | 215,542 (http://www.embase.com/)
31 | ‘falling’/de | 25,824 (http://www.embase.com/)
30 | ‘dementia’/exp | 238,471 (http://www.embase.com/)
29 | ‘disorders of higher cerebral function’/exp | 553,733 (http://www.embase.com/)
28 | ‘polypharmacy’/de | 7,732 (http://www.embase.com/)
27 | ‘cerebrovascular disease’/exp | 480,125 (http://www.embase.com/)
26 | ‘hypotension’/exp | 106,487 (http://www.embase.com/)
25 | ‘kidney disease’/exp | 707,514 (http://www.embase.com/)
24 | ‘heart failure’/exp | 322,750 (http://www.embase.com/)
23 | ‘cardiovascular disease’/exp | 3,134,649 (http://www.embase.com/)
22 | #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 | 1,125,178 (http://www.embase.com/)
21 | ‘renin angiotensin aldosterone system’/de | 31,112 (http://www.embase.com/)
20 | ‘pempidine’/de | 283 (http://www.embase.com/)
19 | ‘deoxycorticosterone acetate’/de | 2,712 (http://www.embase.com/)
18 | ‘deoxycorticosterone’/de | 7,177 (http://www.embase.com/)
17 | ‘mineralocorticoid’/exp | 71,060 (http://www.embase.com/)
16 | ‘chlorisondamine’/de | 1,025 (http://www.embase.com/)
15 | ‘aldosterone’/de | 31,797 (http://www.embase.com/)
14 | ‘vasodilator agent’/exp OR vasodilator^*^:ab,ti | 430,197 (http://www.embase.com/)
13 | ‘diuretic agent’/exp OR diuretic^*^:ab,ti | 310,799 (http://www.embase.com/)
12 | ‘calcium channel blocking agent’/exp OR ‘calcium channel blocker’:ab,ti OR ‘calcium channel blockers’:ab,ti | 187,980 (http://www.embase.com/)
11 | ‘angiotensin 2 receptor antagonist’/exp OR ‘angiotensin ii receptor antagonist’:ab,ti OR ‘angiotensin ii receptor antagonists’:ab,ti | 8,252 (http://www.embase.com/)
10 | ‘angiotensin receptor antagonist’/exp OR ‘angiotensin receptor antagonist’:ab,ti OR ‘angiotensin receptor antagonists’:ab,ti | 63,456 (http://www.embase.com/)
9 | ‘adrenergic receptor blocking agent’/exp OR ‘adrenergic alpha-antagonist’:ab,ti OR ‘adrenergic alpha-antagonists’:ab,ti OR ‘adrenergic alphaantagonist’:ab,ti | 342,302 (http://www.embase.com/)
8 | ‘antihypertensive agent’/exp OR antihypertensive:ab,ti OR ‘anti hypertensive’:ab,ti | 593,629 (http://www.embase.com/)
7 | #1 OR #2 OR #3 OR #4 OR #5 OR #6 | 1,115,118 (http://www.embase.com/)
6 | ‘blood pressure’:ab,ti OR ‘arterial pressure’:ab,ti OR systole^*^:ab,ti OR (systol^*^:ab,ti AND (pressure^*^:ab,ti OR mm Hg:ab,ti OR ‘mm hg’:ab,ti)) OR diastole^*^:ab,ti OR (diastol^*^:ab,ti AND (pressure^*^:ab,ti OR mm Hg:ab,ti OR ‘mm hg’:ab,ti)) OR bp:ab,ti OR dbp:ab,ti OR (sbp:ab,ti NOT ‘spontaneous bacterial peritonitis’:ab,ti) | 505,982 (http://www.embase.com/)
5 | ‘diastole’/de | 14,230 (http://www.embase.com/)
4 | ‘systole’/de | 13,554 (http://www.embase.com/)
3 | ‘blood pressure’/exp | 415,778 (http://www.embase.com/)
2 | hypertensive:ab,ti OR hypertension:ab,ti OR (((high OR elevated OR raised) NEAR/2 blood):ab,ti AND pressure:ab,ti) | 458,732 (http://www.embase.com/)
1 | ‘hypertension’/exp | 513,148 (http://www.embase.com/)

## Cochrane Library (Ovid EBM Reviews)

- Cochrane Central Register of Controlled Trials December 2014
- Cochrane Database of Systematic Reviews 2005 to December 2014
- Database of Abstracts of Reviews of Effects 4th Quarter 2014
- Health Technology Assessment 4th Quarter 2014
- NHS Economic Evaluation Database 4th Quarter 2014

Date of search: January 30, 2015

1 | (hypertensive or hypertension or ((high or elevated or raised) adj2 blood pressure)).ti,ab. | 29303
2 | (blood pressure^*^ or arterial pressure^*^ or systole^*^ or (systol^*^ and (pressure^*^ or mm Hg or mm Hg)) or diastole^*^ or (diastol^*^ and (pressure^*^ or mm Hg or mm Hg)) or BP or DBP or (SBP not spontaneous bacterial peritonitis)).ti,ab. | 44700
3 | and/1-2 | 16149
4 | (antihypertensive or anti-hypertensive).ti,ab. | 8074
5 | (adrenergic alpha-antagonist^*^ or adrenergic alphaantagonist^*^).ti,ab. | 0
6 | angiotensin-converting enzyme inhibitor^*^.ti,ab. | 2444
7 | angiotensin receptor antagonist^*^.ti,ab. | 74
8 | calcium channel blocker^*^.ti,ab. | 1575
9 | diuretic^*^.ti,ab. | 4287
10 | vasodilator^*^.ti,ab. | 2596
11 | or/4-10 | 16071
12 | (death^*^ or mortalit^*^ or morbidit^*^ or comorbidit^*^ or co-morbidit^*^ or multimorbidit^*^ or multi-morbidit^*^ or coexist^*^ or co-exist^*^ or stroke^*^ or infarct^*^ or multiinfarct^*^ or multi-infarct^*^ or transient ischemic attack^*^ or TIA or cerebrovascular or (heart adj (disease^*^ or failure^*^)) or ((renal or nephro^*^ or kidney) adj2 (disease^*^ or failure^*^ or disorder^*^ or injury or injuries)) or AKI or fracture^*^ or falls or cognit^*^ or dementia^*^ or hypotension or hypotensive or polypharm^*^ or “quality of life”).ti,ab. | 155570
13 | (elder^*^ or aged or old or older or oldest or senior^*^ or geriatric^*^ or gerontolog^*^ or sexagenarian^*^ or septuagenarian^*^ or octogenarian^*^ or nonagenarian^*^).ti,ab. | 70846
14 | and/3,11-13 | 536
15 | limit 14 to medline records [Limit not valid in CDSR,DARE,CLHTA,CLEED; records were retained] | 407
16 | 14 not 15 | 129
17 | limit 16 to english language [Limit not valid in CDSR,DARE; records were retained] | 84