# ABBREVIATIONS

Abbreviation: Definition
α-B: Alpha-blocker
β-B: Beta-blocker
ACCORD: Action to Control Cardiovascular Risk in Diabetes
ACE: Angiotensin converting enzyme
ADL: Activities of daily living
ADVANCE: Action in Diabetes and Vascular Disease
AE: Adverse effect or event
AHRQ: Agency for Healthcare Research and Quality
ARB: Angiotensin II receptor blockers
ARR: Absolute risk reduction
BENEDICT-B: Bergamo Nephrologic Diabetes Complications Trial-B
BioLINCC: Biologic Specimen and Data Repository Information Coordinating Center
BP: Blood Pressure
BPLTTC: Blood Pressure Lowering Treatment Trialists Collaborative
CAD: Coronary artery disease
Cardio-Sis: Studio Italiano Sugli Effetti Cardiovascolari del Controllo della Pressione Arteriosa Sistolica
CCB: Calcium channel blocker
CHD: Coronary heart disease
CHF: Congestive heart failure
CI: Confidence interval
CKD: Chronic kidney disease
CVA: Cerebrovascular accident
CVD: Cerebrovascular disease
DBP: Diastolic blood pressure
DM: Diabetes mellitus
DSST: Digit Symbol Substitution Test
ESP: Evidence-based Synthesis Program
EuroQOL: European Quality of Life scale
EWPHE: European Working Party on High Blood Pressure in the Elderly
FEVER: Felodipine Event Reduction Study
HOT: Hypertension Optimal Treatment
HR: Hazard ratio
HYVET: Hypertension in the Very Elderly Trial
JATOS: Japanese Trial to Assess Optimal Systolic Blood Pressure in Elderly Hypertensive Patients
JNC-BP: Joint National Committee on the Prevention, Detection, Evaluation, and Treatment of High Blood Pressure
KQ: Key Question(s)
LVH: Left Ventricular Hypertrophy
Ml: Myocardial infarction
mm Hg: Millimeters of mercury (unit of pressure)
MMSE: Mini-mental state examination
MRI: Magnetic resonance imaging
N: Number randomized (N= total, n = subgroup)
NNT: Number needed to treat
NR: Not reported
ns: Not statistically significant
OR: Odds ratio
PALT: Paired Associate Learning Test
PGWB: Psychological General Well-Being
PICOTS: Population, intervention, comparator, outcome, timing, study design
PROGRESS: Perindopril Protection Against Recurrent Stroke Study
QOL: Quality of life
RCT: Randomized controlled trial
RENAAL: Reduction of Endpoints in NIDDM with the Angiotensin II Antagonist Losartan
RR: Relative risk
SBP: Systolic blood pressure
SCOPE: Study on Cognition and Prognosis in the Elderly
SD: Standard deviation
SHEP: Systolic Hypertension in the Elderly Program
SIP: Sickness Impact Profile
SPRINT: Systolic Blood Pressure Intervention Trial
SPS3: Secondary Prevention of Small Subcortical Strokes
SSA-P: Subjective Symptoms Assessment Profile
STONE: Shanghai Trial of Nifedipine in the Elderly
Syst-China: Systolic Hypertension in China
Syst-Eur: Systolic Hypertension in Europe
TIA: Transient ischemic attack
TRANSCEND: Telmisartan Randomized Assessment Study in ACE Intolerant Subjects with Cardiovascular Disease
VA: Veterans Administration
VALISH: Valsartan in Elderly Isolated Systolic Hypertension
WHO: World Health Organization