# SUMMARY AND DISCUSSION

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Questions 1 and 1a – Incidence

- The published literature provides limited information about the true incidence and prevalence of blast-related injuries experienced by US military personnel. Findings are likely influenced by assessment and reporting methods.
- The reported explosion injury incidence ranged from 4.5/1,000 deployed in 2005 to 1.7/1,000 deployed in 2009.
- During the Iraq troop surge (2007) explosion injury incidence was particularly high (83/1,000 deployed in a US Army Brigade Combat Team).
- Musculoskeletal explosion injury incidence (fractures, amputations, neurological injuries, joint dislocations, and soft tissue injuries) ranged from 3.5/1,000 deployed in 2005 to 1.3/1,000 deployed in 2009.
- Spinal injury incidence (fractures, dislocations, nerve root injuries, spinal cord injuries) ranged from 0.18/1,000 deployed in 2008 to 0.40/1,000 deployed in 2005.
- Thoracolumbar burst fracture incidence was low (0.45 to 2.1 per 10,000 soldier years between 2008 and 2010) but higher in Afghanistan than Iraq and increased over the study period.
- No study reported incidence by blast characteristics.

### Key Question 2 and 2a – Prevalence

- Nearly three-quarters of all combat injuries over the period from 2005 to 2009 (31 per 10,000 deployed) were due to explosions.
- A high proportion of musculoskeletal injuries (82%; 23 per 10,000 deployed) and spinal injuries (75%; 3 per 10,000 deployed) between 2005 and 2009 were due to explosions. Of the musculoskeletal injuries, 80% of axial skeletal and extremity fractures, 94% of amputations, and 85% of soft tissue injuries were explosion-related. Another study reported explosion-related amputations in 4 per 10,000 troop-years (Iraq) and 9 per 10,000 troop-years (Afghanistan) over the period from 2001 to 2011.
- No study reported prevalence by blast characteristics.

### Key Question 3

- The published literature provides limited information on outcomes associated with blast versus non-blast TBI experienced by US military personnel. Definitions of blast/non- blast injury, assessment of outcomes, and reporting methods vary and often are based on small selected groups.
- Blast and non-blast TBI groups had similar rates of pain, vision loss, vestibular dysfunction, functional ability, depression, sleep disorders, alcohol misuse, and post- concussive symptoms.
- Comparative outcomes in individuals with blast versus non-blast TBI were inconsistent across studies with regard to PTSD diagnosis or symptom severity, hearing loss, cognitive function, and headache in blast and non-blast TBI groups.
- Mortality, burn injuries, limb loss, and quality of life were infrequently reported in studies comparing blast versus non-blast TBI.
- Results were consistent across studies that varied by location of assessment (combat zone, medical facility), time from exposure to assessment (< 30 days, 30 days to one year, or > one year), and level of TBI severity, although the most studies were small, clinical cohort studies, with mTBI patients evaluated at a DoD or VA medical facility.
- There is little data on outcomes among those with TBI according to blast characteristics.

## DISCUSSION

Numerous studies have reported combat casualties but do not provide a denominator to allow for determination of true incidence or prevalence in the deployed population at risk.^49^ For example, Ivey et al reported that 2,049 of 23,797 wounded US military personnel documented in the JTTR from January 2003 to May 2011 sustained thoracic injuries, a “prevalence” of 8.6%.^50^ They further note that an explosive device was the source of injury for 62% of the thoracic injuries. However, these data do not allow a true determination of prevalence of thoracic injuries associated with explosive devices among deployed service members. Our literature search identified studies like the Ivey et al study for deaths (Eastridge 2012) and other types of injuries including spinal column, craniomaxillofacial, colorectal, ocular, otologic, and extremity.^51-56^

Similarly, we identified a recent systematic review and meta-analysis reporting the “prevalence” and characteristics of battle casualties in Iraq and Afghanistan.^57^ The review included 8 studies spanning 2001 to 2013. Four of the studies are included in our review; the remaining 4 studies would not have been eligible for our review because they were either single facility or short-term studies, not published in English, and/or not predominantly US soldiers. Different studies addressed the casualty classifications (died of wounds, killed in action [KIA], wounded in action, and returned to duty) differently (eg, one study included only KIA; 2 other studies excluded KIA) but the results of all 8 studies were combined. Of 19,671 battle casualties, 14,056 (72%) were caused by blasts but, again, no denominator of deployed service members was provided.

The DoDTR (formerly the JTTR) is recognized as the best available source of data for the study of US military combat injuries, but it is not without limitations.^7^ The DoDTR provides data on all combat casualty cases initially entering the Joint Theater Trauma System at Level III medical facilities (combat zone). Information is added to the DoDTR as the service member moves to an out-of-theater facility and ultimately to a facility in the United States (if required for their care). Disadvantages of the DoDTR include variations in the reliability of the data entered by non-researchers involved in the delivery of care, absence of data on service members killed in action or returned to duty (ie, not medically evacuated), and absence of data on US troops treated at North Atlantic Treaty Organization Facilities prior to late 2008.^7,50^ Furthermore, in 2007, the system for classifying mechanism of injury used in the JTTR was changed and injuries are now classified as primarily blunt or penetrating. As a result, blast injury is now less frequently reported.^50^

Few studies of blast incidence or blast-related TBI outcomes report any of the important characteristics of a blast injury: how far the individual was from the blast, whether they experienced a blast wave, whether there was loss of consciousness or altered consciousness, whether there was amnesia (and length of time), and whether there was additional trauma.^58^ There have been attempts to document this information, however. Data from 367,555 service members who completed a Post-Deployment Health Assessment (PDHA) that included questions about possible TBI events experienced during deployments from 2012 to 2015 showed that 45.7% with a positive TBI screen experienced a blast or explosion.^59^ Among those who reported the distance from the blast, the majority were less than 25 meters away. Over 30% reported receiving more than one concussive event during the deployment. Among those with a positive TBI screen, 11.5% reported 3 or more events.

We found no reports of blast injuries associated with different combat roles. One combat role considered to place soldiers at higher risk of injury due to repeated low-level primary blast exposure is that of breacher. Breachers place explosives on structures where access is needed and then stand at a “safe” distance away during the explosion. A study of US Marines enrolled in a 2-week Breacher Training Course focused on auditory and vestibular effects.^60^ Clinically significant hearing loss was noted while the vestibular effects were “unremarkable.” A similar study enrolling US Marine instructors measured effects on vision.^61^ The analysis included 9 breacher instructors (estimated to be exposed to 500 to 600 “low-level” blasts each year of a 2-to-3-year assignment) and a control group of 4 breacher engineers (not exposed to blasts) with repeat testing of both groups over a 2-year period. Vision test results for the blast-exposed group were within or slightly lower (worse) than normal ranges and symptom scores did not differ between blast-exposed and control. A study of 21 participants in a 2-week New Zealand military breacher training course where blast exposures occurred one to 20 times per day on 5 of the training days observed changes in neurocognitive performance and self-reported symptom scores warranting further investigation.^62^ A report of neuropsychological and neurocognitive outcomes following a Canadian Explosives Forced Entry course (10 days of lectures and training on use of explosives to gain entry into building walls, doors, and windows) for police (4 instructors and 10 students) found no significant changes from baseline to the end of the course.^63^

## LIMITATIONS

The limitations of this review relate to little published information on blast injuries and variations in reporting across studies. There is no information on incidence and prevalence of blast injuries by blast mechanism (eg, primary, secondary, tertiary, quaternary, quinary) and limited reporting in studies comparing blast and non-blast TBI. For determination of incidence and prevalence, there are also limited published data on numbers of soldiers deployed that accurately take into account factors such as true deployment length, combat intensity, and type of unit.^7^ Clear and consistent definitions for injuries (eg, casualties, battle injuries, wounded in action, etc) and consistent standards for what to include in numerators and denominators when calculating incidence is necessary for accurate interpretation of combat trauma data.^64^

In the TBI studies, diagnoses and outcomes assessment were done at different time points following the blast and using different instruments, making comparisons across studies difficult. Reporting of symptoms may change over time and persistent or late-occurring symptoms may or may not be related to an earlier TBI.^4^ For example, a recent study of 119,353 active duty US service members who began their first deployment in 2011 and were followed for approximately 4 years reported 11,498 first-time TBI diagnoses in the cohort including 2,525 prior to deployment, 3,086 during deployment, and 5,897 after deployment.^65^ Cause of injury data were not complete and were not fully reported. In addition, authors used varying definitions of blast/non-blast injury. It was unclear whether the increased rate of TBI diagnoses post-deployment was a result of late diagnoses of TBI that occurred during deployment, delayed diagnoses during a more complete evaluation of severe injuries obtained during deployment, or increased post-deployment injury, possibly due to increased risk-taking behaviors.

Furthermore, confounding factors in studies of blast-exposed soldiers make it difficult to isolate the effects of the blast.^63^ In studies comparing individuals with blast and non-blast TBI, outcomes such as headache, sleep disturbance, memory difficulties, and depression may be attributed to factors other than blast exposure (eg, deployment status, chronic pain and other physical injuries, substance use disorders).^4^

## APPLICABILITY OF FINDINGS TO THE VA POPULATION

Our review was limited to studies of combat injuries associated with OEF, OIF, and OND. The findings are highly applicable to military personnel and organizations that provide direct acute or chronic health care services including rehabilitation as well as employment to those either currently serving or of recent Veteran status. Additionally, an understanding of the incidence, prevalence, outcomes, and causal factors of blast and non-blast injuries may be used to help reduce these injuries in future combat operations.

However, many studies reported findings from individuals presenting to medical facilities and undergoing treatment for a specific combat injury. Patient and injury characteristics and subsequent health outcomes from these selected patients may differ in unknown ways from the broader group of individuals who had combat injuries. We also have little information on very long-term effects (eg, cognitive function decline over decades).

The Analysis of VA Health Care Utilization among Operation Enduring Freedom (OEF), Operation Iraqi Freedom (OIF), and Operation New Dawn (OND) Veterans (released June 2015) reports that 1,906,754 OEF/OIF/OND Veterans have become eligible for VA health care since fiscal year 2002 (beginning October 1, 2001) and approximately 2.7 million troops (as of December 31, 2014) have served or are serving in the 2 theaters of operation since the beginning of the conflicts in Iraq and Afghanistan (http://www.publichealth.va.gov/docs/epidemiology/healthcare-utilization-report-fy2015-qtr1.pdf Accessed 10 August 2015). In 2007, the VA began a program of TBI screening and comprehensive. OEF/OIF/OND Veterans who present for care at a VA facility undergo a screen for TBI.^66^ One of the screening questions addresses exposure to physical trauma. Veterans who screen positive for TBI undergo a comprehensive evaluation. An analysis of data from October 2007 to June 2010 found that 55% (30,267/55,070) of those evaluated for TBI after a positive screen were diagnosed with TBI. Of those, 36% had blast exposure and 44% had both blast and non-blast exposures.^67^

## RESEARCH GAPS/FUTURE RESEARCH

In the Institute of Medicine's “Gulf War and Health, Volume 9: Long-term Effects of Blast Exposures,” recommendations for future work highlighted the need to fill the gaps in the evidence base pertaining to the health effects of blast exposure and the need for greater emphasis on identifying and treating the complex injury patterns that often follow blast exposure. Collaborative efforts between the VA, DoD, and others were encouraged including the development of more complete registries with detailed information about the blast environment, information about both blast-injured and blast-exposed service members, and measurement of long-term health outcomes.^68^

Accurately recording in a standardized fashion every injury to every individual who experiences a blast (including type of blast [eg, primary, secondary, etc], distance from the blast, etc), and then following those individuals to assess long-term outcomes, would be ideal insofar as possible within the combat environment. However, for those who have been determined to have received blast-related injuries, additional information on the circumstances surrounding the injury should include: type of blast, distance from the blast, history of blast exposure, injury severity, assigned and actual duties, and military member's physical and psychosocial characteristics. Additional information gathered would be useful to evaluate methods to reduce combat-related blast injuries. Comparisons versus deployed controls may facilitate our understanding of the mechanisms and severity of blast-related injuries and the long-term health and social consequences of those injuries. This includes not only the treatments and health outcomes specific to the blast injury but also the long-term psychosocial, employment, and economic impact of blast injuries and the role and capacity needs for health care systems and the work force as these individuals reintegrate into the civilian society. Existing databases may already contain some of this information and future analyses should incorporate blast data where possible.

## CONCLUSIONS

- The published literature provides limited information about the true incidence and prevalence of blast-related injuries experienced by US military personnel and the outcomes associated with blast versus non-blast TBI. We found no reports of incidence and prevalence of blast injuries associated with different combat roles.
- Few studies of incidence of blast-related injuries or outcomes associated with blast versus non-blast TBI report important characteristics of a blast injury: type of blast, how far the individual was from the blast, whether they experienced a blast wave, whether there was loss of consciousness or altered consciousness, whether there was amnesia (and length of time), and whether there was additional trauma.
- Only 6 studies, 3 of which were derived from the same data set, provide information about the incidence and prevalence of blast-related injuries in the deployed population at risk.
- Pain, vision loss, vestibular dysfunction, functional status, depression, sleep disturbance, alcohol misuse, and post-concussive symptoms were similar in groups of patients with blast and non-blast TBI. Findings were less consistent for PTSD, hearing loss, cognitive function, and headache. Few studies reported mortality, burn outcomes, limb loss, or quality of life.
- Reporting studies were often small and involved highly selected patients and thus may not be fully representative of all individuals with blast or non-blast TBI. There are little data on very long-term outcomes that may be particularly relevant to assessment of cognitive function and quality of life.
- Blast and blast injuries (including TBI) are often defined differently. Therefore, the incidence, prevalence, and patient outcomes may vary across studies in part due to differences in how blast injury is categorized.
- To more adequately address questions about consequences of blast exposure, future research efforts should focus on comprehensive and consistent documentation at the time of and following blast exposure and more complete analyses of databases that may have already captured blast exposure information.