# REFERENCES

1 Centers for Disease Control and Prevention (CDC). Explosion and Blast Injuries: A Primer for Clinicians. Available at: http://www.cdc.gov/masstrauma/preparedness/primer.pdf. Accessed August 24, 2015.
2 Department of Defense (DoD) Blast Injury Research Program. Defining Blast Injuries (DoDD 6026.21E). Available at: https://blastinjuryresearch.amedd.army.mil/index.cfm?f = application.introduction#blastInjury. Accessed August 24, 2015.
3 Cernak I, Noble-Haeusslein LJ. Traumatic brain injury: an overview of pathobiology with emphasis on military populations. J Cereb Blood Flow Metab. 2010;30(2):255-266.19809467
4 Howe LL. Giving context to post-deployment post-concussive-like symptoms: blast-related potential mild traumatic brain injury and comorbidities. Clin Neuropsychol. 2009;23(8):1315-1337.19882474
5 Wolf W, Beharta VS, B onnett CJ, Pons PT, Cantrill SV. Blast injuries. Lancet. 2009;374:405-415.19631372
6 Belmont PJ, Jr., Goodman GP, Zacchilli M, Posner M, Evans C, Owens BD. Incidence and epidemiology of combat injuries sustained during “the surge” portion of Operation Iraqi Freedom by a U.S. Army Brigade Combat Team. J Trauma. 2010;68:204-210.20065776
7 Belmont PJ, Jr., McCriskin BJ, Hsiao MS, Burks R, Nelson KJ, Schoenfeld AJ. The nature and incidence of musculoskeletal combat wounds in Iraq and Afghanistan (2005-2009). J Orthop Trauma. 2013;27(5):e107-113.23187153
8 Belmont PJ, Jr., McCriskin BJ, Sieg RN, Burks R, Schoenfeld AJ. Combat wounds in Iraq and Afghanistan from 2005 to 2009. J Trauma Acute Care Surg. 2012;73(1):3-12.22743366
9 Schoenfeld AJ, Laughlin MD, McCriskin BJ, Bader JO, Waterman BR, Belmont PJ, Jr. Spinal injuries in United States military personnel deployed to Iraq and Afghanistan. Spine. 2013;38:1770-1778.23759821
10 Freedman BA, Serrano JA, Belmont PJ, Jr., . The combat burst fracture study--results of a cohort analysis of the most prevalent combat specific mechanism of major thoracolumbar spinal injury. Arch Orthop Trauma Surg. 2014;134(10):1353-1359.25107602
11 Goldberg MS. Updated death and injury rates of U.S. military personnel during the conflicts in Iraq and Afghanistan. Congressional Budget Office Working Paper 2014-08. Washington, DC: 2014.
12 National Institute of Mental Health. What is Prevalence? http://www.nimh.nih.gov/health/statistics/prevalence/index.shtml. Accessed September 10, 2015.
13 DuBose JJ, Barmparas G, Inaba K, . Isolated severe traumatic brain injuries sustained during combat operations: demographics, mortality outcomes, and lessons to be learned from contrasts to civilian counterparts. J Trauma. 2011;70(1):11-16.21217475
14 Lew HL, Pogoda TK, Baker E, . Prevalence of dual sensory impairment and its association with traumatic brain injury and blast exposure in OEF/OIF veterans. J Head Trauma Rehabil. 2011;26(6):489-496.21386715
15 Akin FW, Murnane OD. Head injury and blast exposure: vestibular consequences. Otolaryngol. Clin. North Am. 2011;44(2):323-334.21474007
16 Kennedy JE, Leal FO, Lewis JD, Cullen MA, Amador RR. Posttraumatic stress symptoms in OIF/OEF service members with blast-related and non-blast-related mild TBI. NeuroRehabilitation. 2010;26(3):223-231.20448312
17 Luethcke CA, Bryan CJ, Morrow CE, Isler WC. Comparison of concussive symptoms, cognitive performance, and psychological symptoms between acute blast-versus nonblast-induced mild traumatic brain injury. J Int Neuropsychol Soc. 2011;17(1):36-45.21083963
18 Mac Donald CL, Johnson AM, Wierzechowski L, . Prospectively assessed clinical outcomes in concussive blast vs nonblast traumatic brain injury among evacuated US military personnel. JAMA Neurology. 2014;71(8):994-1002.24934200
19 Wojcik BE, Stein CR, Bagg K, Humphrey RJ, Orosco J. Traumatic brain injury hospitalizations of U.S. Army soldiers deployed to Afghanistan and Iraq. Am J Prev Med. 2010;38(S1):S108-S116.20117583
20 MacGregor AJ, Dougherty AL, Galarneau MR. Injury-specific correlates of combat-related traumatic brain injury in Operation Iraqi Freedom. J Head Trauma Rehabil. 2011;26(4):312-318.20808241
21 Wilk JE, Thomas JL, McGurk DM, Riviere LA, Castro CA, Hoge CW. Mild traumatic brain injury (concussion) during combat: lack of association of blast mechanism with persistent postconcussive symptoms. J Head Trauma Rehabil. 2010;25(1):9-14.20051900
22 Kontos AP, Kotwal RS, Elbin RJ, . Residual effects of combat-related mild traumatic brain injury. J Neurotrauma. 2013;30(8):680-686.23031200
23 Schneiderman AI, Braver ER, Kang HK. Understanding sequelae of injury mechanisms and mild traumatic brain injury incurred during the conflicts in Iraq and Afghanistan: persistent postconcussive symptoms and posttraumatic stress disorder. Am J Epidemiol. 2008;167(12):1446-1452.18424429
24 Xydakis MS, Ling GS, Mulligan LP, Olsen CH, Dorlac WC. Epidemiologic aspects of traumatic brain injury in acute combat casualties at a major military medical center: a cohort study. Ann Neurol. 2012;72(5):673-681.23060246
25 French LM, Lange RT, Marshall K, . Influence of the severity and location of bodily injuries on post-concussive and combat stress symptom reporting after military-related concurrent mild traumatic brain injuries and polytrauma. J Neurotrauma. 2014;31(19):1607-1616.24831890
26 Belanger HG, Kretzmer T, Yoash-Gantz R, Pickett T, Tupler L. Cognitive sequelae of blast-related versus other mechanisms of brain trauma. J Int Neuropsyhchol Soc. 2009;15:1-8.
27 Belanger HG, Proctor-Weber Z, Kretzmer T, Kim M, French LM, Vanderploeg RD. Symptom complaints following reports of blast versus non-blast mild TBI: does mechanism of injury matter? Clin Neuropsychol. 2011;25(5):702-715.21512958
28 Brahm KD, Wilgenburg HM, Kirby J, Ingalla S, Chang CY, Goodrich GL. Visual impairment and dysfunction in combat-injured servicemembers with traumatic brain injury. Optom Vis Sci. 2009;86(7):817-825.19521270
29 Clark ME, Walker RL, Gironda RJ, Scholten JD. Comparison of pain and emotional symptoms in soldiers with polytrauma: unique aspects of blast exposure. Pain Med. 2009;10:447-455.19416436
30 Cockerham GC, Lemke S, Glynn-Milley C, Zumhagen L, Cockerham KP. Visual performance and the ocular surface in traumatic brain injury. Ocul Surf. 2013;11(1):25-34.23321357
31 Collen J, Orr N, Lettieri CJ, Carter K, Holley AB. Sleep disturbances among soldiers with combat-related traumatic brain injury. Chest. 2012;142(3):622-630.22459784
32 Cooper DB, Chau PM, Armistead-Jehle P, Vanderploeg RD, Bowles AO. Relationship between mechanism of injury and neurocognitive functioning in OEF/OIF service members with mild traumatic brain injuries. Mil Med. 2012;177(10):1157-1160.23113441
33 Fortier CB, Amick MM, Grande L, . The Boston Assessment of Traumatic Brain Injury-Lifetime (BAT-L) semistructured interview: evidence of research utility and validity. J Head Trauma Rehabil. 2014;29(1):89-98.23535389
34 Goodrich GL, Flyg HM, Kirby JE, Chang CY, Martinsen GL. Mechanisms of TBI and visual consequences in military and veteran populations. Optom Vis Sci. 2013;90(2):105-112.23314131
35 Goodrich GL, Martinsen GL, Flyg HM, Kirby J, Garvert SW, Tyler CW. Visual function, traumatic brain injury, and posttraumatic stress disorder. J Rehabil Res Dev. 2014;51:547-558.25144168
36 Hoffer ME, Donaldson C, Gottshall KR, Balaban C, Balough BJ. Blunt and blast head trauma: different entities. Int Tinnitus J. 2009;15(2):115-118.20420334
37 Lange RT, Pancholi S, Brickell TA, . Neuropsychological outcome from blast versus non-blast: mild traumatic brain injury in U.S. military service members. J Int Neuropsychol Soc. 2012;18(3):595-605.22459022
38 Lew HL, Jerger JF, Guillory SB, Henry JA. Auditory dysfunction in traumatic brain injury. J Rehabil Res Dev. 2007;44(7):921-928.18075949
39 Lippa SM, Pastorek NJ, Benge JF, Thornton GM. Postconcussive symptoms after blast and nonblast-related mild traumatic brain injuries in Afghanistan and Iraq war veterans. J Int Neuropsychol Soc. 2010;16(5):856-866.20682086
40 Maguen S, Madden E, Lau KM, Seal K. The impact of head injury mechanism on mental health symptoms in veterans: do number and type of exposures matter? J Trauma Stress. 2012;25(1):3-9.22354503
41 Mendez MF, Owens EM, Jimenez EE, Peppers D, Licht EA. Changes in personality after mild traumatic brain injury from primary blast vs. blunt forces. Brain Injury. 2013;27(1):10-18.23252434
42 Mendez MF, Owens EM, Reza Berenji G, Peppers DC, Liang LJ, Licht EA. Mild traumatic brain injury from primary blast vs. blunt forces: post-concussion consequences and functional neuroimaging. NeuroRehabilitation. 2013;32(2):397-407.23535805
43 Mora AG, Ritenour AE, Wade CE, Holcomb JB, Blackbourne LH, Gaylord KM. Posttraumatic stress disorder in combat casualties with burns sustaining primary blast and concussive injuries. J Trauma. 2009;66(4 Suppl):S178-185.19359963
44 Nakase-Richardson R, McNamee S, Howe LL, . Descriptive characteristics and rehabilitation outcomes in active duty military personnel and veterans with disorders of consciousness with combat- and noncombat-related brain injury. Arch Phys Med Rehabil. 2013;94(10):1861-1869.23810353
45 Oleksiak M, Smith BM, St Andre JR, Caughlan CM, Steiner M. Audiological issues and hearing loss among Veterans with mild traumatic brain injury. J Rehabil Res Dev. 2012;49(7):995-1004.23341275
46 Pogoda TK, Hendricks AM, Iverson KM, . Multisensory impairment reported by veterans with and without mild traumatic brain injury history. J Rehabil Res Dev. 2012;49(7):971-984.23341273
47 Reid MW, Miller KJ, Lange RT, . A multisite study of the relationships between blast exposures and symptom reporting in a post-deployment active duty military population with mild traumatic brain injury. J Neurotrauma. Dec 1 2014;31(23):1899-1906.25036531
48 Sayer NA, Chiros CE, Sigford B, . Characteristics and rehabilitation outcomes among patients with blast and other injuries sustained during the Global War on Terror. Arch Phys Med Rehabil. 2008;89(1):163-170.18164349
49 Heltemes KJ, Dougherty AL, MacGregor AJ, Galarneau MR. Inpatient hospitalizations of U.S. military personnel medically evacuated from Iraq and Afghanistan with combat-related traumatic brain injury. Mil Med. Feb 2011;176(2):132-135.21366072
50 Ivey KM, White CE, Wallum TE, al. e. Thoracic injuries in US combat casualties: a 10-year review of Operation Enduring Freedom and Iraqi Freedom. J Trauma Acute Care Surg. 2012;73:S514-S519.23192079
51 Chan RK, Siller-Jackson A, Verrett AJ, Wu J, Hale RG. Ten years of war: a characterization of craniomaxillofacial injuries incurred during operations Enduring Freedom and Iraqi Freedom. J Trauma Acute Care Surg. 2012;73(6 Suppl 5):S453-458.23192069
52 Blair JA, Patzkowski JC, Schoenfeld AJ, al. e. Spinal column injuries among Americans in the Global War on Terrorism. J Bone Joint Surg Am. 2012;94:e136(131-139).22992884
53 Thach AB, Johnson AJ, Carroll RB, al. e. Severe eye injuries in the war in Iraq, 2003-2005. Ophthalmology. 2008;115:377-382.17904224
54 Glasgow S, Steele SR, Duncan JE, Rasmussen TE. Epidemiology of modern battlefield colorectal trauma: a review of 977 coalition casualties. J Trauma Acute Care Surg. 2012;73:S503-S508.23192077
55 Shah A, Syala M, Capra G, Fox D, Hoffer M. Otologic assessment of blast and non-blast injujry in returning Middle East-deployed service members. Laryngoscope. 2014;124:272-277.23686673
56 Fleming M, Waterman S, Dunne J, D'Alleyrand J-C, Andersen RC. Dismounted complex blast injuries; patterns of injuries and resource utilization associated with the multiple extremity amputee. J Surg Orthop Adv. 2012;21:32-37.22381508
57 Hoencamp R, Vermetten E, Tan EC, Putter H, Leenen LP, Hamming JF. Systematic review of the prevalence and characteristics of battle casualties from NATO coalition forces in Iraq and Afghanistan. Injury. 2014;45(7):1028-1034.24878294
58 Elder GA, Cristian A. Blast-related mild traumatic brain injury: mechanisms of injury and impact on clinical care. Mt Sinai J Med. 2009;76(111-118).
59 Surveillance snapshot: Responses to the traumatic brain injury (TBI) screening questions on the 2012 version of the post-deployment health assessment (DD Form 2796). MSMR. 2015;22(2):12-13.
60 St. Onge P, McIlwain DS, Hill ME, Walilko TJ, Bardolf LB. Marine Corps breacher training study: auditory and vestibular findings. US Army Med Dep J. 2011:97-107.21805461
61 Capo-Aponte JE, Jurek GM, Walsh DV, Temme LA, Ahroon WA, Riggs DW. Effects of repetitive low-level blast exposure on visual system and ocular structures. J Rehabil Res Dev. 2015;52(3):273-290.26237153
62 Tate CM, Wang KKW, Eonta S, . Serum brain biomarker level, neurocognitive performance, and self-reported symptoms changes in soldiers repeatedly exposed to low-level blast: a breacher pilot study. J Neurotrauma. 2013;30:1620-1630.23687938
63 Baker AJ, Topolovec-Vranic J, Michalak A, . Controlled blast exposure during forced explosive entry training and mild traumatic brain injury. J Trauma. 2011;71:S472-S477.22072006
64 Holcomb JB, Stansbury LG, Champion HR, Wade C, Bellamy RF. Understanding combat casualty care statistics. J Trauma. 2006;60(2):397-401.16508502
65 Regasa LE, Thomas DM, Gill RS, Marion DW, Ivins BJ. Military Deployment May Increase the Risk for Traumatic Brain Injury Following Deployment. J Head Trauma Rehabil. 2016;31(1):E28-35.26098261
66 DePalma RG Combat TBI: History, Epidemiology, and Injury Modes. In: Kobeissy FH, ed. Brain Neurotrauma: Molecular, Neuropsychological, and Rehabilitation Aspects. Boca Raton (FL): CRC Press/Taylor & Francis; 2015.
67 Scholten JD, Sayer NA, Vanderploeg RD, Bidelspach DE, Cifu DX. Analysis of US Veterans Health Administration comprehensive evaluations for traumatic brain injury in Operation Enduring Freedom and Operation Iraqi Freedom Veterans. Brain Inj. 2012;26(10):1177-1184.22646489
68 Institute of Medicine. Gulf War and Health, Volume 9: Long-term Effects of Blast Exposures. Washington, DC: The National Academies Press; 2014.