# METHODS

## TOPIC DEVELOPMENT

This topic was nominated by Ralph DePalma, MD, Special Operations Office, Office of Research and Development. Additional stakeholders included: David Cifu, MD, Chair, VHA TBI Advisory Committee; Stuart Hoffman, PhD, Scientific Program Manager for Brain Injury, Rehabilitation Research and Development Service; and Col. Todd Rasmussen, MD, Director, Combat Casualty Care Research Program, US Army Medical Research and Materiel Command. Information on the incidence and prevalence of combat blast injuries and the outcomes of blast-related and non-blast TBI may be used to allocate research funding appropriately to improve care for Veterans with blast injuries and/or TBIs.

## SEARCH STRATEGY

We searched MEDLINE (Ovid) for articles published in English from 2000 through April 2015 using separate search strategies for Key Questions 1 and 2 and Key Question 3. Our searches were designed to identify studies of combat injuries in US military personnel during OEF, OIF, and OND. The searches included the MeSH terms Brain Injuries; Wounds, Nonpenetrating; Wounds, Penetrating; Afghan Campaign 2001-; Iraq War, 2003-2011; and Military Personnel. The full search strategies are presented in Appendix A. We obtained additional articles by hand-searching the table of contents of Journal of Trauma-Injury Infection & Critical Care and reference lists of systematic reviews and other reports, and from references suggested by the topic stakeholders and TEP members.

## STUDY SELECTION

Abstracts from the MEDLINE searches were reviewed in duplicate by investigators and research associates and abstracts from the table of contents search were reviewed by a single investigator. We identified for full-text review studies of any design potentially relevant to the key questions. Two investigators or research associates independently reviewed full-text articles excluding the following:

- Studies not including US military personnel from OEF, OIF, or OND (2000-2014);
- Studies not involving combat injuries;
- Modeling studies (eg, mechanical/engineering models, animal studies);
- Studies not relevant to the key questions;
- Studies of treatment outcomes;
- Imaging studies or studies reporting changes in tissue (eg, white matter);
- Case reports;
- Studies for Key Questions 1 and 2 where the denominator was not the number deployed during the study period (ie, reports of injuries at a medical facility were excluded); and
- Studies for Key Question 3 that did not report outcomes of interest for blast-related TBI and non-blast TBI groups (ie, studies only reporting on blast-related TBI were excluded).

## DATA ABSTRACTION

For Key Questions 1 and 2, study characteristics (data source, inclusion/exclusion criteria, cohort characteristics) and outcomes (blast injury incidence, blast injury prevalence) were extracted into evidence tables by one investigator or research associate and verified by another. For Key Question 3, study characteristics (data source, inclusion exclusion criteria, cohort characteristics, outcome measures used) and outcomes (mortality, pain, burns, limb loss, vision loss, hearing loss, vestibular dysfunction, PTSD, cognitive function, quality of life, functional status/employment, other) for blast-related TBI and non-blast TBI patients were extracted into evidence tables by one investigator or research associate and verified by another.

## RISK OF BIAS ASSESSMENT

We did not assess the risk of bias of the included studies, although risk of bias for each study was likely moderate or high due to the study design used, selective population studied, and failure to control for potential confounding factors.

## DATA SYNTHESIS

We created summary tables with incidence and prevalence results (Key Questions 1 and 2). We organized evidence tables for Key Question 3 by outcome and time since exposure (<30 days, 30 days to 1 year, >1 year, or not specified). Pooled analyses were not possible due to heterogeneity of the study populations and outcome measures.

## RATING THE BODY OF EVIDENCE

We did not formally rate the overall strength of evidence for outcomes. The typical approach to assessing strength of evidence considers consistency, precision, directness, and risk of bias of the included studies. However, because included studies were observational and there was limited reporting of outcomes of interest (ie, most outcomes reported in only a few studies and often using different measures), it is unlikely that strength of evidence would be anything above low. Many outcomes had insufficient evidence.

## PEER REVIEW

A draft version of this report was reviewed by content experts as well as clinical leadership. Reviewer's comments and our responses are presented in Appendix B and the report was modified as needed.