# APPENDIX B PEER REVIEWER COMMENTS AND RESPONSES

| Reviewer Comment | Response
Are the objectives, scope, and methods for this review clearly described? | Yes
Are the objectives, scope, and methods for this review clearly described? | Yes
Are the objectives, scope, and methods for this review clearly described? | Yes
Are the objectives, scope, and methods for this review clearly described? | Yes
Are the objectives, scope, and methods for this review clearly described? | Yes
Are the objectives, scope, and methods for this review clearly described? | No - The questions were too broad. In light of the lack of detail in reporting, we should have picked one or two types of injury common to blast. In addition, failure to answer the first two questions indicates a problem with the process of reporting. | We sought input from Operational Partners and Technical Expert Panels to guide the report development.
Is there any indication of bias in our synthesis of the evidence? | No
Is there any indication of bias in our synthesis of the evidence? | No
Is there any indication of bias in our synthesis of the evidence? | No
Is there any indication of bias in our synthesis of the evidence? | No
Is there any indication of bias in our synthesis of the evidence? | No
Is there any indication of bias in our synthesis of the evidence? | No
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | Yes - Consider including the following article for DoD TBI incidence/denominator sample data: Regasa, et.al. (2015, JHTR ahead of pub) “Military Deployment May Increase the Risk for TBI Following Deployment”. Posted under Reviewer attachments for your consideration. | We have included this article in the Discussion section. Although it includes a large sample, it is not truly an incidence report given that some service members were excluded. Furthermore, there was inadequate data for the authors to comment on causes of injury.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | Yes - Noted within the comments but there are unpublished, classified studies that we do not mention and it appears that no attempts were made to obtain data from JTAPIC. | Classified studies would be out of scope. We looked at the military injury database sites for posted reports.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | Yes - Not sure if these were reviewed, but there is limited mention of VA data related to the TBI screening and evaluation process. There are questions specific to blast in both the screen and evaluation template. Studies with this data may not have been strong enough to include, but it would appear to be an area for possible expanded use in the future. | We have added information about the VA TBI screening and evaluation process including the findings of Scholten et al.(2012). We did not find other reports of findings related to the VA protocol. We have noted in the Future Research section that additional analyses of existing databases are needed.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | Yes - The data from VA re incidence/prevalence for key questions 1 and 2: Scholten JD,Sayer NA et al: Analysis of US Veterans Health Administration for Traumatic Brain Injury...Brain Injury ISSN: 0269 = 9052; DePalma RG Combat TBI: History, Epidemiology, and Injury Modes. DePalma RG.In:Kobeissy FH, editor: Brain Neurotrauma: Molecular, Neuropsychological, and Rehabilitation Aspects. Boca Raton (FL): CRC Press/Taylor & Francis; 2015. Chapter 2. Frontiers in Neuroengineering | We have reviewed the suggested references and have included them in the Applicability section. We have noted that most studies do not include a denominator that allows determination of true incidence or prevalence.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | Yes - MSMR was not cited, a major resource of traumatic injuries due to blast. VA TBI Screen and Comprehensive Eval publications were not cited. | We searched the contents of MSMR for relevant publications and have added the Surveillance Snapshot from the February 2015 edition. Other reports either did not distinguish blast-related injuries (combining gun and explosive events), included all service members (not limited to OEF/OIF/OND), or did not provide an appropriate denominator.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | Thank you for an excellent and very focused review. It is unfortunate that after so many years of research, we continue to find there is little known about a variety of TBI-related issues. The root cause of many of our lingering questions stems from our shortcomings in diagnostic accuracy, among other limitations of existing data. We have a growing expertise treating symptoms associated with TBI, but without objective diagnostic criteria and without adequately controlled, comparative studies the best outcomes may elude us. In addition to the DoDTR and MTR (which likely contain the best blast data), data from the Armed Forces Health Surveillance Center (AFHSC) may be the most comprehensive for (first) TBI incident reporting (see 2015 article attached). Editing comments: 1) Page 34 - Cognitive Function / Other, review of Clark 2009 was not easy to read/follow. The sentence seems broken. 2) Page 40 - vestibular EFFECTS (not affects) | We have added information about limitations of the existing data in the Discussion section. We have cited the Regassa 2015 reference. As noted above, we have checked military injury database sites for posted reports. Editing: 1) we have revised this sentence 2) we have made the suggested change
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | p. 7, line 22 - citation to Cernak or Okie related to definition of injury would be best here p. 11, line 15 - are we certain that there is no study related to amputation due to blast injury -is this included in extremity injury. I think amputation is considered differently than musculoskeletal injury p. 14, line 33 - I would refer to this as musculoskeletal injury and again would clarify if this is extremity trauma vs. orthopedic injury (fracture/soft tissue) p. 14, line 53 - I believe there are citations related to burn related to explosion 1: Escolas SM, Archuleta DJ, Orman JA, Chung KK, Renz EM. Postdischarge Cause-of-Death Analysis of Combat-Related Burn Patients. J Burn Care Res. 2015 Dec 1. [Epub ahead of print] PubMed PMID: 26629656. 2: Barillo DJ, Pozza M, Margaret-Brandt M. A literature review of the military uses of silver-nylon dressings with emphasis on wartime operations. Burns. 2014 Dec;40 Suppl 1:S24-9. doi: 10.1016/j.burns.2014.09.017. Review. PubMed PMID: 25418434. 3: Valerio IL, Sabino J, Mundinger GS, Kumar A. From battleside to stateside: the reconstructive journey of our wounded warriors. Ann Plast Surg. 2014 May;72 Suppl 1:S38-45. doi: 10.1097/SAP.0000000000000168. PubMed PMID: 24740023. 4: Jeevaratnam JA, Pandya AN. One year of burns at a role 3 Medical Treatment Facility in Afghanistan. J R Army Med Corps. 2014 Mar;160(1):22-6. doi: 10.1136/jramc-2013-000100. Epub 2013 Jun 7. PubMed PMID: 24109100. 5: Feldt BA, Salinas NL, Rasmussen TE, Brennan J. The joint facial and invasive neck trauma (J-FAINT) project, Iraq and Afghanistan 2003-2011. Otolaryngol Head Neck Surg. 2013 Mar;148(3):403-8. doi: 10.1177/0194599812472874. Epub 2013 Jan 11. PubMed PMID: 23314163. 6: Chan RK, Siller-Jackson A, Verrett AJ, Wu J, Hale RG. Ten years of war: a characterization of craniomaxillofacial injuries incurred during operations Enduring Freedom and Iraqi Freedom. J Trauma Acute Care Surg. 2012 Dec;73(6 Suppl 5):S453-8. doi: 10.1097/TA.0b013e3182754868. PubMed PMID: 23192069. 7: Mora AG, Ritenour AE, Wade CE, Holcomb JB, Blackbourne LH, Gaylord KM. Posttraumatic stress disorder in combat casualties with burns sustaining primary blast and concussive injuries. J Trauma. 2009 Apr;66(4 Suppl):S178-85. doi: 10.1097/TA.0b013e31819ce2d6. PubMed PMID: 19359963. 8: Gaylord KM, Cooper DB, Mercado JM, Kennedy JE, Yoder LH, Holcomb JB. Incidence of posttraumatic stress disorder and mild traumatic brain injury in burned service members: preliminary report. J Trauma. 2008 Feb;64(2 Suppl):S200-5; discussion S205-6. doi: 10.1097/TA.0b013e318160ba42. PubMed PMID: 18376167. p. 17, line 26 - again would reference Okie or Cernak p. 26, line 14 - Did they include deployed population at time as the denominator? Should that be reported for consistency p. 26, line 23 - suggest overall number be reported p. 28, line 30 - this happens multiple times in the document, after this point, the period and the parentheses seem misaligned and are done inconsistently - some with period before, some after; other formatting problems with spacing should also be checked, noted this throughout the document. p. 35, line 8 - s missing from patients p. 45, line 35 - usually referred to as musculoskeletal injury and unclear if this includes SCI p. 46, line 6 - change contraction don't to do not p. 46, line 50 - was any attempt made to request data or technical reports from JTAPIC or DVBIC for unpublished data? http://jtapic.amedd.army.mil/getStarted.php p. 47, line 21 - I think the caveat here is related to what is available in the published literature. There are unpublished data on the classified side that we know exist but to which we do not have access. p. 47, line 55 - this sentence is awkward and I cannot rewrite because I cannot understand what is meant by it. | p7/22. We have added the Cernak reference to the full report (we did not include references in the Executive Summary). p11/15. The report of musculoskeletal injuries included amputations. We have noted this in the Executive Summary and full report and have added data to the Appendix tables. p14/33. We have made this change and clarified the type of injury. p14/53. We have reviewed each of the suggested references. Two were already included (Chan, Mora) although Chan has now been removed because the denominator was not number deployed. We added a burn outcome reported by Mora to the outcomes for KQ3. None of the other references provided outcomes pertaining to the key questions. p17/26. We have added the Cernak reference. p26/14. The study this comment refers to has been deleted because it did not provide a suitable denominator. p26/23. The study this comment refers to has also been deleted because it did not provide a suitable denominator. p28/30. The inconsistency and spacing issues noted have been eliminated with the switch to superscript reference citations in the final version of the report. p35/8. We have made this correction. p45/35. We have made this change and clarified the type of injury included. p46/6. We have made this change. p46/50. We included only published data. As noted above, we looked at the military injury database sites for posted reports. p47//21. We have added “published” to this sentence. p47/55. We have revised this sentence.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | Applicability of Report page9 lines 9-18 references the 1,906 754 OEF/OIF/OND veterans becoming eligible for VA Care. It is known that ∼55% reported for VA care. All those screened for TBI; the numbers reporting, screened and completing TBI evaluation are also known. Currently these approach 80-90,000; with additional arriving with DOD diagnosed TBI 125-126,000(Bidelspach/Cifu). This is a partial denominator which needs to be taken into consideration, recognizing that we cannot extrapolate to those not reporting and seen. | There were many reports of “proportional” outcomes – the fraction of an exposed group (ie, those injured in combat)(Holcomb 2006) but we have defined incidence based on number deployed and included only studies that report incidence or prevalence for the deployed population. We have included information about the VA TBI evaluation program in the Applicability section of the report.