# APPENDIX A SEARCH STRATEGIES

## KEY QUESTIONS 1 AND 2

1. (operation enduring freedom or operation iraqi freedom or operation new dawn).mp.
2. (OEF or OIF or OND).mp.
3. exp Afghan Campaign 2001-/
4. exp Iraq War, 2003-2011/
5. 1 or 2 or 3 or 4
6. (blast$ and injur$).mp.
7. blast$.mp.
8. ep.fs.
9. incidence.mp.
10. prevalence.mp.
11. 8 or 9 or 10
12. 6 or 7
13. 5 and 11 and 12
14. military personnel.mp. or exp Military Personnel/
15. 5 or 14
16. blast injuries.mp. or exp Blast Injuries/
17. 6 or 7 or 16
18. 11 and 15 and 17
19. limit 18 to (english language and yr = “2001 -Current”)

## KEY QUESTION 3

1. brain injury.mp. or exp Brain Injuries/
2. exp Wounds, Nonpenetrating/
3. exp Wounds, Penetrating/
4. (blast or (non-blast or nonblast)).mp.
5. (traumatic brain injur$ or tbi).mp.
6. brain.mp.
7. exp Afghan Campaign 2001-/
8. exp Iraq War, 2003-2011/
9. (operation enduring freedom or operation iraqi freedom or operation new dawn).mp.
10. (OEF or OIF or OND).mp.
11. 7 or 8 or 9 or 10
12. 2 or 3 or 4
13. 1 or 5 or 6
14. 11 and 12 and 13
15. (military or combat or deploy$).mp.
16. 12 and 13 and 15
17. 14 or 16
18. limit 17 to (english language and yr = “2001 -Current”)
19. military personnel.mp. or exp Military Personnel/
20. (military or veteran$ or soldier$).mp.
21. 15 or 19 or 20
22. 12 and 13 and 21
23. 16 or 22
24. limit 23 to (english language and yr = “2001 -Current”)