# References

1. Colli A, Mestres CA, Castella M, Gherli T. Comparing warfarin to aspirin (WoA) after aortic valve replacement with the St. Jude Medical Epic heart valve bioprosthesis: results of the WoA Epic pilot trial. The Journal of heart valve disease. 2007;16(6):667-671.18095518
2. di Marco F, Grendene S, Feltrin G, Meneghetti D, Gerosa G. Antiplatelet therapy in patients receiving aortic bioprostheses: a report of clinical and instrumental safety. The Journal of thoracic and cardiovascular surgery. 2007;133(6):1597-1603.17532962
3. Rafiq S, Steinbruchel DA, Lilleor NB, . Antithrombotic therapy after bioprosthetic aortic valve implantation: Warfarin versus aspirin, a randomized controlled trial. Thrombosis research. 2017;150:104-110.27914653
4. Blair KL, Hatton AC, White WD, . Comparison of anticoagulation regimens after Carpentier-Edwards aortic or mitral valve replacement. Circulation. 1994;90(5 Pt 2):II214-219.7955256
5. Brennan JM, Edwards FH, Zhao Y, . Early anticoagulation of bioprosthetic aortic valves in older patients: results from the Society of Thoracic Surgeons Adult Cardiac Surgery National Database. Journal of the American College of Cardiology. 2012;60(11):971-977.22921973
6. Colli A, Verhoye J-P, Heijmen R, Antunes M, Investigators A. Low-dose acetyl salicylic acid versus oral anticoagulation after bioprosthetic aortic valve replacement. Final report of the ACTION registry. International journal of cardiology. 2013;168(2):1229-1236.23237759
7. Gherli T, Colli A, Fragnito C, . Comparing warfarin with aspirin after biological aortic valve replacement: a prospective study. Circulation. 2004;110(5):496-500.15289387
8. Mistiaen W, Van Cauwelaert P, Muylaert P, Sys SU, Harrisson F, Bortier H. Thromboembolic events after aortic valve replacement in elderly patients with a Carpentier-Edwards Perimount pericardial bioprosthesis. The Journal of thoracic and cardiovascular surgery. 2004;127(4):1166-1170.15052218
9. Lee SI, Lee KS, Kim JB, . Early Antithrombotic Therapy after Bioprosthetic Aortic Valve Replacement in Elderly Patients: A Single-Center Experience. Annals of thoracic and cardiovascular surgery : official journal of the Association of Thoracic and Cardiovascular Surgeons of Asia. 2017.
10. van der Wall SJ, Umans VAWM, Schotten J, . Antithrombotic strategy after bioprosthetic aortic valve replacement in patients in sinus rhythm: evaluation of guideline implementation. European journal of cardio-thoracic surgery : official journal of the European Association for Cardio-thoracic Surgery. 2016;49(4):1157-1163.26233944
11. Al-Atassi T, Lam K, Forgie M, . Cerebral microembolization after bioprosthetic aortic valve replacement: comparison of warfarin plus aspirin versus aspirin only. Circulation. 2012;126(11 Suppl 1):S239-244.22965989
12. Jamieson WRE, Moffatt-Bruce SD, Skarsgard P, . Early antithrombotic therapy for aortic valve bioprostheses: is there an indication for routine use? The Annals of thoracic surgery. 2007;83(2):549-547.17257986
13. Lytle BW, Cosgrove DM, Goormastic M, Loop FD. Aortic valve replacement and coronary bypass grafting for patients with aortic stenosis and coronary artery disease: early and late results. European heart journal. 1988;9 Suppl E:143-147.3261241
14. Aramendi JI, Mestres C-A, Mestres C-A, . Triflusal versus oral anticoagulation for primary prevention of thromboembolism after bioprosthetic valve replacement (trac): prospective, randomized, co-operative trial. European journal of cardio-thoracic surgery : official journal of the European Association for Cardio-thoracic Surgery. 2005;27(5):854-860.15848326
15. Rodes-Cabau J, Masson J-B, Welsh RC, . Aspirin Versus Aspirin Plus Clopidogrel as Antithrombotic Treatment Following Transcatheter Aortic Valve Replacement With a Balloon-Expandable Valve: The ARTE (Aspirin Versus Aspirin + Clopidogrel Following Transcatheter Aortic Valve Implantation) Randomized Clinical Trial. JACC Cardiovascular interventions. 2017.
16. Stabile E, Pucciarelli A, Cota L, . SAT-TAVI (single antiplatelet therapy for TAVI) study: a pilot randomized study comparing double to single antiplatelet therapy for transcatheter aortic valve implantation. International journal of cardiology. 2014;174(3):624-627.24809922
17. Ussia GP, Scarabelli M, Mule M, . Dual antiplatelet therapy versus aspirin alone in patients undergoing transcatheter aortic valve implantation. The American journal of cardiology. 2011;108(12):1772-1776.21907949
18. Ichibori Y, Mizote I, Maeda K, . Clinical Outcomes and Bioprosthetic Valve Function After Transcatheter Aortic Valve Implantation Under Dual Antiplatelet Therapy vs. Aspirin Alone. Circulation journal : official journal of the Japanese Circulation Society. 2017;81(3):397-404.28123149
19. Durand E, Blanchard D, Chassaing S, . Comparison of 2 antiplatelet therapy strategies in patients undergoing transcatheter aortic valve implantation. Am J Cardiol. 2014;113(2):355-360.24169016
20. Holy EW, Kebernik J, Allali A, El-Mawardy M, Richardt G, Abdel-Wahab M. Comparison of dual antiplatelet therapy versus oral anticoagulation following transcatheter aortic valve replacement: A retrospective single-center registry analysis. Cardiology journal. 2017.
21. Abdul-Jawad Altisent O, Durand E, Muñoz-García AJ, . Warfarin and Antiplatelet Therapy Versus Warfarin Alone for Treating Patients With Atrial Fibrillation Undergoing Transcatheter Aortic Valve Replacement. JACC: Cardiovascular Interventions. 2016;9(16):1706-1717.27539691
22. Seeger J, Gonska B, Rodewald C, Rottbauer W, Wohrle J. Apixaban in Patients With Atrial Fibrillation After Transfemoral Aortic Valve Replacement. JACC Cardiovascular interventions. 2017;10(1):66-74.27916486
23. Barreto-Filho JA, Wang Y, Dodson JA, . Trends in aortic valve replacement for elderly patients in the United States, 1999-2011. Jama. 2013;310(19):2078-2085.24240935
24. Rahimtoola SH. Choice of prosthetic heart valve in adults an update. Journal of the American College of Cardiology. 2010;55(22):2413-2426.20510209
25. Whitlock RP, Sun JC, Fremes SE, Rubens FD, Teoh KH, American College of Chest P. Antithrombotic and thrombolytic therapy for valvular disease: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. 2012;141(2 Suppl):e576S-600S.22315272
26. Heras M, Chesebro JH, Fuster V, . High risk of thromboemboli early after bioprosthetic cardiac valve replacement. Journal of the American College of Cardiology. 1995;25(5):1111-1119.7897124
27. Roudaut R, Serri K, Lafitte S. Thrombosis of prosthetic heart valves: diagnosis and therapeutic considerations. Heart. 2007;93(1):137-142.17170355
28. Cohn LH, Mudge GH, Pratter F, Collins JJ, Jr. Five to eight-year follow-up of patients undergoing porcine heart-valve replacement. The New England journal of medicine. 1981;304(5):258-262.7442757
29. Colli A, Verhoye J-P, Heijmen R, . Antithrombotic therapy after bioprosthetic aortic valve replacement: ACTION Registry survey results. European journal of cardio-thoracic surgery : official journal of the European Association for Cardio-thoracic Surgery. 2008;33(4):531-536.18203613
30. Nishimura RA, Otto CM, Bonow RO, . 2017 AHA/ACC Focused Update of the 2014 AHA/ACC Guideline for the Management of Patients With Valvular Heart Disease: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. J Am Coll Cardiol. 2017;70(2):252-289.28315732
31. Nishimura RA, Otto CM, Bonow RO, . 2014 AHA/ACC guideline for the management of patients with valvular heart disease: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. Journal of the American College of Cardiology. 2014;63(22):e57-185.24603191
32. Vahanian A, Alfieri O, Andreotti F, . Guidelines on the management of valvular heart disease (version 2012). European Heart Journal. 2012;33(19):2451-2496.22922415
33. Leon MB, Smith CR, Mack M, . Transcatheter aortic-valve implantation for aortic stenosis in patients who cannot undergo surgery. N Engl J Med. 2010;363(17):1597-1607.20961243
34. Kodali SK, Williams MR, Smith CR, . Two-year outcomes after transcatheter or surgical aortic-valve replacement. The New England journal of medicine. 2012;366(18):1686-1695.22443479
35. Renda G, Ricci F, Giugliano RP, De Caterina R. Non-Vitamin K Antagonist Oral Anticoagulants in Patients With Atrial Fibrillation and Valvular Heart Disease. J Am Coll Cardiol. 2017;69(11):1363-1371.28302287
36. Papak J, Kansagara D, Noelck N, . Comparing antithrombotic strategies after bioprosthetic aortic valve replacement: a systematic review. PROSPERO 2017:CRD42017057064 Available from http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=CRD42017057064
37. Wallace BC, Small K, Brodley CE, Lau J, Trikalinos TA. Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. Proceedings of the 2nd ACM SIGHIT International Health Informatics Symposium (IHI). 2012:819-824.
38. Higgins J, Green S (editors). Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0 [updated March 2011]. Chapter 8: Assessing risk of bias in included studies. The Cochrane Collaboration, 2011. Accessed at www.handbook.cochrane.org on January 16, 2017. 2011.
39. Wells GA, Shea B, O’Connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomized studies in meta-analyses. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed January 11, 2016.
40. Viswanathan M, Ansari M, Berkman N, . Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions Agency for Healthcare Research and Quality Methods Guide for Comparative Effectiveness Reviews. March 2012. AHRQ Publication No. 12-EHC047-EF. Available at: www.effectivehealthcare.ahrq.gov/. Rockville, MD: Agency for Healthcare Research and Quality; Methods Guide for Comparative Effectiveness Reviews (AHRQ Publication No. 12-EHC047-EF);2012.
41. Berkman N, Lohr K, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Rockville, MD: Agency for Healthcare Research and Quality; Methods Guide for Comparative Effectiveness Reviews (AHRQ Publication No. 13(14)-EHC130-EF);2013.
42. Atkins D, Chang S, Gartlehner G, . Assessing the Applicability of Studies When Comparing Medical Interventions. Rockville, MD: Agency for Healthcare Research and Quality; Methods Guide for Comparative Effectiveness Reviews (AHRQ Publication No. 11-EHC019-EF);2011.
43. Merie C, Kober L, Skov Olsen P, . Association of warfarin therapy duration after bioprosthetic aortic valve replacement with risk of mortality, thromboembolic complications, and bleeding. JAMA. 2012;308(20):2118-2125.23188028
44. Dewilde WJ, Janssen PW, Verheugt FW, . Triple therapy for atrial fibrillation and percutaneous coronary intervention: a contemporary review. J Am Coll Cardiol. 2014;64(12):1270-1280.25236521
45. Poliacikova P, Cockburn J, de Belder A, Trivedi U, Hildick-Smith D. Antiplatelet and antithrombotic treatment after transcatheter aortic valve implantation - comparison of regimes. The Journal of invasive cardiology. 2013;25(10):544-548.24088430
46. Nijenhuis VJ, Bennaghmouch N, Hassell M, . Rationale and design of POPular-TAVI: antiPlatelet therapy fOr Patients undergoing Transcatheter Aortic Valve Implantation. American heart journal. 2016;173:77-85.26920599
47. Merie C, Kober L, Torp-Pedersen C. Warfarin treatment after bioprosthetic aortic valve replacement--reply. JAMA. 2013;309(12):1225-1226.
48. Egbe AC, Pislaru SV, Pellikka PA, . Bioprosthetic Valve Thrombosis Versus Structural Failure: Clinical and Echocardiographic Predictors. Journal of the American College of Cardiology. 2015;66(21):2285-2294.26610876
49. Holmes DR, MacK MJ, Kaul S, . 2012 ACCF/AATS/SCAI/STS expert consensus document on transcatheter aortic valve replacement. Journal of the American College of Cardiology. 2012;59(13):1200-1254.22300974
50. Webb J, Rodés-Cabau J, Fremes S, . Transcatheter Aortic Valve Implantation: A Canadian Cardiovascular Society Position Statement. Canadian Journal of Cardiology. 2012;28(5):520-528.22703948
51. Fann JI, Miller DC, Moore KA, . Twenty-year clinical experience with porcine bioprostheses. The Annals of thoracic surgery. 1996;62(5):1301-1302.8893561
52. Eichinger WB, Botzenhardt F, Gunzinger R, . European experience with the Mosaic bioprosthesis. The Journal of thoracic and cardiovascular surgery. 2002;124(2):333-339.12167794
53. Fradet GJ, Bleese N, Burgess J, Cartier PC. Mosaic valve international clinical trial: early performance results. The Annals of thoracic surgery. 2001;71(5 Suppl):S273-277.11388203
54. Anselmi A, Ruggieri VG, Lelong B, . Mid-term durability of the Trifecta bioprosthesis for aortic valve replacement. The Journal of thoracic and cardiovascular surgery. 2017;153(1):21-28.e21.27697360
55. Thomson DJ, Jamieson WR, Dumesnil JG, . Medtronic Mosaic porcine bioprosthesis: midterm investigational trial results. The Annals of thoracic surgery. 2001;71(5 Suppl):S269-272.11388202
56. Aupart MR, Mirza A, Meurisse YA, Sirinelli AL, Neville PH, Marchand MA. Perimount pericardial bioprosthesis for aortic calcified stenosis: 18-year experience with 1133 patients. The Journal of heart valve disease. 2006;15(6):768-766.17152784