# APPENDIX D Peer Reviewer Comments

Reviewer Number | Comment | Authors' response
Are the objectives, scope, and methods for this review clearly described?
2-6 | All responded, “Yes.” | Noted.
Is there any indication of bias in our synthesis of the evidence?
2-6 | All responded, “No.” | Noted.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
2-6 | All responded, “No.” | Noted.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
2 | N/A | Noted.
3 | 1-The methods do not mention the review period (years) of the published articles 2- I suspect that there might be studies published in the 1960's that might not have been included | We have clarified in the Methods that we searched all available years of publication from database inception (1946 for Ovid MEDLINE) through January 2017. Our initial search yield contained 48 publications published during 1964-1969.
4 | The authors present a thorough assessment of the literature regarding varying risk-benefit ratios of different antithrombotic strategies after bioprosthetic aortic valve replacement (bAVR; surgical or transcatheter). Their systematic search strategy included multiple data sources, a detailed algorithm of their inclusion/exclusion criteria for literature selection, including a consort diagram, and comprehensive tables outlining the details of the studies reviewed. Based on the literature reviewed, the investigators conclude that aspirin (ASA) and VitaminK antagonist administration after bAVR appear to show a similar risk profile with regard to mortality, bleeding and thromboembolism study. They note that the optimal anti-thrombotic strategy in other situations (eg, concomitant thrombotic conditions and procedures) is not clear as the evidence is very limited but that large scale studies in the transcatheter (TAVR) population are forthcoming. | Noted.
4 | Comments: The search presented by the authors is a comprehensive one which explores all aspects of bAVR including both surgical and transcatheter approaches, and the 2 of the most common accompanying clinical circumstances: concomitant ischemic heart and/or atrial fibrillation. The review illustrates the challenges is studying optimal anticoagulation strategies for the diverse and dynamic population of patients undergoing bAVR regardless of the approach. The review is well written and comprehensive. Comments/suggestions are only minor, as follow: | Noted.
4 | The rationale for not including the study by Merie and colleagues (ref 35) in the current analysis is clear; however, the AHA/ACC appears to have considered the findings of this study in their 2017 updated guidelines for pts with valve disease (it is reasonable to anticoagulate with a VKA for 3-6 months after valve replacement for patients at low risk for bleeding), the authors might consider including a little more information on this study than what is currently written (p 16, lines 33-38).
4 | In the Introduction section, the sentence, “Bioprosthetic valves carry a significant advantage over mechanical aortic valve replacement....” (p 3, line 11), as written, seems to imply that that bioprosthetic valves are preferable to mechanical valves. While it is not necessary to note that mechanical valves have a significant advantage over bioprosthetic valves in that they are at almost zero risk of structural deterioration, consider revising this sentence. | We agree and have clarified that there may be a lower need for long term anticoagulation with bioprosthetic valves.
4 | The sentence, “However, in the first 3 months after implantation....”(p. 3, line 15) may be slightly overstated since it these studies include prosthetic mitral valves which are known to have a higher risk of thromboembolism relative to valves in the aortic positions - eg, in the study by Heras et al, (ref 5) the thromboembolism rate from 11-90 days was comparatively higher for mitral valves as was stated in their conclusions. | We agree and have reworded the sentence to convey the risk as theoretical rather than established.
4 | Where possible, it might be helpful to distinguish between pre and postoperative AFib (e.g, on p. 23, lines 25 and 46; p 24, line 23, etc) or state that this information was not clarified in the reviewed study. In most of these cases, it appears that the afib was pre-existing although not clearly stated. Similarly, in reading the paragraph synopsis of the anticoagulation regimens in the study by Brannan and colleagues (p. 24, lines 22-42), the reader would likely wonder what percentages of preop Afib patients were in each of the anticoagulation arms (i.e., how many of the 49% ASA only patients had Afib, etc). Even though the authors imply that there were more Afib patients in the Warfarin/ASA group (p. 24, lines 33-35), more details might be appreciated. | We agree and have revised the summary of the Brennan 2012 paper (in the Results section for for Warfarin combined with ASA vs ASA monotherapy)_to clarify that patients with a pre-operative indication for warfarin were excluded, but it was unclear to what extent this exclusion extended to patients with pre-operative atrial fibrillation. Propensity scoring included pre-discharge atrial fibrillation without further differentiation of pre- vs post-operative atrial fibrillation.
4 | Although the RCT comparing trifusal vs. acenocoumarol met study criteria inclusion, the study might not have much direct application in the VA population (I could not find information on either drug at FDA.gov. in my limited search on US availability). | We have added clarification that the drugs used in this trial are not currently used in the US, therefore applicability to practice is limited.
4 | On 6 line 15: the phrase “warfarin plus was” should probably read “warfarin plus aspirin was” | We have made the correction as suggested.
4 | Although the relevant studies for each of the sub analyses are more readily available for review when included within each section (rather than altogether as an appendix at the end of the statement), the tables distract from the flow of the document to a degree | Noted. We have relocated the tables to occur together after the text for each treatment comparison.
5 | Overall, the authors are to be commended for a thorough overview of the topic that provides a trove of available data supporting current recommendations. Overall, the evidence review appears complete and the findings and conclusions of the paper appear reasonable. | Noted.
5 | My preference in evidence reviews is to better separate and distinguish evidence/data from non-RCT observational data, whether in large populations or small populations, from evidence from RCT data. In this review, evidence from these 2 types of data are often presented together. Eg, Table 10 has both RCT and cohort data presented together. Could there be a separate column for RCT versus cohort data (ie N studies per outcome separated into 2 columns, one for RCT, one for the rest)? | We have revised each table by grouping studies together by study design, and listing RCTs first, followed by cohort studies, for each drug comparison. For the summary of evidence table, all of the information was used to determine the strength of evidence, so both study designs contributed to the summary findings for each drug comparison.
5 | Of the various guidelines cited by the authors, the AHA/ACC focused update of the 2014 AHA/ACC guidelines for management of patients with valvular heart disease may be of greatest relevance for the practice in the VA setting of clinicians licensed in the USA. Thus, agree with the decision to highlight the conclusions regarding warfarin plus aspirin benefit/risk in BAVR and the review might further emphasize the concordance of this conclusion with the AHA/ACC guidelines in particular. | We strengthened the discussion of the guidelines, as noted in the Discussion, (2^nd^ to last paragraph).
5 | The novel TAVR data are an important focus of this review. The review would also benefit from a stronger statement about the limited data available from adequately sized RCTs and a comment about the gaps that need to be addressed by ongoing or currently unplanned trials in addition to the listing of ongoing trials in Table 9. | We agree and have added a statement in the Discussion as suggested.
6 | None | Noted.