# APPENDIX C Quality Assessment Criteria and Tables

Domain | Criteria
Trials: Cochrane Risk of Bias assessment^38^
Sequence generation | Was the allocation sequence adequately generated?
Allocation concealment | Was allocation adequately concealed?
Blinding | Was knowledge of the allocated intervention adequately prevented during the study?
Incomplete outcome data | Were incomplete outcome data adequately addressed? Consider attrition, intention-to-treat analysis.
Selective outcome reporting | Are reports of the study free of suggestion of selective outcome reporting?
Other sources of bias | Was the study apparently free of other problems that could put it at a high risk of bias?
Overall assessment of potential for bias | Low/Unclear/High
Observational studies: criteria based on the Newcastle-Ottawa scale^39^
Representativeness of the exposed cohort | Enter 0 or 1: 1 = truly representative of the average patient in the community 1 = somewhat representative of the average patient in the community 0 = selected group of users (eg, nurses, volunteers) 0 = no description of the derivation of the cohort
Selection of the non-exposed cohort | Enter 0 or 1: 1 = drawn from the same community as the exposed cohort 0 = drawn from a different source 0 = no description of the derivation of the non-exposed cohort
Ascertainment of exposure | Enter 0 or 1: 1 = secure record (eg surgical records; chart review; database) 0 = no description
Precision of Exposure Dose Ascertainment | Enter 0 or 1: 1 = both criteria satisfied for warfarin & aspirin: For warfarin, they reported duration of exposure and some measure of achieved INR or % time in range (dose of warfarin not meaningful). For aspirin, need to specify range of dose, as well as duration. 1 = amount and duration of exposure, other drugs studied (INR not needed) – applies to DOACS. 0 = if exposure category is simply “warfarin” or “aspirin” with duration noted, but without dose. 0 = no information about amount and time.
Demonstration that outcome of interest was not present at start of study, or baseline assessment | Enter 0 or 1: 1= yes 0 = no Note: we are prioritizing symptomatic outcomes; MRI outcomes found 6 months later might be problematic (stroke present at baseline) but not applicable to our outcomes of interest.
Adjustment for confounding (rendering comparability of cohorts on the basis of the design or analysis) | Enter 0 or 1: 1 = study accounts/controls for key factors (age, sex, atrial fibrillation; other cardiovascular risk factors; previous thromboembolic event) 0 = study controls for other factors but lacks key factors listed above Notes: propensity score matching–variables associated with receipt of a given therapy (eg, CABG; end up on dual AP because of procedure); multivariate regression
Assessment of outcome | Enter 0 or 1: 1 = independent assessment/chart review – investigators aren't assessing patient themselves 1 = record linkage (eg administrative data, registry data) 0 = no description; unspecified; non-specific patient self-report without chart review or clinical assessment
Adequacy of follow-up of cohorts | Enter 0 or 1: 1 = complete follow-up, all subjects accounted for 1 = subjects lost to follow-up unlikely to introduce bias; small number lost (select an adequate % follow-up), or description of those lost 0 = follow-up rate < 80%, and no description of those lost 0 = no statement

QA Tables for RCTs

Quality assessment criteria | Aramendi, 2005^14^ | Colli, 2007^1^ | DiMarco 2007^2^ | Rafiq 2017^3^
Randomization/allocation sequence adequately generated? Yes/No | Yes: Statistical significance between groups' baseline characteristics not reported, but appear similar. Note: 5% of included pts had mitral valve or both aortic and mitral valve replacement. | No: randomization method not reported, and groups were not balanced: “The 2 groups were similar except for the male:female ratio, which differed due to the method of randomization applied.” | Unclear: method of randomization not reported. Authors note in discussion: “the randomization methods (especially in group 1) might imply some bias” | Unclear-exact method of randomization not reported (“randomly sequenced opaque sealed envelopes,” but method of generating sequence or assigning them to a group was not reported). Groups were balanced at baseline.
Allocation adequately concealed? Yes/No | Yes | Unclear: not reported | Unclear: method not reported | Yes: opaque sealed envelopes
Blinding? Yes/No | No for patients: randomized open pilot trial. Yes for outcome assessors: All reported primary and secondary end-points were validated by all 4 investigators without unblinding the treatment assigned. | No, not reported whether blinding was attempted | No, there is no mention of the providers or outcome assessors being blinded | No: open-label trial (although data analysis blinded to group allocation); however, outcome data appears to have been collected in an objective manner (clear criteria)
Incomplete outcome data adequately addressed? Yes/No | Yes: 191 analyzed of 200 randomized; 18% withdrew but reported reasons for withdrawal | Yes. Only 8% were excluded because they developed afib and were treated with VKA. | Yes, no loss to follow up | Yes: 11% attrition (even among groups), ITT analysis
Free of suggestion of selective outcome reporting? Yes/No | Yes: protocol published prior to study | Yes | No: overly favorable: “Aspirin therapy appears to be the appropriate response to both cardiac surgeons' and patients' needs in the early postoperative course after aortic valve replacement with tissue valves” | Yes: ClinicalTrials.gov record available, does not appear to have been any selective outcome reporting
Free of other problems that could put it at a high risk of bias? Yes/No | Unclear - authors call analysis ITT but excluded those who did not receive medication. Post-randomization exclusions: 3.5% because they did not receive medication | Unclear. “The sample size was underpowered to demonstrate statistical differences between the 2 groups.” | Yes | Yes: updated INR charts provided by 79% of warfarin group (Table 5), although the study admits there was some difficulty staying within range
Overall risk of bias: Low/ Unclear/ High | Low ROB | Unclear | Unclear. Randomized, but no efforts at concealment discussed, would pose risk | Low
Comments | INR out of range was reported (147 instances where INR values were >3; mean period when patients out of INR range was 11.8±7 days). | Non-blinded, but similar allocation strategy for embolic events | 50 of 250 patients were in RCT arm with little explanation of methods and 0 events for outcomes | Unclear (because open-label trial with no blinding)

Quality assessment criteria | Rodes-Cabau, 2017^15^ | Stabile, 2014^16^ | Ussia, 2011^17^
Randomization/ allocation sequence adequately generated? Yes/No | Unclear: no description of sequence generation but no significant differences in table 1 | Unclear - Randomized trial, does not report sequence generation -- groups are well balanced | Unclear: no description of sequence generation but groups were balanced.
Allocation adequately concealed? Yes/No | Yes: “random block sizes were used to conceal Tx allocation and randomization was stratified by clinical center | Unclear | No: no description
Blinding? Yes/No | No: open label | Unclear - Physicians were blinded. It does not state whether patients were blinded. | No: open-label
Incomplete outcome data adequately addressed? Yes/No | Yes: at 3 months, 98.6% included in analysis; states no loss to follow-up. | Yes: No attrition was reported, however, outcomes data is only to 30 days. | Yes: full follow-up + ITT
Free of suggestion of selective outcome reporting? Yes/No | Yes: all events were adjudicated by an independent committee. Pts with serious AEs were systematically monitored for source data verification. Protocol as posted and amended with updates. | No: most outcomes only report 30 day data (except mortality). Methods state 6-month follow-up, but reports only mortality at 6 months. Other outcomes only 30 days presented. | Yes: conclusions match data
Free of other problems that could put it at a high risk of bias? Yes/No | No: Sample size calculation was for 300 pts; only 222 enrolled because of slow enrollment and financial constraints. | No: Short-term follow-up biases towards vascular complications which are increased with DAPT, but may be insufficient to capture thromboembolic events. Not powered to assess clinical endpoints based on author's assessment. Small sample size. | Unclear: an exploratory paper and, hence, a formal sample size estimation was not performed. The authors acknowledge the main limitation of the study was the small number of randomized subjects.
Overall risk of bias: Low/ Unclear/ High | Low | High ROB | Unclear
Comments | Study prematurely ended (anticipated 300 patients) due to slow enrollment and lack of continued financial support. | Authors note: “...caution should be applied when interpreting the study results, which should be considered hypothesis generating rather than offering a definitive answer.”

QA Table for Cohort Studies

Quality assessment criteria | Abdul-Jawad Altisent, 2016^21^ | Al-Atassi, 2012^11^ | Blair, 1994^4^ | Brennan, 2012^5^
Representativeness of the exposed cohort | 1 - multiple sites, probably typical of patients selected for TAVR | 1 | 0 = Highly selected sample, excluded 115 patients (13% of 881 operated) who died before discharge. Patients who got AVR+MVR were included in both AVR and MVR | 1 = sampling of large number of institutions
Selection of the non-exposed cohort | 1 - drawn from same sites | 1 | 0 = Not specified whether ASA or No Tx pts differed from War pts, or why treated differently | 1 = drawn from same database (same consortium of hospitals)
Ascertainment of exposure | 1 - database, prospectively collected data including on antithrombotic strategy | 1 | 1 = chart review | 1 = discharge records
Precision of Exposure Dose Ascertainment | 0 - specified for aspirin, but not INR for warfarin | 1 | 0 = Specifies prothrombin time for Warfarin, but not duration. ASA dosage and duration NR | 0 = based on discharge medications without clear exposure dose
Demonstration that outcome of interest was not present at baseline | 1 | 1 | 1 = Outcomes well defined, not likely to be present at baseline. | 1 = based on record review
Adjustment for confounding (rendering comparability of cohorts on the basis of the design or analysis) | 1 - accounts for CAD, center, strategy and explored other key differences between groups | 1 - propensity score model | 0 = key factors were examined via univariate analysis, but not signif so excluded from multivariate model. | 1 = propensity scoring done
Assessment of outcome | 0 - unclear - chart review or telephone interview, but unclear how many patients were called or how outcomes were assessed over telephone. | 1 | 0 = chart review “supplemented by patient contact”; possible non-independence, and lack of information about how often they needed to contact people, who was contacting them, what they asked, etc. | 1 = administrative data based on ICD9
Adequacy of follow-up of cohorts | 1-person-time outcome so would have censored for loss to follow-up; however, # patients lost to follow-up NR. Median f/u 13 months and no one followed for less than 3 months | 1 No loss | 1 | 1 = Medicare administrative data
Comments | Moderate-quality study. Main limitations include lack of specific information on exact outcome assessment procedures and baseline imbalance in proportion of patients with CAD suggesting potential for confounding by indication, though crude and adjusted HR were very similar | Small sample size (N=56) | Poor quality study. | 7 = high quality with the notable exception of exposure risk. Some bias likely in selection. Tx choice varied among institutions.

Quality assessment criteria | Colli, 2013^6^ | di Marco, 2007^2^ | Durand, 2014^19^ | Gherli, 2004^7^
Representativeness of the exposed cohort | 1 | 1 consecutive patients | 1 = consecutive TAVR at 3 sites | 1
Selection of the non-exposed cohort | 0 = War population differed from ASA treated pts, with higher prevalence of Periphral vascular dz, CKD, and CAD. | 1 consecutive patients | 0 = Tx group individually determined by pt's previous use of same drug. SAPT pts were from 2 of the centers whereas DAPT pts were predominantly from a single center. | 1 = treatment assignment depended on which surgeon was on duty the day the patient underwent surgery.
Ascertainment of exposure | 1 | 1 = chart review and in person visits | 1 = registry | 1
Precision of Exposure Dose Ascertainment | 0 = target INR for War was 2.5; dose and duration of ASA or War not otherwise specified | 0 = time in INR not reported, though authors mention that all events occurred when patient INR was in range | 1 | 0 = Warfarin maintained for 3 months then substituted with ASA; NOS
Demonstration that outcome of interest was not present at baseline | 1 | 1 = based on clinical review | 1 = prospective study; major clinical events as primary end point | 1 = major health outcomes, clinically assessed.
Adjustment for confounding | 1 = propensity score matching | 0 : 200 patients assigned to anticoagulation strategy by surgeon preference with no mention of adjustment for confounders | 1 = multivariate analysis and propensity score matching | 1 = Cox model used to adjust for possible confounders.
Assessment of outcome | 1 | 0 = some chart review administrative data; then ambulatory clinical evaluation and phone interviews. Unclear if clinical evaluations by independent assessor. | 1 | 0 = 2nd author performed all clinical evaluations for study outcomes.
Adequacy of follow-up of cohorts | 0: Follow-up was uneven: 78% in War vs 89% in ASA | 1 = no patient lost to follow up | 1 | 1 = survival analysis with person-time-at risk
Comments | Registry industry-sponsored by St. Jude. Conclusions don't fit data. Significant results only with combined endpoints or small subgroups. 16% attrition | 5, appears to have low risk of bias but there is not clear adjustment for confounders and the assessment of outcome was somewhat unclear, likely clinical | Limited applicability: follow-up was only 30 days | Sum = 6

Quality assessment criteria | Holy, 2017^20^ | Ichibori, 2017^18^ | Jamieson, 2007^12^ | Lee, 2017^9^
Representativeness of the exposed cohort | 1 =All Ss from a single site | 1 = consecutive TAVR pts | 1 = a matched group within 2 regional teaching hospitals | 1
Selection of the n-exposed cohort | 1 = All Ss from a single site, but Tx groups differed: more AF in the OAC group; more staged PCI in DAPT group (P = .01). AF was adjusted for in analysis | 1 = same source; treatment based on year of surgery. | 1 = all from same database | 1 = treatment by surgeon's preference, but pts with indications for warfarin (eg, afib) received warfarin.
Ascertainment of exposure | 0 = no description | 0 = no description | 1 = UBC cardiac valve database | 1 = clinical database
Precision of Exposure Dose Ascertainment | 0 = dose not specified, only duration | 1 | 0 = unclear exposure; describes only the antithrombotic therapy during the study era | 1
Demonstration that outcome of interest was not present at baseline | 1 = clinical exams and imaging performed at multiple time points | 1 | 1 = from chart review | 1 = clinical presentation, primarily.
Adjustment for confounding | 1 = adjusted for age, sex, BMI, AF, and staged PCI | 1 = Cox proportional hazards regression | 1 = multivariate regression | 1 = propensity score matching
Assessment of outcome | 0 = not clear if investigators performed the clinical exams | 0 = no description on how outcome data was gathered | 0 = no information about how they assessed outcomes. | 0 = investigators also treated patients, examined patients for outcomes
Adequacy of follow-up of cohorts | 1 = no mention of follow-up completeness, but mentions Tx changes and ITT approach. | 1 = follow-up data on all patients | 0 = no statement on % follow-up. | 1 = All but one pt were followed up for 3 months
Comments | Insufficient detail on dose and/or duration of treatment; method of exposure ascertainment not described. | Dr. Y Sakata and Dr. Y Sawa received research grants from Edwards Lifesciences and Dr. S Nakatani received lecture fees from Edwards Lifesciences. | Lack of information about outcome assessment and follow-up are important flaws. | Very small study after the propensity score matching

Quality assessment criteria | Lytle, 1988^13^ | Mistiaen, 2004^8^ | Seeger, 2017^22^ | van der Wall, 2016^10^
Representativeness of the exposed cohort | 1 = consecutive patients, 294 identified as having a preoperative aortic valve lesion that was a 'pure' aortic stenosis (1+ aortic insufficiency) | 0 = 500 consecutive patients getting a CEP valve. Doesn't say where patients were drawn from | 1 = single site, large N. | 1
Selection of the non-exposed cohort | 1 = patients were subgrouped looking at valve-anticoagulation subgroups using a cox multivariate model. | 0 = Difficult to tell how the groups are derived | 1 = Pts with Hx or new onset AF after TAVR were given War or apixaban (with use at institution beginning Nov 2013) | 1
Ascertainment of exposure | 0 = anticoagulation strategy was 'warfarin', not otherwise specified | 1 = probably Rx from hospital database | 0 = no description | 1 = In all 3 hospitals, postoperative medical files were obtained and evaluated.
Precision of Exposure Dose Ascertainment | 0 = Time on warfarin, INR range or % time spent in range NR | 0 = no description, not even sure if all received ASA in the ASA group | 0 = dose not specified, only duration, which varied according to: dialysis status | 1 = postoperative medical files obtained and evaluated; thrombosis service was consulted about Tx duration, INRs and target values of pts who received acenocoumarol.
Demonstration that outcome of interest was not present at baseline | 1 | 1 = Previous stroke was present in some patients; Hx stroke was analyzed as a predictive variable. | 1 = early safety endpoint at 30 days appear to be all major clinical outcomes | 1
Adjustment for confounding | 1 = Multivariate analysis performed | 1 = univariate and multivariate analysis | 1 = multivariate analyses using stepwise forward regression: age, sex, DM, renal insufficiency, DAPT, STS score for mortality, and AF. | 1 = multivariable Poisson regression was performed using all potential risk factors simultaneously.
Assessment of outcome | 1: chart review | 0 = cardiologist filling out questionaire, but then all those with events underwent CT | 0 = “Patients were followed up by assessing their clinical histories at scheduled outpatient controls or through telephone contact after 1 and 12 months.” | 1
Adequacy of follow-up of cohorts | 1 = 1 patient lost to follow up after 29 months. | 0 = unclear outcome ascertainment, proportion of questionnaires returned NR. | 0 = differential loss to follow-up between Tx groups. Twelve-month follow-up was available in 131 in AF (48% of 272 at baseline): 81 (57.4%) of 141 apixaban 50 (31.7%) of 131 War | 1 = 5% excluded due to missing Tx data
Comments | Total: 6/8 | 1/8, high risk of selection and ascertainment bias | The afib group was a subpopulation of the entire study which was designed to ascertain differences in outcomes between patients in sinus rhythm with those in atrial fibrillation. | For the RR analyses separation of War vs ASA use for bleeding and TE isn't possible as they analyzed the data differently.