# APPENDIX B Study Selection

## Inclusion Codes, Code Definitions, and Criteria

Does the population include non-pregnant adults who have had bioprosthetic aortic valve replacement, which may include transcatheter aortic valve implantation?

Exclusions: patients with valve replacement in areas other than/in addition to aortic (eg, mitral valve); Ross procedure; Bentall procedure; and aortic root repair.

Exclude: studies that do not report outcomes of interest for patients who underwent isolated aortic valve replacement (eg mixed mitral & aortic population).

Yes → Proceed to 2.

No → STOP. Code X1 (Excluded population)

For reference, below is a list of bioprosthetic and mechanical valves. Please note any other valves occurring in the literature that should be added to the list.

BIOPROSTHETIC VALVES

3F (Medtronic)

ACURATE-TA

Biocor

Carpentier-Edwards

COLIBRI

CoreValve (Medtronic)

Crown PRT

Cryo-Life O'Brien Stentless

DOKIMOS

Edwards-Sapien XT

Engager

EPIC (St. Jude Medical)

EVOLUTE-R™ (MCV)

Freestyle (Medtronic)

FS

Hancock, Hancock II (Medtronic)

INSPIRIS

Ionescu-Shiley

JENAVALVE

J-Valve

LOTUS (Boston)

Mitroflow (Sorin)

MOSAIC (Medtronic)

MYVAL

Perceval

Perimount/Perimount Magna (Carpentier-Edwards)

Sapien (Edwards)

SAPIEN 3

SOLO

SORIN Freedom SOLO

TexMi

TLPB

TRIFECTA (St. Jude)

Xenomedica

Zorin

MECHANICAL VALVES

ATS

Beall

Bicarbon

Bjork

Bjork-Shiley/Delrin

Bjork-Shiley/Integral Monostrut

Braunwald-Cutter

CarboMedics bileaflet

Chitra tilting disc valve

Cross-Jones

DeBakey-Surgitool

Edwards MIRA

Edwards-Duromedics

Edwards-Tekna

Harken

Hufnagel-Lucite

Kay-Sheiley

Lillehei-Kaster

Magovern-Cromie

Medtronic-Hall

Monostrut (Sorin)

Omnicarbon

Omniscience

On-X

Smeloff-Cutter

Sorin Bicarbon

Sorin tilting-disc

St. Jude Medical (SJM)

Star-GK

Starr

Starr-Edwards

Ultracor

Wada-Cutter

Is the intervention an anticoagulant, antiplatelet, antithrombotic, or direct oral anticoagulant (DOAC) agent, used alone or in combination? We are interested only in post-procedure anticoagulation strategies, rather than strategies used before or during surgery (eg, heparin use intraoperatively).

Yes → Proceed to 3.

No → STOP. Code X2 (Not relevant to topic)

Note: If the study doesn't compare with appropriate control intervention, go to Q4

Is the article any of the following study designs or publication types:

- Randomized controlled trial
- Non-randomized controlled trial

Case-control or cohort study that adequately controls for important confounders. Cohort studies would include registry studies with comparative analyses.

Yes → Proceed to 4.

No → STOP. Code X3 (Excluded study design or publication type)

X3 examples: Narrative or non-systematic review; opinion/editorial; cross-sectional study; case report; non-consecutive case series; or consecutive case series with fewer than 500 subjects.

Note: Systematic reviews, meta-analyses, large (N ≥500) non-comparative registry studies, large (N ≥500) consecutive case series, and any other important background/discussion papers should be coded B-X3, with notes/keywords.

Examples:

B-X3 – consecutive case series, N>1000

B-X3 – non-comparative registry study, N>4000

B-X3 – SR, pearl references

B-X3 – narrative review with good background

Is the intervention compared with no therapy or with another anticoagulant, antiplatelet, antithrombotic, or direct oral anticoagulant (DOAC) agent, used alone or in combination?

Yes → Proceed to 5.

No → STOP. Code X4 (Comparator agent not in scope)

Are any of the following outcomes reported:

- Mortality
- Thromboembolic events
- Stroke
- Myocardial infarction
- Heart failure
- Readmission rates
- Need for valve reoperation (eg, valve thrombosis)
- Length of stay
- Need for change in antithrombotic strategy
- Major bleeding events
  – GI bleeds
  – Intracranial hemorrhage
  – Other (eg, retroperitoneal)
- Other/minor bleeding
- Readmission rates
- Pericardial or pleural effusion (requiring intervention where specified, rather than detected solely by imaging)

Excluded outcomes:

Imaging findings (including echocardiogram, CT, MRI); pleural effusions seen on X-ray but not requiring intervention

Low platelet count (thrombocytopenia)

Lab abnormalities not requiring intervention values in general (high INR, or anemia)

Subclinical thrombosis

Vascular complications, eg, AV fistula, local thrombosis, vascular dissection, vascular perforation, access-site hematoma, aortic dissection, left ventricle perforation, other peri-procedural complications

Atrial fibrillation

Yes → STOP. Code I (Include: study contains primary data addressing one or more KQs)

No → STOP. Code X5 (No outcomes of interest)