# APPENDIX A Search Strategies

[underlined: DATABASES/WEBSITES:]

Ovid Medline 1946 to June 19, 2017

PubMed (non-Medline materials) January 9, 2017

Elsevier EMBASE February 1, 2017

EBM Reviews (CDSR, DARE, HTA, Cochrane CENTRAL, etc.) January 24, 2017

Clinicaltrials.gov January 24, 2017

RoPR (Registry of Patient Registries January 24, 2017

[underlined: SEARCH STRATEGIES]

Updated search strategy – 9Jan2017, after adding “placement” based on Stevenson editorial:

Epub Ahead of Print, In-Process & Other Non-Indexed Citations, Ovid MEDLINE(R) Daily and Ovid MEDLINE(R) 1946 to Present

Date Searched: January 9, 2017

Searched by: Robin Paynter, MLIS

1 | Heart Valve Prosthesis/ or Heart Valve Prosthesis Implantation/ or Transcatheter Aortic Valve Replacement/ or (((aort* or valve*) adj3 (implant* or replac* or graft*)) or AVR or AVRs or mini-AVR* or “surgical AVR*” or SAVR or SAVRs or “bioprosthe* AVR*” or “bio-prosthe* AVR*” or “biologic* AVR*” or bAVR* or TAVI* or TAVR* or PAVR* or ((transcatheter* or trans-catheter* or transfemoral* or trans-femoral* or transapical* or trans-apical* or transaxillar* or trans-axillar* or transvascular* or trans-vascular* or percutaneous* or bioprosthet* or bio-prosthet* or biologic*) adj3 (implant* or placement* or replac* or graft*))).tw,kf. | 80730
2 | aortic valve/ or (aort* or answer or “Anticoagulation Treatment Influence on Postoperative Patients” or action).tw,kf. | 998641
3 | bioprosthesis/ or (bioprosthe* or bio-prosthe* or ((biologic* or tissue* or prosthe*) adj3 (aort* or valv* or graft*)) or bovine* or porcine* or equine* or xenograft* or xenogen* or heterograft* or xenobioprosthe* or 3F* or ACURATETA* or Biocor* or Carpentier-Edwards* or COLIBRI* or CoreValve* or Crown PRT* or DOKIMOS* or Engager* or EPIC* or Freestyle* or FS or HANCOCK* or INSPIRIS* or J-Valve* or JENAVALVE* or MITROFLOW* or MOSAIC* or MYVAL* or Perceval* or Perimount* or Sapien* or SOLO or TLPB* or TRIFECTA*).tw,kf. | 512785
4 | exp Anticoagulants/ or exp Platelet Aggregation Inhibitors/ or exp Antithrombins/ | 322966
5 | (anti-coagul* or anticoag* or antiplatelet* or antiplatelet* or (platelet* adj2 (aggregat* or anti-aggregat* or antiaggregat* or inhibit*)) or anti-thromb* or antithromb* or NOAC* or ((new or novel) adj3 (anti-coagul* or anticoagul*)) or DOAC* or “direct oral anti-coagul*” or “direct oral anticoagul*” or AVK or AVKs or “anti-vitamin k” or “antivitamin k” or VKA or VKAs or “vitamin k antagonist*” or coumarin* or acenocoumarol* or phenprocoumon* or fluindione*).tw,kf. | 174660
6 | 4-hydroxycoumarins/ or acenocoumarol/ or dicumarol/ or ethyl biscoumacetate/ or phenprocoumon/ | 5484
7 | warfarin/ or (warfarin* or Coumadin*).tw,kf. | 28607
8 | Thienopyridines/ or (Clopidogrel* or Plavix*).tw,kf. | 11380
9 | (Ticagrelor* or Brilinta*).tw,kf. | 1519
10 | Ticlopidine/ or (ticlopidine* or Ticlid* or prasugrel* or cangrelor*).tw,kf. | 12168
11 | Dipyridamole/ or (dipyridamole* or Persantine*).tw,kf. | 11573
12 | Aspirin, Dipyridamole Drug Combination/ or ((aspirin* adj2 dipyridamole) or Aggrenox*).tw,kf. | 969
13 | (Edoxaban* or Savaysa* or Lixiana*).tw,kf. | 814
14 | (Apixaban* or Eliquis*).tw,kf. | 1906
15 | Dabigatran/ or (dabigatran* or Pradaxa*).tw,kf. | 3910
16 | Rivaroxaban/ or (Rivaroxaban* or Xarelto*).tw,kf. | 3457
17 | Aspirin/ or (“acetylsalicylic acid” or “acetyl salicylic acid” or aspirin*).tw,kf. | 69828
18 | and/1-3 | 15004
19 | or/4-17 | 434099
20 | 18 and 19 | 1740
21 | limit 20 to english language | 1480
22 | limit 21 to animals | 165
23 | limit 22 to humans | 93
24 | 22 not 23 | 72
25 | 21 not 24 | 1408
26 | remove duplicates from 25 | 1317

EBM Reviews: (Cochrane trials, SRs; HTA; NHS econ)

Cochrane Central Register of Controlled Trials November 2016,

Cochrane Database of Systematic Reviews 2005 to January 18, 2017,

Health Technology Assessment 4th Quarter 2016,

NHS Economic Evaluation Database 1st Quarter 2015

Date Searched: January 24, 2017

Searched by: Robin Paynter, MLIS

1 | Heart Valve Prosthesis/ or Heart Valve Prosthesis Implantation/ or Transcatheter Aortic Valve Replacement/ or (((aort* or valve*) adj3 (implant* or replac* or graft*)) or AVR or AVRs or mini-AVR* or “surgical AVR*” or SAVR or SAVRs or “bioprosthe* AVR*” or “bio-prosthe* AVR*” or “biologic* AVR*” or bAVR* or TAVI* or TAVR* or PAVR* or ((transcatheter* or trans-catheter* or transfemoral* or trans-femoral* or transapical* or trans-apical* or transaxillar* or trans-axillar* or transvascular* or trans-vascular* or percutaneous* or bioprosthet* or bio-prosthet* or biologic*) adj3 (implant* or placement* or replac* or graft*))).tw,kf. | 3064
2 | aortic valve/ or (aort* or answer or “Anticoagulation Treatment Influence on Postoperative Patients” or action).tw,kf. | 33128
3 | bioprosthesis/ or (bioprosthe* or bio-prosthe* or ((biologic* or tissue* or prosthe*) adj3 (aort* or valv* or graft*)) or bovine* or porcine* or equine* or xenograft* or xenogen* or heterograft* or xenobioprosthe* or 3F* or ACURATE-TA* or Biocor* or Carpentier-Edwards* or COLIBRI* or CoreValve* or Crown PRT* or Cryo Life O'Brien or DOKIMOS* or Engager* or EPIC* or Freestyle* or FS or HANCOCK* or INSPIRIS* or Ionescu-Shiley* or J-Valve* or JENAVALVE* or MITROFLOW* or MOSAIC* or MYVAL* or Perceval* or Perimount* or Sapien* or SOLO or TexMi* or TL PB* or TRIFECTA* or Xenomedica*).tw,kf. | 7797
4 | exp Anticoagulants/ or exp Platelet Aggregation Inhibitors/ or exp Antithrombins/ | 16171
5 | (anti-coagul* or anticoag* or antiplatelet* or antiplatelet* or (platelet* adj2 (aggregat* or anti-aggregat* or antiaggregat* or inhibit*)) or anti-thromb* or antithromb* or NOAC* or ((new or novel) adj3 (anti-coagul* or anticoagul*)) or DOAC* or “direct oral anti-coagul*” or “direct oral anticoagul*” or AVK or AVKs or “anti-vitamin k” or “antivitamin k” or VKA or V KAs or “vitamin k antagonist*” or coumarin* or acenocoumarol* or phenprocoumon* or fluindione*).tw,kf. | 13560
6 | 4-hydroxycoumarins/ or acenocoumarol/ or dicumarol/ or ethyl biscoumacetate/ or phenprocoumon/ | 210
7 | warfarin/ or (warfarin* or Coumadin*).tw,kf. | 2850
8 | Thienopyridines/ or (Clopidogrel* or Plavix*).tw,kf. | 2334
9 | (Ticagrelor* or Brilinta*).tw,kf. | 387
10 | Ticlopidine/ or (ticlopidine* or Ticlid* or prasugrel* or cangrelor*).tw,kf. | 2003
11 | Dipyridamole/ or (dipyridamole* or Persantine*).tw,kf. | 1106
12 | Aspirin, Dipyridamole Drug Combination/ or ((aspirin* adj2 dipyridamole) or Aggrenox*).tw,kf. | 299
13 | (Edoxaban* or Savaysa* or Lixiana*).tw,kf. | 146
14 | (Apixaban* or Eliquis*).tw,kf. | 302
15 | Dabigatran/ or (dabigatran* or Pradaxa*).tw,kf. | 404
16 | Rivaroxaban/ or (Rivaroxaban* or Xarelto*).tw,kf. | 519
17 | Aspirin/ or (“acetylsalicylic acid” or “acetyl salicylic acid” or aspirin*).tw,kf. | 9850
18 | and/1-3 | 509
19 | or/4-17 | 28997
20 | 18 and 19 | 79

## ESP Searches: Bavr and Anticoagulation: Clinicaltrials.gov Search Results

ClinicalTrials.gov

Date Searched: January 24, 2017

Searched by: Robin Paynter, MLIS

Search #1:
bioprosthetic OR bio-prosthetic OR bovine OR porcine OR equine OR xenograft OR heterograft OR xenobioprosthetic \| aortic OR heart OR valve OR valvular \| anticoagulation OR antiplatelet OR antithromb OR antiaggregation OR VKA OR coumarin OR warfarin OR NOAC OR DOAC OR Clopidogrel OR Ticagrelor OR ticlopidine OR prasugrel OR dipyridamole OR Edoxaban OR Apixaban OR dabigatran OR Rivaroxaban | 8 studies found

Search #2
3F OR ACURATE-TA OR BiocOR OR Carpentier-Edwards OR COLIBRI OR COReValve OR Crown PRT OR Cryo-Life O'Brien OR DOKIMOS OR Engager OR EPIC OR Freestyle OR FS OR HANCOCK OR INSPIRIS OR Ionescu-Shiley OR J-Valve OR JENAVALVE OR MITROFLOW OR MOSAIC \| aortic OR heart OR valve OR valvular | 128 studies found

Search #3
MYVAL OR Perceval OR Perimount OR Sapien OR SOLO OR TexMi OR TLPB OR TRIFECTA OR Xenomedica \| aortic OR heart OR valve OR valvular | 78 studies found

## ESP Searches: Bavr + Anticoagulation: Registry of Patient Registries

RoPR (Registry of Patient Registries, https://patientregistry.ahrq.gov/search)

Date Searched: January 24, 2017

Searched by: Robin Paynter, MLIS

Search terms: bioprosthetic AND aortic

EMBASE.COM

Date Searched: February 1, 2017

Searched by: Robin Paynter, MLIS

1 | 'aorta valve prosthesis'/exp OR 'aorta valve replacement'/exp OR ((aort* OR valve*) NEAR/3 (implant* OR replac* OR graft*)):ab,ti OR avr:ab,ti OR avrs:ab,ti OR 'mini avr*':ab,ti OR 'surgical avr*':ab,ti OR savr:ab,ti OR savrs:ab,ti OR 'bioprosthe* avr*':ab,ti OR 'bio-prosthe* avr*':ab,ti OR 'biologic* avr*':ab,ti OR bAVR*:ab,ti OR tavi*:ab,ti OR tavr*:ab,ti OR pavr*:ab,ti OR ((transcatheter* OR 'trans catheter*' OR transfemoral* OR 'trans femoral*' OR transapical* OR 'trans apical*' OR transaxillar* OR 'trans axillar*' OR transvascular* OR 'trans vascular*' OR percutaneous* OR bioprosthet* OR 'bio prosthet*' OR biologic*) NEAR/3 (implant* OR replac* OR graft*)):ab,ti | 78,179
2 | 'aorta valve'/exp OR aort*:ab,ti OR answer:ab,ti OR 'anticoagulation treatment influence on postoperative patients':ab,ti OR action:ab,ti | 1,085,625
3 | 'bioprosthesis'/exp OR 'heart valve bioprosthesis'/exp OR 'carpentier edwards bioprosthesis'/exp OR 'hancock valve prosthesis'/exp OR 'mosaic bioprosthesis'/exp OR 'percutaneous aortic valve'/exp OR (bioprosthe*:ab,ti OR 'bio prosthe*':ab,ti OR ((biologic* OR tissue* OR prosthe*) NEAR/3 (aort* OR valv* OR graft*)):ab,ti OR bovine*:ab,ti OR porcine*:ab,ti OR equine*:ab,ti OR xenograft*:ab,ti OR xenogen*:ab,ti OR heterograft*:ab,ti OR xenobioprosthe*:ab,ti OR 3f*:ab,ti OR 'acurate ta*':ab,ti OR biocor*:ab,ti OR 'carpentier edwards*':ab,ti OR colibri*:ab,ti OR corevalve*:ab,ti OR crown:ab,ti AND prt*:ab,ti) OR dokimos*:ab,ti OR engager*:ab,ti OR epic*:ab,ti OR freestyle*:ab,ti OR fs:ab,ti OR hancock*:ab,ti OR inspiris*:ab,ti OR 'j valve*':ab,ti OR jenavalve*:ab,ti OR mitroflow*:ab,ti OR mosaic*:ab,ti OR myval*:ab,ti OR perceval*:ab,ti OR perimount*:ab,ti OR sapien*:ab,ti OR solo:ab,ti OR tlpb*:ab,ti OR trifecta*:ab,ti | 128,669
4 | 'anticoagulant agent'/exp OR 'antithrombocytic agent'/exp OR 'blood clotting inhibitor'/exp | 572,738
5 | 'anti coagul*':ab,ti OR anticoagul*:ab,ti OR 'anti platelet*':ab,ti OR antiplatelet*:ab,ti OR (platelet* NEAR/2 (aggregat* OR 'anti aggregat*' OR antiaggregat* OR inhibit*)):ab,ti OR 'anti thromb*':ab,ti OR antithromb*:ab,ti OR noac*:ab,ti OR ((new OR novel) NEAR/3 ('anti coagul*' OR anticoagul*)):ab,ti OR doac*:ab,ti OR 'direct oral anti-coagul*':ab,ti OR 'direct oral anticoagul*':ab,ti OR avk:ab,ti OR avks:ab,ti OR 'anti-vitamin k':ab,ti OR 'antivitamin k':ab,ti OR vka:ab,ti OR vkas:ab,ti OR 'vitamin k antagonist*':ab,ti OR coumarin*:ab,ti OR acenocoumarol*:ab,ti OR phenprocoumon*:ab,ti OR fluindione*:ab,ti | 222,158
6 | 'coumarin derivative'/exp OR '4 hydroxycoumarin'/exp OR 'acenocoumarol'/exp OR 'dicoumarol'/exp OR'ethyl biscoumacetate'/exp OR 'phenprocoumon'/exp | 111,728
7 | 'warfarin'/exp OR warfarin*:ab,ti OR coumadin*:ab,ti | 79,840
8 | 'thienopyridine derivative'/exp OR clopidogrel*:ab,ti OR plavix*:ab,ti | 20,571
9 | 'ticagrelor'/exp OR ticagrelor*:ab,ti OR brilinta*:ab,ti | 4,835
10 | 'ticlopidine'/exp OR ticlopidine*:ab,ti OR ticlid*:ab,ti OR prasugrel*:ab,ti OR cangrelor*:ab,ti | 16,536
11 | 'dipyridamole'/exp OR dipyridamole*:ab,ti OR persantine*:ab,ti | 23,918
12 | 'acetylsalicylic acid plus dipyridamole'/exp OR (aspirin* NEAR/2 dipyridamole):ab,ti OR aggrenox*:ab,ti | 1,837
13 | 'edoxaban'/exp OR edoxaban*:ab,ti OR savaysa*:ab,ti OR lixiana*:ab,ti | 2,104
14 | 'apixaban'/exp OR apixaban*:ab,ti OR eliquis*:ab,ti | 5,957
15 | 'dabigatran'/exp OR dabigatran*:ab,ti OR pradaxa*:ab,ti | 9,218
16 | 'rivaroxaban'/exp OR rivaroxaban*:ab,ti OR xarelto*:ab,ti | 9,238
17 | 'acetylsalicylic acid'/exp OR 'acetylsalicylic acid':ab,ti OR 'acetyl salicylic acid':ab,ti OR aspirin*:ab,ti | 192,267
18 | #1 AND #2 AND #3 | 9,238
19 | #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 | 674,206
20 | #18 AND #19 | 810
21 | #20 AND [English]/lim | 735

Ovid MEDLINE(R) Epub Ahead of Print, In-Process & Other Non-Indexed Citations, Ovid MEDLINE(R) Daily and Ovid MEDLINE(R) 1946 to Present

Date Searched: June 19, 2017

Searched by: Robin Paynter, MLIS

1 | Heart Valve Prosthesis/ or Heart Valve Prosthesis Implantation/ or Transcat heter Aortic Valve Replacement/ or (((aort* or valve*) adj3 (implant* or replac* or graft*)) or AVR or AVRs or mini-AVR* or “surgical AVR*” or SAVR or SAVRs or “bioprosthe* AVR*” or “bio-prosthe* AVR*” or “biologic* AVR*” or bAVR* or TAVI* or TAVR* or PAVR* or ((transcatheter* or trans-catheter* or transfemoral* or trans-femoral* or transapical* or trans-apical* or transaxillar* or trans-axillar* or transvascular* or trans-vascular* or percutaneous* or bioprosthet* or bio-prosthet* or biologic*) adj3 (implant* or placement* or replac* or graft*))).tw,kf. | 77787
2 | aortic valve/ or (aort* or answer or “Anticoagulation Treatment Influence on Postoperative Patients” or action).tw,kf. | 925458
3 | bioprosthesis/ or (bioprosthe* or bio-prosthe* or ((biologic* or tissue* or prosthe*) adj3 (aort* or valv* or graft*)) or bovine* or porcine* or equine* or xenograft* or xenogen* or heterograft* or xenobioprosthe* or 3F* or ACURATE-TA* or Biocor* or Carpentier-Edwards* or COLIBRI* or CoreValve* or Crown PRT* or Cryo-Life O'Brien or DOKIMOS* or Engager* or EPIC* or Freestyle* or FS or HANCOCK* or INSPIRIS* or Ionescu-Shiley* or J-Valve* or JENAVALVE* or MITROFLOW* or MOSAIC* or MYVAL* or Perceval* or Perimount* or Sapien* or SOLO or TexMi* or TLPB* or TRIFECTA* or Xenomedica*).tw,kf. | 476257
4 | exp Anticoagulants/ or exp Platelet Aggregation Inhibitors/ or exp Antithrombins/ | 292022
5 | (anti-coagul* or anticoag* or antiplatelet* or antiplatelet* or (platelet* adj2 (aggregat* or anti-aggregat* or antiaggregat* or inhibit*)) or anti-thromb* or antithromb* or NOAC* or ((new or novel) adj3 (anti-coagul* or anticoagul*)) or DOAC* or “direct oral anti-coagul*” or “direct oral anticoagul*” or AVK or AVKs or “anti-vitamin k” or “antivitamin k” or VKA or V KAs or “vitamin k antagonist*” or coumarin* or acenocoumarol* or phenprocoumon* or fluindione*).tw,kf. | 167816
6 | 4-hydroxycoumarins/ or acenocoumarol/ or dicumarol/ or ethyl biscoumacetate/ or phenprocoumon/ | 5251
7 | warfarin/ or (warfarin* or Coumadin*).tw,kf. | 27383
8 | Thienopyridines/ or (Clopidogrel* or Plavix*).tw,kf. | 11048
9 | (Ticagrelor* or Brilinta*).tw,kf. | 1580
10 | Ticlopidine/ or (ticlopidine* or Ticlid* or prasugrel* or cangrelor*).tw,kf. | 11737
11 | Dipyridamole/ or (dipyridamole* or Persantine*).tw,kf. | 10369
12 | Aspirin, Dipyridamole Drug Combination/ or ((aspirin* adj2 dipyridamole) or Aggrenox*).tw,kf. | 881
13 | (Edoxaban* or Savaysa* or Lixiana*).tw,kf. | 814
14 | (Apixaban* or Eliquis*).tw,kf. | 1993
15 | Dabigatran/ or (dabigatran* or Pradaxa*).tw,kf. | 3964
16 | Rivaroxaban/ or (Rivaroxaban* or Xarelto*).tw,kf. | 3563
17 | Aspirin/ or (“acetylsalicylic acid” or “acetyl salicylic acid” or aspirin*).tw,kf. | 65868
18 | and/1-3 | 14497
19 | or/4-17 | 398605
20 | 18 and 19 | 1692
21 | limit 20 to english language | 1432
22 | limit 21 to animals | 154
23 | limit 22 to humans | 90
24 | 22 not 23 | 64
25 | 21 not 24 | 1368
26 | remove duplicates from 25 | 1347
27 | Heart Valve Prosthesis/ or Heart Valve Prosthesis Implantation/ or Transcatheter Aortic Valve Replacement/ or (((aort* or valve*) adj3 (implant* or replac* or graft* or repair*)) or “bioprosthe* AVR*” or “bio-prosthe* AVR*” or “biologic* AVR*” or bAVR* or TAVI* or TAVR* or PAVR* or ((transcatheter* or trans-catheter* or transfemoral* or trans-femoral* or transapical* or trans-apical* or transaxillar* or trans-axillar* or transvascular* or trans-vascular* or percutaneous* or bioprosthet* or bio-prosthet* or biologic*) adj3 (implant* or placement* or replac* or graft* or repair*))).tw,kf. | 90097
28 | 2 and 27 | 53970
29 | 19 and 28 | 3275
30 | limit 29 to english language | 2815
31 | limit 30 to animals | 241
32 | limit 31 to humans | 115
33 | 31 not 32 | 126
34 | 30 not 33 | 2689
35 | remove duplicates from 34 | 2622
36 | 35 not 26 | 1277
37 | from 36 keep 1-1277 | 1277