# SUMMARY AND DISCUSSION

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Question 1

Bariatric surgery candidates and those receiving surgery have depression, anxiety, and certain eating disorders (eg, binge eating) at rates equal to or exceeding 15%. Other mental health disorders, such as psychoses, are less frequent. Published prevalence estimates vary, particularly for depression and binge eating disorder. The few assessments done in Veteran populations found higher proportions of comorbidities than are present in other populations, particularly PTSD.

### Key Question 2

There are conflicting data regarding the impact of mental health conditions on post-operative outcomes, including weight loss, mental health symptoms, quality of life, and suicide. The most consistent evidence suggests lower rates of depression, fewer symptoms of depression, and decreased usage of anti-depressant therapies after bariatric surgery. A causal role of bariatric surgery cannot be established with the existing studies. Aside from depression, only quality of life demonstrated consistent improvement across multiple studies, although the use of different scales and timelines complicates the evaluation. There is insufficient evidence to determine the relationship between pre-operative mental health conditions and post-operative weight loss outcomes.

### Key Question 3

There were no studies that assessed the impact of a pre-operative intervention addressing mental health conditions on post-operative outcomes, such as surgical weight loss or the prevalence of the mental health disorders. Five low-quality studies reported pre-operative improvements in targeted mental health behaviors, as well as pre-operative physician-supervised weight loss before surgery and substance abuse, for bariatric surgery candidates.

## LIMITATIONS

### Publication Bias

We were not able to do a formal test of publication bias since we did not perform a quantitative analyses. However, publication bias is always likely to exist for subjects such as this, where prevalence data and association data are presumably present on a majority of patients receiving the procedure.

### Study Quality

Most studies had limitations in their methods. These include an unclear method of enrolling participants, poor or unstated follow-up rate, and use of a pre-post design for studies of interventions. There are some notable exceptions, of course, such as the LABS-2 study, which probably provides the most rigorous evidence on variables included in that study, albeit in a selected sample. LABS-2 is a multi-site study with clear enrollment criteria, provides very detailed follow-up rate at multiple time points, and uses standardized measures to collect all data, including comorbidities, quality of life, and mental health conditions, both pre-operatively and at regular time points following surgery.

### Heterogeneity

The estimates for prevalence of mental health conditions and eating disorders vary, and most of this variation is unexplained. Hence, heterogeneity is a concern and lowers the confidence in conclusions.

### Applicability of Findings to the VA Population

There are striking differences in the gender of patients assessed in VA compared to non-VA populations. From the limited VA studies that have been done, the prevalence of mental health conditions and eating disorders is higher than in non-VA populations. Therefore, generalizing results from the non-VA population to the VA population needs to be done with caution.

### Other

We limited the scope of our evaluation to particular mental health conditions. However, other factors, such as cognitive functioning, temperament, socioeconomic status, and personality traits may also play a role in patient safety and success with bariatric surgery.

Binge eating disorder has undergone change in how it is defined, not existing formally as a psychiatric disorder until DSM-5, which appeared in 2013/2014. If the diagnosis was made by a scale, that was listed. However, if the diagnosis was made by interview, it is not always clear what criteria were used.

Mental health conditions were defined by the authors of the original studies and it was not always clear what types of disorders were included under diagnostic terms such as anxiety, depression and others. We were only able to specify according to the information given.

## RESEARCH GAPS/FUTURE RESEARCH

In order to generate VA-relevant data, a more broadly-based data collection effort is needed among Veterans seeking bariatric surgery. This should include a sufficient number of sites to be representative of the diversity within the VA system, have clear eligibility criteria, use the same standardized instruments for classifying disorders, measure outcomes at regular intervals following surgery (eg,3 months, 6 months, 12 months, 2 years, etc), and report the follow-up rate at each time point. For studies of associations, the addition of a control group would improve the ability to make causal inferences. The Swedish Obese Subjects study has shown that causal inferences are possible using non-randomized patients. Very careful attention to the selection of controls, as in the Swedish Obese Subjects study, is required. To assess the effectiveness of pre-operative interventions, randomized clinical trials are ideal.

One difficulty in comparing studies was the use of different measures, at separate sites, to diagnose mental health conditions. Future research should focus on determining the best methods of diagnosing these conditions and the VA should meet and decide which measures will be used across all VA sites.

More research into the severity or chronicity of mental health conditions is needed, as these were not usually reported but may contribute to the effect of mental health conditions on bariatric outcomes. Specifically, more research is needed in both the VA and non-VA patients who may be seeking bariatric surgery. Long-term studies, beyond 2 years, on sustainability of the changes in response to interventions should be studied as well.

## CONCLUSIONS

Mental health conditions and eating disorders are seen in rates exceeding 15% in bariatric surgery candidates and patients, in particular depression, anxiety, and binge eating disorders. Moderate quality evidence supports an association between bariatric surgery and lower rates of depression post-operatively. There is inconsistent evidence about the association of other mental health conditions and eating disorders on subsequent post-operative outcomes. There are no studies assessing the effect of pre-operative interventions aimed at mental health conditions or eating disorders. There is insufficient evidence to recommend for or against routine specialized pre-operative mental health screening in bariatric surgery candidates in addition to the existing general evaluation by the surgical and/or medical bariatric team. More research is needed to determine the optimal screening process and helpful interventions to address mental health and eating disorders in bariatric surgery candidates. Likewise, research is needed to better define the optimal mental health evaluations needed for clearance for bariatric surgery.