# REFERENCES

1 Livhits M, Mercado C, Yermilov I, et al. Preoperative predictors of weight loss following bariatric surgery: systematic review. Obesity surgery. Jan. 2012;22(1):70-89. [pmid: 21833817].
2 Malik S, Mitchell JE, Engel S, Crosby R, Wonderlich S. Psychopathology in bariatric surgery candidates: A review of studies using structured diagnostic interviews. Comprehensive psychiatry. Oct. 24. 2013.
3 Flegal KM, Carroll MD, Ogden CL, Johnson CL. Prevalence and trends in obesity among US adults, 1999-2000. JAMA : the journal of the American Medical Association. Oct. 9. 2002;288(14):1723-1727. [pmid: 12365955].
4 Flegal KM, Carroll MD, Ogden CL, Curtin LR. Prevalence and trends in obesity among US adults, 1999-2008. JAMA : the journal of the American Medical Association. Jan. 20. 2010;303(3):235-241. [pmid: 20071471].
5 Ogden CL, Carroll MD, Kit BK, Flegal KM. Prevalence of childhood and adult obesity in the United States, 2011-2012. JAMA : the journal of the American Medical Association. Feb. 26. 2014;311(8):806-814. [pmid: 24570244].
6 American Medical Association. AMA Adopts New Policies on Second Day of Voting at Annual Meeting. 6. 18. 2013. http://www.ama-assn.org/ama/pub/news/news/2013/2013-06-18-new-ama-policies-annual-meeting.page. 7/15/2014.
7 Flegal KM, Graubard BI, Williamson DF, Gail MH. Excess deaths associated with underweight, overweight, and obesity. JAMA : the journal of the American Medical Association. Apr. 20. 2005;293(15):1861-1867. [pmid: 15840860].
8 Flegal KM, Graubard BI, Williamson DF, Gail MH. Cause-specific excess deaths associated with underweight, overweight, and obesity. JAMA : the journal of the American Medical Association. Nov. 7. 2007;298(17):2028-2037. [pmid: 17986696].
9 Gastrointestinal Surgery for Severe Obesity. NIH Consens Statement 3/25/1991-3/27/1991. 9(1):1-20.
10 Buchwald H, Avidor Y, Braunwald E, et al. Bariatric surgery: a systematic review and meta-analysis. JAMA : the journal of the American Medical Association. Oct. 13. 2004;292(14):1724-1737. [pmid: 15479938].
11 Maggard-Gibbons M, Maglione M, Livhits M, et al. Bariatric surgery for weight loss and glycemic control in nonmorbidly obese adults with diabetes: a systematic review. JAMA : the journal of the American Medical Association. Jun. 5. 2013;309(21):2250-2261. [pmid: 23736734].
12 Maggard MA, Shugarman LR, Suttorp M, et al. Meta-analysis: surgical treatment of obesity. Ann Intern Med. Apr. 5. 2005;142(7):547-559. [pmid: 15809466].
13 Hsu LK, Benotti PN, Dwyer J, et al. Nonsurgical factors that influence the outcome of bariatric surgery: a review. Psychosom Med. May-Jun. 1998;60(3):338-346. [pmid: 9625222].
14 van Hout GC, Verschure SK, van Heck GL. Psychosocial predictors of success following bariatric surgery. Obesity surgery. Apr. 2005;15(4):552-560. [pmid: 15946437].
15 Bauchowitz AU, Gonder-Frederick LA, Olbrisch ME, et al. Psychosocial evaluation of bariatric surgery candidates: a survey of present practices. Psychosom Med. Sep-Oct. 2005;67(5):825-832. [pmid: 16204445].
16 Buchwald H. Consensus conference statement bariatric surgery for morbid obesity: health implications for patients, health professionals, and third-party payers. Surgery for obesity and related diseases : official journal of the American Society for Bariatric Surgery. May-Jun. 2005;1(3):371-381. [pmid: 16925250].
17 Malik S, Mitchell JE, Engel S, Crosby R, Wonderlich S. Psychopathology in bariatric surgery candidates: a review of studies using structured diagnostic interviews. Comprehensive psychiatry. Feb. 2014;55(2):248-259. [pmid: 24290079].
18 Higgins JP, Altman DG, Gotzsche PC, et al. The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ (Clinical research ed.). 2011;343:d5928.
19 Balshem H, Helfand M, Schunemann HJ, et al. GRADE guidelines: 3. Rating the quality of evidence. Journal of clinical epidemiology. Apr. 2011;64(4):401-406. [pmid: 21208779].
20 Rutledge T, Adler S, Friedman R. A prospective assessment of psychosocial factors among bariatric versus non-bariatric surgery candidates. Obesity surgery. Oct. 2011;21(10):1570-1579. [pmid: 20872090].
21 Allison KC, Wadden TA, Sarwer DB, et al. Night eating syndrome and binge eating disorder among persons seeking bariatric surgery: prevalence and related features. Obesity (Silver Spring, Md.). Mar. Suppl 2. 2006;14:77S-82S.
22 Castellini G, Godini L, Amedei SG, et al. Psychopathological similarities and differences between obese patients seeking surgical and non-surgical overweight treatments. Eating and weight disorders : EWD. Sep. 8. 2013.
23 Chen EY, Fettich KC, Tierney M, et al. Factors associated with suicide ideation in severely obese bariatric surgery-seeking individuals. Suicide & life-threatening behavior. Oct. 2012;42(5):541-549. [pmid: 22957662].
24 Chen EY, Fettich KC, McCloskey MS. Correlates of suicidal ideation and/or behavior in bariatric-surgery-seeking individuals with severe obesity. Crisis. Jan. 1. 2012;33(3):137-143. [pmid: 22343060].
25 Grothe KB, Mundi MS, Himes SM, et al. Bipolar Disorder Symptoms in Patients Seeking Bariatric Surgery. Obesity surgery. Apr. 22. 2014.
26 Hall BJ, Hood MM, Nackers LM, Azarbad L, Ivan I, Corsica J. Confirmatory factor analysis of the Beck Depression Inventory-II in bariatric surgery candidates. Psychological assessment. Mar. 2013;25(1):294-299. [pmid: 23088200].
27 Hayden MJ, Murphy KD, Brown WA, O'Brien PE. Axis I disorders in adjustable gastric band patients: the relationship between psychopathology and weight loss. Obes Surg. Sep. 2014;24(9):1469-1475. [pmid: 24570091].
28 Hayden MJ, Brown WA, Brennan L, O'Brien PE. Validity of the Beck Depression Inventory as a screening tool for a clinical mood disorder in bariatric surgery candidates. Obesity surgery. Nov. 2012;22(11):1666-1675. [pmid: 22669523].
29 Kalarchian MA, Marcus MD, Levine MD, et al. Psychiatric disorders among bariatric surgery candidates: relationship to obesity and functional health status. The American journal of psychiatry. Feb. 2007;164(2):328-334. quiz 374. [pmid: 17267797].
30 Lester D, Iliceto P, Pompili M, Girardi P. Depression and suicidality in obese patients. Psychological reports. Apr. 2011;108(2):367-368. [pmid: 21675551].
31 Marek RJ, Ben-Porath YS, Ashton K, Heinberg LJ. Impact of using DSM-5 criteria for diagnosing binge eating disorder in bariatric surgery candidates: change in prevalence rate, demographic characteristics, and scores on the Minnesota Multiphasic Personality Inventory--2 restructured form (MMPI-2-RF). The International journal of eating disorders. Jul. 2014;47(5):553-557. [pmid: 24599797].
32 Marek RJ, Ben-Porath YS, Windover A, et al. Assessing psychosocial functioning of bariatric surgery candidates with the Minnesota multiphasic personality inventory-2 restructured form (MMPI-2-RF). Obesity surgery. Nov. 2013;23(11):1864-1873. [pmid: 23856990].
33 Mauri M, Rucci P, Calderone A, et al. Axis I and II disorders and quality of life in bariatric surgery candidates. The Journal of clinical psychiatry. Feb. 2008;69(2):295-301. [pmid: 18251626].
34 Wee CC, Davis RB, Huskey KW, Jones DB, Hamel MB. Quality of life among obese patients seeking weight loss surgery: the importance of obesity-related social stigma and functional status. Journal of general internal medicine. Feb. 2013;28(2):231-238. [pmid: 22956443].
35 Windover AK, Merrell J, Ashton K, Heinberg LJ. Prevalence and psychosocial correlates of self-reported past suicide attempts among bariatric surgery candidates. Surgery for obesity and related diseases : official journal of the American Society for Bariatric Surgery. Nov-Dec. 2010;6(6):702-706. [pmid: 21111382].
36 Cremieux PY, Ledoux S, Clerici C, Cremieux F, Buessing M. The impact of bariatric surgery on comorbidities and medication use among obese patients. Obesity surgery. Jul. 2010;20(7):861-870. [pmid: 20440579].
37 Cunningham JL, Merrell CC, Sarr M, et al. Investigation of antidepressant medication usage after bariatric surgery. Obesity surgery. Apr. 2012;22(4):530-535. [pmid: 21901283].
38 Dixon JB, Dixon ME, O'Brien PE. Depression in association with severe obesity: changes with weight loss. Arch Intern Med. Sep. 22. 2003;163(17):2058-2065. [pmid: 14504119].
39 Dixon JB, Dixon ME, O'Brien PE. Quality of life after lap-band placement: influence of time, weight loss, and comorbidities. Obes Res. Nov. 2001;9(11):713-721. [pmid: 11707538].
40 Herpertz S, Burgmer R, Stang A, et al. Prevalence of mental disorders in normal-weight and obese individuals with and without weight loss treatment in a German urban population. Journal of psychosomatic research. Jul. 2006;61(1):95-103. [pmid: 16813851].
41 Hood MM, Grupski AE, Hall BJ, Ivan I, Corsica J. Factor structure and predictive utility of the Binge Eating Scale in bariatric surgery candidates. Surgery for obesity and related diseases : official journal of the American Society for Bariatric Surgery. Jul. 14. 2012.
42 Legenbauer T, Petrak F, de Zwaan M, Herpertz S. Influence of depressive and eating disorders on short- and long-term course of weight after surgical and nonsurgical weight loss treatment. Comprehensive psychiatry. May-Jun. 2011;52(3):301-311. [pmid: 21497225].
43 Legenbauer T, De Zwaan M, Benecke A, Muhlhans B, Petrak F, Herpertz S. Depression and anxiety: their predictive function for weight loss in obese individuals. Obes Facts. 2009;2(4):227-234. [pmid: 20054228].
44 Mitchell JE, King WC, Courcoulas A, et al. Eating behavior and eating disorders in adults before bariatric surgery. The International journal of eating disorders. Apr. 9. 2014.
45 Ostlund MP, Backman O, Marsk R, et al. Increased admission for alcohol dependence after gastric bypass surgery compared with restrictive bariatric surgery. JAMA surgery. Apr. 2013;148(4):374-377. [pmid: 23716012].
46 Raebel MA, Newcomer SR, Reifler LM, et al. Chronic use of opioid medications before and after bariatric surgery. JAMA : the journal of the American Medical Association. Oct. 2. 2013;310(13):1369-1376. [pmid: 24084922].
47 Wolnerhanssen BK, Peters T, Kern B, et al. Predictors of outcome in treatment of morbid obesity by laparoscopic adjustable gastric banding: results of a prospective study of 380 patients. Surgery for obesity and related diseases : official journal of the American Society for Bariatric Surgery. Jul-Aug. 2008;4(4):500-506. [pmid: 18586562].
48 Won EJ, Tran TT, Rigby A, Rogers AM. A comparative study of three-year weight loss and outcomes after laparoscopic gastric bypass in patients with “yellow light” psychological clearance. Obesity surgery. Jul. 2014;24(7):1117-1119. [pmid: 24760310].
49 Adams TD, Pendleton RC, Strong MB, et al. Health outcomes of gastric bypass patients compared to nonsurgical, nonintervened severely obese. Obesity (Silver Spring, Md.). Jan. 2010;18(1):121-130.
50 Apovian CM, Huskey KW, Chiodi S, et al. Patient Factors Associated with Undergoing Laparoscopic Adjustable Gastric Banding vs Roux-en-Y Gastric Bypass for Weight Loss. Journal of the American College of Surgeons. Dec. 2013;217(6):1118-1125. [pmid: 24083911].
51 Caixas A, Lecube A, Morales MJ, et al. Weight-related quality of life in Spanish obese subjects suitable for bariatric surgery is lower than in their North American counterparts: a case-control study. Obesity surgery. Apr. 2013;23(4):509-514. [pmid: 23090430].
52 Corsica JA, Hood MM, Azarbad L, Ivan I. Revisiting the revised master questionnaire for the psychological evaluation of bariatric surgery candidates. Obesity surgery. Mar. 2012;22(3):381-388. [pmid: 21567335].
53 Corsica JA, Azarbad L, McGill K, Wool L, Hood M. The Personality Assessment Inventory: clinical utility, psychometric properties, and normative data for bariatric surgery candidates. Obesity surgery. Jun. 2010;20(6):722-731. [pmid: 19890678].
54 Kudsi OY, Huskey K, Grove S, Blackburn G, Jones DB, Wee CC. Prevalence of preoperative alcohol abuse among patients seeking weight-loss surgery. Surgical endoscopy. Apr. 2013;27(4):1093-1097. [pmid: 23052540].
55 Lier HO, Biringer E, Stubhaug B, Tangen T. The impact of preoperative counseling on postoperative treatment adherence in bariatric surgery patients: a randomized controlled trial. Patient education and counseling. Jun. 2012;87(3):336-342. [pmid: 22035647].
56 Lin HY, Huang CK, Tai CM, et al. Psychiatric disorders of patients seeking obesity treatment. BMC psychiatry. 2013;13:1. [pmid: 23281653].
57 Heinberg LJ, Ashton K, Windover A, Merrell J. Older bariatric surgery candidates: is there greater psychological risk than for young and midlife candidates?. Surgery for obesity and related diseases : official journal of the American Society for Bariatric Surgery. Sep-Oct. 2012;8(5):616-622. discussion 622-614. [pmid: 22197385].
58 King WC, Kalarchian MA, Steffen KJ, Wolfe BM, Elder KA, Mitchell JE. Associations between physical activity and mental health among bariatric surgical candidates. Journal of psychosomatic research. Feb. 2013;74(2):161-169. [pmid: 23332532].
59 King WC, Chen JY, Mitchell JE, et al. Prevalence of alcohol use disorders before and after bariatric surgery. JAMA : the journal of the American Medical Association. Jun. 20. 2012;307(23):2516-2525. [pmid: 22710289].
60 Mitchell JE, King WC, Chen JY, et al. Course of depressive symptoms and treatment in the longitudinal assessment of bariatric surgery (LABS-2) study. Obesity (Silver Spring, Md.). Mar. 14. 2014.
61 Mitchell JE, Selzer F, Kalarchian MA. Psychopathology before surgery in the longitudinal assessment of bariatric surgery-3 (LABS-3) psychosocial study. Surgery for obesity and related diseases : official journal of the American Society for Bariatric Surgery. Sep-Oct. 2012;8(5):533-541. [pmid: 22920965].
62 Svensson PA, Anveden A, Romeo S, et al. Alcohol consumption and alcohol problems after bariatric surgery in the Swedish obese subjects study. Obesity (Silver Spring, Md.). Dec. 2013;21(12):2444-2451.
63 Adams CE, Gabriele JM, Baillie LE, Dubbert PM. Tobacco use and substance use disorders as predictors of postoperative weight loss 2 years after bariatric surgery. The journal of behavioral health services & research. Oct. 2012;39(4):462-471. [pmid: 22374227].
64 Ikossi DG, Maldonado JR, Hernandez-Boussard T, Eisenberg D. Post-traumatic stress disorder (PTSD) is not a contraindication to gastric bypass in veterans with morbid obesity. Surgical endoscopy. Aug. 2010;24(8):1892-1897. [pmid: 20063014].
65 Rutledge T, Braden AL, Woods G, Herbst KL, Groesz LM, Savu M. Five-year changes in psychiatric treatment status and weight-related comorbidities following bariatric surgery in a veteran population. Obesity surgery. Nov. 2012;22(11):1734-1741. [pmid: 23011461].
66 Rutledge T, Groesz LM, Savu M. Psychiatric factors and weight loss patterns following gastric bypass surgery in a veteran population. Obesity surgery. Jan. 2011;21(1):29-35. [pmid: 19847571].
67 Arterburn DE, Westbrook EO, Bogart TA, Sepucha KR, Bock SN, Weppner WG. Randomized trial of a video-based patient decision aid for bariatric surgery. Obesity (Silver Spring, Md.). Aug. 2011;19(8):1669-1675.
68 Kalarchian MA, Marcus MD, Courcoulas AP, Cheng Y, Levine MD. Preoperative lifestyle intervention in bariatric surgery: initial results from a randomized, controlled trial. Obesity (Silver Spring, Md.). Feb. 2013;21(2):254-260.
69 Kalarchian MA, Marcus MD, Courcoulas AP, Cheng Y, Levine MD, Josbeno D. Optimizing long-term weight control after bariatric surgery: a pilot study. Surgery for obesity and related diseases : official journal of the American Society for Bariatric Surgery. Nov-Dec. 2012;8(6):710-715. [pmid: 21719357].
70 Petasne Nijamkin M, Campa A, Samiri Nijamkin S, Sosa J. Comprehensive behavioral-motivational nutrition education improves depressive symptoms following bariatric surgery: a randomized, controlled trial of obese Hispanic americans. Journal of nutrition education and behavior. Nov-Dec. 2013;45(6):620-626. [pmid: 23819903].
71 Peterli R, Borbely Y, Kern B, et al. Early results of the Swiss Multicentre Bypass or Sleeve Study (SM-BOSS): a prospective randomized trial comparing laparoscopic sleeve gastrectomy and Roux-en-Y gastric bypass. Annals of surgery. Nov. 2013;258(5):690-694. discussion 695. [pmid: 23989054].
72 Shah M, Snell PG, Rao S, et al. High-volume exercise program in obese bariatric surgery patients: a randomized, controlled trial. Obesity (Silver Spring, Md.). Sep. 2011;19(9):1826-1834.
73 Hayden MJ, Dixon JB, Dixon ME, Shea TL, O'Brien PE. Characterization of the improvement in depressive symptoms following bariatric surgery. Obesity surgery. Mar. 2011;21(3):328-335. [pmid: 20559893].
74 Tindle HA, Omalu B, Courcoulas A, Marcus M, Hammers J, Kuller LH. Risk of suicide after long-term follow-up from bariatric surgery. The American journal of medicine. Nov. 2010;123(11):1036-1042. [pmid: 20843498].
75 Lapidoth JD, Ghaderi A, Norring C. Binge eating in surgical weight-loss treatments. Long-term associations with weight loss, health related quality of life (HRQL), and psychopathology. Eating and weight disorders : EWD. Dec. 2011;16(4):263-269.
76 Ahmed AT, Warton EM, Schaefer CA, Shen L, McIntyre RS. The effect of bariatric surgery on psychiatric course among patients with bipolar disorder. Bipolar disorders. Aug. 5. 2013.
77 Alosco ML, Galioto R, Spitznagel MB, et al. Cognitive function after bariatric surgery: evidence for improvement 3 years after surgery. American journal of surgery. Oct. 10. 2013.
78 Odom J, Zalesin KC, Washington TL. Behavioral predictors of weight regain after bariatric surgery. Obesity surgery. Mar. 2010;20(3):349-356. [pmid: 19554382].
79 Batsis JA, Lopez-Jimenez F, Collazo-Clavell ML, Clark MM, Somers VK, Sarr MG. Quality of life after bariatric surgery: a population-based cohort study. The American journal of medicine. Nov. 2009;122(11):1055 e1051-1055 e1010. [pmid: 19854336].
80 Adams TD, Davidson LE, Litwin SE, et al. Health benefits of gastric bypass surgery after 6 years. JAMA : the journal of the American Medical Association. Sep. 19. 2012;308(11):1122-1131. [pmid: 22990271].
81 Abiles V, Rodriguez-Ruiz S, Abiles J. EFFECTIVENESS OF COGNITIVE-BEHAVIORAL THERAPY IN MORBIDLY OBESE CANDIDATES FOR BARIATRIC SURGERY WITH AND WITHOUT BINGE EATING DISORDER. Nutricion hospitalaria. Septiembre-Octubre. 2013;28(5):1523-1529. [pmid: 24160210].
82 Ashton K, Drerup M, Windover A, Heinberg L. Brief, four-session group CBT reduces binge eating behaviors among bariatric surgery candidates. Surg. Mar-Apr. 2009;5(2):257-262.
83 Wild B, Herzog W, Wesche D, Niehoff D, Muller B, Hain B. Development of a group therapy to enhance treatment motivation and decision making in severely obese patients with a comorbid mental disorder. Obesity surgery. May. 2011;21(5):588-594. [pmid: 19949887].
84 Ashton K, Heinberg L, Merrell J, Lavery M, Windover A, Alcorn K. Pilot evaluation of a substance abuse prevention group intervention for at-risk bariatric surgery candidates. Surg. May-Jun. 2013;9(3):462-467.