# METHODS

## TOPIC DEVELOPMENT

This project was nominated by Dr. Lisa Kearney, Senior Consultant for Technical Assistance, VA Central Office Mental Health Operations. Currently, the VHA does not have a policy requiring that all bariatric surgery candidates undergo a psychological evaluation prior to surgery. The Office of Patient Care Services and the Office of Clinical Operations are interested in reviewing the evidence for or against this practice to help determine if the VHA should implement mental health evaluations for bariatric surgery candidates prior to bariatric surgery. Initially, VA policy makers wanted to know if there was convincing evidence that routine specialized pre-operative screening for mental health conditions resulted in better patient outcomes, either in terms of patient selection for surgery or by identifying individuals who would benefit from a pre-operative intervention aimed at modifying mental health comorbidities. However, a preliminary literature search did not identify any studies that examined the impact of pre-operative mental health screening versus no screening on outcomes related to bariatric surgery. Therefore, with the input from a technical expert panel (TEP), this overarching goal was divided into 3 related questions for which a preliminary literature search indicated published data were likely to exist. Initial key questions were refined with input from a technical expert panel.

The final key questions are:

Key Question 1. What is the prevalence of mental health conditions among bariatric surgery candidates?

Key Question 2. What is the association between pre-operative mental health conditions and bariatric outcomes, including weight loss, quality of life, adherence to behavioral guidelines, risk of suicide, prevalence of mental health conditions, and peri-operative complications?

Key Question 3. Is there evidence to support any pre-operative intervention in patients with mental health disorders to improve post-operative bariatric outcomes, including weight loss? With the input from VA stakeholders and our technical experts, we further refined the term, “mental health conditions” to include:

1. The diagnosis of depression, anxiety, post-traumatic stress disorder, personality disorders, substance abuse disorders, or suicidality;
2. Eating disorders, primarily binge eating disorders.

Eating behaviors that are not classified as disorders, (eg, “grazing” and “cognitive restraint”), while important, were outside our scope of interest and were not included. We did not classify cigarette smoking as a substance use disorder.

“Candidates” was defined as persons seeking or being evaluated for possible bariatric surgery. We distinguish this population from a population of patients who all received bariatric surgery.

The PROSPERO registration number is CRD42014008675.

## SEARCH STRATEGY

We searched PubMed, MEDLINE on OVID, and PsycINFO using a broad set of search terms including “bariatric” or “obesity” or the names of the various surgical procedures and then terms for mental health conditions, maladaptive eating, binge eating, and other eating disorders. Because a member of our team had participated in an earlier systematic review on the related topic of pre-operative predictors of weight loss following bariatric surgery1 and our review of that project's search strategy and methods for identifying relevant articles gave us confidence their results were relevant to our needs, we used their search and results to cover the period from 1988 through 2010, and therefore ran our searches from October 2009 through August 2014. We then supplemented these 2 searches with a “related articles” search in PubMed between January 1990 and August 2014 to identify literature related to a key article by Malik and colleagues,2 as well as a targeted search in the psychological literature database PsycINFO for articles related to bariatric surgery and mental health conditions published between January 2009 and August 2014 (see full search strategy details in Appendix A). Additional studies were recommended for inclusion by technical expert panel members and peer reviewers.

## STUDY SELECTION

After conducting an initial pilot screening of 200 titles in order to calibrate all 4 reviewers, all titles identified by the searches were independently reviewed by each of the 4 reviewers (AM, AD, MM, PS). Any title selected by at least one reviewer was included for abstract and full text review.

After eliminating obviously irrelevant titles, we assessed abstracts or full text articles for eligibility. To be included at this stage, an article had to address at least one key question, report findings from primary research or be a systematic review, and report data for patients with a BMI of 35 or greater (Appendix B). All articles were screened independently by 2 reviewers, and all inclusion conflicts were discussed with the larger group.

Within each key question, additional criteria were specified so that the review would focus on the highest quality, and most relevant studies. For Key Question 1, studies with data on prevalence were included if they met one of the following criteria: (1) random or consecutive sampling and over 200 patients or multiple study sites; (2) studies that did not use random or consecutive sampling and over 500 patients; (3) all studies of US Veterans; and (4) all clinical trials, whether randomized or non-randomized. Studies had to measure specific mental health conditions or eating disorders and had to do so with a recognized method (such as a validated instrument or a clinical evaluation which was sometimes, but not always, the Structured Clinical Interview for DSM-IV (SCID)). Studies had to report the prevalence of patients with the condition, rather than an average score of the overall population on a diagnostic scale. For example, we included studies stating, “the percent of persons with major depressive disorder was 15%,” but not studies reporting, “the mean score on the Beck Depression Inventory was 25.” In addition, we required pre-operative classifications of mental health conditions and eating disorders to be made pre-operatively; in other words, we excluded studies that asked patients to recall their pre-operative health status. For Key Question 2, we used the same criteria to restrict the sample to the better quality, more relevant samples, but also required studies to report post-operative assessments of at least one target outcome. For Key Question 3, the assessed intervention had to occur pre-operatively, the outcomes had to be post-operative, and the target had to be related to eating disorders or mental health comorbidities.

## DATA ABSTRACTION

Data were extracted by 2 independent reviewers, and discrepancies were reconciled by the entire research team.

For Key Question 1 and Key Question 2, articles had data abstracted on the country of origin, whether findings were presented for US Veterans, sample analyzed, method of recruitment, details of the sample demographics, details of bariatric surgery, mental health diagnoses assessed, methods of assessment, and whether the assessments were kept confidential from the surgery team.17 This latter item was added at the suggestion of the TEP, as there is evidence that reported prevalence is higher when subjects are told their response will be kept confidential from the surgical team. After identification of studies meeting all eligibility criteria, the appropriate prevalence or outcome data were highlighted by the clinician data abstractor and then given to the research team statistician for extraction of quantitative data.

For Key Question 3, articles discussing pre-operative interventions had data abstracted on the intervention setting, patient characteristics, description of the intervention, description of the care or treatments to which the intervention was compared, type of bariatric procedure patients underwent post-intervention, outcomes assessed, instruments used to assess the outcomes, timing of the outcome assessment, and the article findings.

## QUALITY ASSESSMENT

For Key Question 1 and Key Question 2, articles about prevalence and association were assessed for the representativeness of participants to some larger population.

For Key Question 3, articles addressing pre-operative interventions were assessed for quality using a modified Cochrane Risk of Bias tool to establish high, low, or unclear bias on 7 factors: outcome, allocation concealment, blinding of participants and personnel, blinding of outcome assessment, incomplete outcome data, selective reporting, and other bias.18

## DATA SYNTHESIS

We constructed evidence tables showing characteristics and results for all included studies, organized by key question. We analyzed studies to compare their characteristics, methods, and findings. We summarized findings for each key question and drew conclusions based on qualitative synthesis of the findings. For Key Question 1, we graphed the prevalence data from each study. For studies reporting more than one method for a particular mental health condition, the most relevant measure was selected by the study team psychiatrist. We also calculated the weighted median value, and compared these values between studies with different populations and designs to test the stability of the estimates.

## RATING THE BODY OF EVIDENCE

The evidence for Key Question 3 was assessed using the GRADE criteria, which uses the domains of study design limitations, inconsistency, indirectness, and imprecision in results.19 The evidence for Key Questions 1 and 2 were also assessed using the same domains. The GRADE Working Group classified the quality of evidence across outcomes according to the following criteria:

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Very Low = Any estimate of effect is very uncertain.

## PEER REVIEW

A draft version of this report was reviewed by 9 peer reviewers and 4 operational partners. Reviewer comments were addressed and our responses were incorporated into the final report. The complete set of comments and responses can be found in Appendix C.