# INTRODUCTION

Obesity rates in the US have risen to near epidemic levels. After a period of relative stability from 1960 to 1980, the proportion of adults with a body mass index (BMI) above 30 increased steadily to over 35% by 2010.^3,4^ Despite a plateauing of rates in recent years,5 the prevalence and consequences of obesity remain significant enough that the American Medical Association officially declared it a disease in 2013.^6^ Obesity has been linked to multiple negative health effects, including cardiovascular disease, Type 2 diabetes, hypertension, hyperlipidemia, and obstructive sleep apnea. Even after controlling for other risk factors, non-elderly individuals with a BMI of 30 to <35 have a 20% higher relative risk of death compared to their normal weight counterparts while those with a BMI ≥35 have more than an 80% higher risk, mostly due to the effects of cardiovascular disease.7,8

While caloric restriction, exercise, and behavioral modification remain mainstays for the treatment of overweight individuals (BMI 25 to <35), these strategies have not been shown to produce sustained weight loss in the severely obese (BMI≥35). As a reflection that more intensive strategies may be required in these patients, the National Institutes of Health established guidelines for weight loss surgery in 1991 that included a BMI≥40 or a BMI≥35 in the presence of significant comorbidities.9 Since that time, bariatric surgery has become increasingly popular for the treatment of obesity, and has been associated with greater and more sustained weight loss. Bariatric surgery has also increased short term resolution of medical comorbidities – including diabetes – when compared to non-surgical therapies.10-12 However, concerns remain about the durability of improvements and the risks of surgery because outcomes beyond 5 years have not been published for US-based samples.

A variety of surgical procedures have been used to induce weight loss for severely obese patients. They result in weight loss via different mechanisms: mechanically restricting the size of the stomach, bypassing a portion of the intestines, or by a combination of these mechanisms. Additionally, there is evidence that these procedures generate alterations in gastric and neuropeptides that play a role in weight loss and early satiety.

Currently, the most common procedures performed are done laparoscopically, and they include gastric banding (adjustable gastric band), gastric bypass (Roux-en-Y gastric bypass) and gastric sleeve. The biliopancreatic diversion and vertical banded gastroplasty are performed infrequently and are primarily done by select surgeons and centers (specifics of these procedures will not described in detail).

Gastric banding achieves weight loss by creating gastric restriction. The uppermost portion of the stomach is encircled by a band to create a gastric pouch with a capacity of 15 to 30 cc. The band consists of an inflatable doughnut-shaped balloon whose diameter can be adjusted by adding or removing saline via a reservoir port beneath the skin. The bands are adjustable allowing the size of the gastric outlet to be modified, depending on the rate of a patient's weight loss.

Gastric bypass achieves weight loss through a combination of gastric restriction and malabsorption. Reduction of the stomach to a small gastric pouch results in feelings of satiety following even small meals. This small pouch is connected to the lower segment of the small intestine, bypassing the proximal small intestine. Thus, absorptive function is reduced. Possibly also aiding weight loss is the production of unpleasant gastrointestinal symptoms following ingestion of particular foods: symptoms include abdominal pain, cramping, and diarrhea.

Gastric sleeve is a more recently adopted procedure where the stomach is stapled into a tube. This procedure has been gaining interest as it relatively simple to perform and offers a lower post-operative complication rate. It appears to have successful weight loss results and improvements in comorbidities, but longer term results, beyond 5 years, are not yet known.

Not all patients receive equal benefit from bariatric surgery. Some patients fail to lose adequate weight, lose but quickly regain weight, or have only marginal improvement in medical comorbidities. There is increasing interest in identifying bariatric candidates in whom surgery may be less effective, and in developing strategies to improve their post-operative outcomes.1 Psychosocial factors are commonly cited as important predictors of post-operative outcomes.13,14 Many bariatric surgery programs formally screen for mental health conditions during the pre-operative assessment in an attempt to select patients with the highest compliance and likelihood of successful weight loss, as well to identify patients at risk for worsening mental health or substance abuse after the surgery.15,16 Others, including the Veterans Health Administration (VHA), do not require formal evaluation. Whether screening for mental health conditions in this population improves patient selection or post-operative outcomes remains unknown.