# STUDY SELECTION

Question | Answer
Study Design | Randomized clinical trial
Study Design | Controlled clinical trial
Study Design | Case series ≥ 10 subjects
Study Design | Other (specify)
Study Design | Case series < 10 subjects (STOP)
Study Design | Other kind of review (commentary, editorial non-systematic review, etc) (STOP)
Study Design | Systematic review/Meta-analysis (STOP)
Does article study bariatric surgery? (check all that apply) | Bariatric surgery candidates
Does article study bariatric surgery? (check all that apply) | Gastric bypass
Does article study bariatric surgery? (check all that apply) | Adjustable banding
Does article study bariatric surgery? (check all that apply) | Biliopancreatic diversion
Does article study bariatric surgery? (check all that apply) | Vertical banded gastroplasty
Does article study bariatric surgery? (check all that apply) | Banded gastric bypass
Does article study bariatric surgery? (check all that apply) | Sleeve gastrectomy
Does article study bariatric surgery? (check all that apply) | Mix of common bariatric surgeries
Does article study bariatric surgery? (check all that apply) | Other bariatric surgery, NOS
Does article study bariatric surgery? (check all that apply) | Other bariatric surgeries (STOP)
Does article study bariatric surgery? (check all that apply) | Not bariatric surgery (STOP)
Are data presented on patients with BMI≥ 35? | Yes
Are data presented on patients with BMI≥ 35? | No (STOP)
What is the number of sites included in the study? | 1
What is the number of sites included in the study? | 2
What is the number of sites included in the study? | 3
What is the number of sites included in the study? | 4
What is the number of sites included in the study? | Other (specify)
What is the (approximate) sample size? | 10-50
What is the (approximate) sample size? | 51-150
What is the (approximate) sample size? | 151-500
What is the (approximate) sample size? | >500
What is the (approximate) sample size? | Not reported
Does the sample specifically include Veterans? | Yes
Does the sample specifically include Veterans? | No
Is the purpose of the study to: (check all that apply) | Report prevalence of psychological or other conditions
Is the purpose of the study to: (check all that apply) | Report associations between pre- Operative characteristics and post- operative outcomes
Is the purpose of the study to: (check all that apply) | Report results of an intervention to improve pre-operative status
Is the purpose of the study to: (check all that apply) | Test instrument for psychiatric Screening of bariatric candidates
Is the purpose of the study to: (check all that apply) | Other (STOP)
If the study is about prevalence, what percentage of subjects received surgery? | 100%
If the study is about prevalence, what percentage of subjects received surgery? | Other % (specify)
If the study is about prevalence, what percentage of subjects received surgery? | Not stated
What domains of pre-operative comorbidities or conditions are measured? (Check all that apply) | Mood disorders (depression, bipolar, etc)
What domains of pre-operative comorbidities or conditions are measured? (Check all that apply) | Anxiety disorders (anxiety, OCD, PTSD)
What domains of pre-operative comorbidities or conditions are measured? (Check all that apply) | Personality disorders (Axis 2 disorders, borderline, schizotypal, narcissistic, histronic, etc)
What domains of pre-operative comorbidities or conditions are measured? (Check all that apply) | Sexual abuse
What domains of pre-operative comorbidities or conditions are measured? (Check all that apply) | Substance abuse
What domains of pre-operative comorbidities or conditions are measured? (Check all that apply) | Psychotic disorders
What domains of pre-operative comorbidities or conditions are measured? (Check all that apply) | ADHD
What domains of pre-operative comorbidities or conditions are measured? (Check all that apply) | MMPI or subscales
What domains of pre-operative comorbidities or conditions are measured? (Check all that apply) | Other psychiatric disorders (specify)
What domains of pre-operative comorbidities or conditions are measured? (Check all that apply) | Maladaptive eating
What domains of pre-operative comorbidities or conditions are measured? (Check all that apply) | Self-esteem
What domains of pre-operative comorbidities or conditions are measured? (Check all that apply) | Cognitive dysfunction (dementia, developmental delay/ mental retardation, unspecified memory issues)
What domains of pre-operative comorbidities or conditions are measured? (Check all that apply) | Other mental health traits (specify)
What domains of pre-operative comorbidities or conditions are measured? (Check all that apply) | Non-psychiatric comorbidities (diabetes, etc)
What domains of pre-operative comorbidities or conditions are measured? (Check all that apply) | Quality of life
What domains of pre-operative comorbidities or conditions are measured? (Check all that apply) | Mandatory pre-operative weight loss
What post-operative outcomes are reported? | N/A this is not a study that includes post-operative outcomes
What post-operative outcomes are reported? | Weight, BMI
What post-operative outcomes are reported? | Psychiatric conditions
What post-operative outcomes are reported? | Suicide
What post-operative outcomes are reported? | Substance abuse
What post-operative outcomes are reported? | Quality of life
What post-operative outcomes are reported? | Eating patterns
What post-operative outcomes are reported? | Other (specify)